# Glossary

Biologic: Adalimumab, alefacept, etanercept, infliximab, and ustekinumab.
Body mass index (BMI): A measure of body fat based on height and weight that applies to adult men and women. There are four categories including underweight (≤18.5), normal weight (18.5–24.9), overweight (25–29.9), and obese (≥30).
Body surface area (BSA): Estimation of BSA affected by psoriasis may be done by using hand area representing approximately 1% of total body surface.
Confidence Intervals (CIs): The range within which the ‘true’ value (e.g. size of effect of an intervention) would be expected to lie if sampling could be repeated a large number of times (e.g. 95% or 99%).
Dermatology Life Quality Index (DLQI): A 10-item dermatology-specific validated questionnaire which assesses the health related quality of life of patients suffering from a particular skin condition. All questions refer to “over the past week”. Scores range from 0 (no effect at all on patient’s life) to 30 (extremely large effect on patient’s life). A 5-point reduction is considered clinically relevant.
EuroQoL-5D (EQ-5D): A standardized instrument for use as a measure of health outcomes; it is utilized in a wide variety of disease states. EQ-5D utility index is scaled between 0 (dead) and 1 (optimal health).
Glomerular filtration rate (GFR): A measure of the overall index of kidney function where the normal GFR varies according to age, sex, and body size, and declines with age.
Health Assessment Questionnaire (HAQ): An assessment of patient-oriented outcomes based on five dimensions including disability, pain, medication effects, costs of care, and mortality. There are two HAQ versions including the Full HAQ, which assesses all of the five dimensions, and the Short HAQ, which contains only the HAQ disability index (HAQ-DI) and the HAQ’s patient global and pain visual analog scales (VAS).
Health Assessment Questionnaire Disability Index (HAQ-DI): A 20 question, eight category assessement of a paitent’s level of functional ability and includes questions of fine movements of the upper extremity, locomotor activities of the lower extremity, and activities that involve both upper and lower extremities. Patient responses are based on a scale from zero, representing no disability, to three, corresponding to complete disability.
Health-Related Quality-of-Life (HRQoL): A person or cohort’s perceived physical and mental health over time. Often assesed in chronic plaque psoriasis evaluations using the Dertmatology Life Quality Index (DLQI), 36-item Medical Outcomes Study Short-Form General Health Survey (SF-36) or other disease-specific or general measures.
Intention to treat (ITT): One in which all of the participants in a trial are analysed according to the intervention to which they were allocated, whether they received it or not.
Major adverse cardiac events (MACE): Psoriasis, an inflammatory skin disease, if severe, has been observed to be a risk factor for cardiovascular disease; however, the degree of the association with MACE, such as myocardial infarction, stroke and cardiovascular death, has not been defined.
Meta-Analysis: The process of extracting and pooling data from several studies investigating a similar topic to synthesize a final outcome.
Neutralizing antibodies: A phenomenon observed with prolonged therapy of TNF-alpha inhibitors, including infliximab (Remicade), adalimumab (Humira), and etanercept (Enbrel), which may lead to the development of autoantibodies that counteract the TNF-alpha antagonist activity of the drugs and reduces efficacy.
Nonbiologic: Acitretin, cyclosporine, and methotrexate.
Patient’s Assessment of Global Improvement: A measure of patient’s impression of how well his/her disease is controlled. The score ranges from 0 (complete disease control) to 3 (uncontrolled disease).
Percent activity impairment due to psoriasis: Percent impairment in regular activities was evaluated using the Work Productivity and Activity Impairment Questionnaire: Specific Health Problem (WPAI-SHP), a 6-item questionnaire that measures effect of psoriasis on daily activity impairment, number of hours worked and the number of hours missed from work. Scores range from 0% to 100%. A decrease in percent impairment indicates improvement.
Percent impairment while working due to psoriasis: Percent impairment while working was evaluated using the Work Productivity and Activity Impairment Questionnaire: Specific Health Problem (WPAI-SHP), a 6-item questionnaire that measures effect of psoriasis on daily activity impairment, number of hours worked and the number of hours missed from work. Scores range from 0% to 100%. A decrease in percent impairment indicates improvement.
Percent overall work impairment due to psoriasis: Percent overall work impairment was evaluated using the Work Productivity and Activity Impairment Questionnaire: Specific Health Problem (WPAI-SHP), a 6-item questionnaire that measures effect of psoriasis on daily activity impairment, number of hours worked and the number of hours missed from work. Scores range from 0% to 100%. A decrease in percent overall work impairment indicates improvement.
Percent work time missed due to psoriasis: Percent work time missed due to psoriasis was evaluated using the Work Productivity and Activity Impairment Questionnaire: Specific Health Problem (WPAI-SHP), a 6-item questionnaire that measures effect of psoriasis on daily activity impairment, number of hours worked and the number of hours missed from work. Scores range from 0% to 100%. A decrease in percent work time missed indicates improvement.
Physician’s Global Assessment (PGA): A 6-point scale used to measure the severity of a patient’s disease relative to baseline condition by a dermatologist. Overall lesions are graded for induration, erythema, and scaling. The score ranges from 0=clear (no plaque elevation; no scaling; erythema=hyperpigmentation, pigmented macules, diffuse faint pink or red coloration) to 5=very severe (plaque elevation=very marked; scaling=very coarse; erythema=very severe). A 7-point scale also available with 7 being clear and 6 almost clear, 5 mild, 4 mild to moderate, 3 moderate, 2 moderately severe and 1 being severe psoriasis.
Plaque psoriasis: The most common form of psoriasis, also known as psoriasis vulgaris, recognized by red, raised lesions covered by silvery scales. About 80% of patients with psoriasis have this type.
Psoriasis Area and Severity Index (PASI): A clincal assessment of the severity and extend of disease based on body surface area involvement, erythema, induration, and scaling. The PASI score is commonly used to assess efficacy of psoriasis treatments. The score ranges from 0 (no disease) to 72 (maximal disease). An improvement of 50%, 75%, 90%, 100% from baseline corresponds to PASI 50, PASI 75, PASI 90, and PASI 100, respectively. An improvement of 75% from baseline (PASI 75) is commonly used as a dichotomous cut-off for efficacy in most trials.
Psoriatic Arthritis: Rheumatoid factor-negative inflammatory arthritis associated with psoriasis. This disease is characterised by stiffness, pain, and swelling in the joints, especially of the hands and feet. It affects about 23% of people with psoriasis. Early diagnosis and treatment can help inhibit the progression of joint deterioration.
Psoriasis-related Pruritus Assessment: A scale for evaluating pruritus-related to psoriasis over the previous week; values range from 0 (no itching) to 10 (severe itching). A decrease in score indicates an improvement in pruritus.
Psoriasis Subject Satisfaction Questionnaire (PSSQ): An 18-item psoriasis-specific questionnaire which assesses patients’ satifisfaction. The change from baseline in PSSQ was determined by week X minus baseline, where larger scores indicate improvement.
Relative Risks (RRs): The ratio of an event occurring in an exposed group to an event occurring in a non-exposed group in a given population. A ratio of one indicates no difference in the risk between the two groups.
Subject Global Assessment (SGA): A 6-point scale used to measure the severity of a patient’s disease relative to baseline condition by the subject; values range from 0 (good) to 5 (severe). A decrease in score indicates improvement.
Sensitivity Analyses: A ‘what if’ analysis that helps determine the robustness of a study. Helps determine the degree of importance of each variable for a given outcome.
Standard Deviations (SDs): A measure of the variability of a data set.
Thrombocytopenia: A condition where there is an abnormally low amount of platelets (<50,000 platelets/microliter), components of the blood that assist in clotting, which may lead to abnormal bleeding. Normal human platelet count ranges from 150,000 to 450,000 platelets per microliter of blood.
Tumor necrosis factor (TNF): One of the cytokines, or messengers, known to be fundamental to the disease process that underlies psoriasis. It often plays a key role in the onset and the continuation of skin inflammation.
TNF-alpha inhibitors: Agents that bind to and neutralize the effects of TNF-alpha, a pro-inflammatory cytokine, by preventing its binding to receptors. FDA-approved agents for use in plaque psoriasis include infliximab (Remicade), etanercept (Enbrel), and adalimumab (Humira).
Variance: A measure of the variation shown by a set of observations, defined by the sum of the squares of deviations from the mean, divided by the number of degrees of freedom in the set of observations.
Visual analogue scale (VAS): Direct rating where raters are asked to place a mark at a point between two anchor states appearing at either end of the line. It is used as a method of valuing health states.
Visual analogue scale (VAS) for plaque psoriasis and psoriatic arthritis pain: A scale for evaluating pain due to plaque psoriasis and psoriatic arthritis during the previous week; values range from 0 (no pain) to 100 (pain as bad as it could be). A decrease in score indicates an improvement in pain.