# Applicability of Individual Studies

Table 47 Evaluation of applicability for individual randomized controlled trials

Table 48 Evaluation of applicability for individual observational studies