# Strength of Evidence for Outcomes

Table 12 Strength of evidence for final health outcomes comparing adalimumab with methotrexate

Outcome | Study design and number | Risk of bias | Consistency | Directness | Precisions | Strength of Evidence
Mortality | RCT (1) | Low risk of bias | NA | Direct | NA | Insufficient
| Observational (0) | --- | --- | --- | ---
HRQoL | RCT (1) | Low risk of bias | NA | Direct | Precise | Low
| Observational (1) | Medium risk of bias | NA | Direct | NA
MACE | RCT (0) | --- | --- | --- | --- | Insufficient
| Observational (0) | --- | --- | --- | ---
Diabetes | RCT (0) | --- | --- | --- | --- | Insufficient
| Observational (0) | --- | --- | --- | ---
Psychological Comorbidities | RCT (0) | --- | --- | --- | --- | Insufficient
| Observational (0) | --- | --- | --- | ---

HRQoL= health-related quality of ligr; MACE=major cardiovascular events; NA=not applicable; RCT=randomized controlled trials

Table 13 Strength of evidence for intermediate health outcomes comparing adalimumab with methotrexate

Outcome | Study design and number | Risk of bias | Consistency | Directness | Precisions | Strength of Evidence
Plaque BSA | RCT (0) | --- | --- | --- | --- | Insufficient
| Observational (1) | Medium risk of bias | NA | Direct | NA
PASI | RCT (1) | Low risk of bias | NA | Direct | NA | Low
| Observational (1) | Medium risk of bias | NA | Direct | NA
PGA | RCT (1) | Low risk of bias | NA | Direct | NA | Low
| Observational (1) | Medium risk of bias | NA | Direct | Precise
Patient assessment of disease | RCT (1) | Low risk of bias | NA | Direct | NA | Low
| Observational (0) | --- | --- | --- | ---
Individual symptoms-pain | RCT (1) | Low risk of bias | NA | Direct | NA | Low
| Observational (0) | --- | --- | --- | ---
Individual symptoms- puritus | RCT (1) | Low risk of bias | NA | Direct | NA | Low
| Observational (0) | --- | --- | --- | ---

BSA=body surface area; NA=not applicable; PASI=Psoriasis Area Severity Index; PGA=Physician’s Global Assessment; RCT=randomized controlled trial

Table 14 Strength of evidence for final health outcomes comparing etanercept versus acitretin

Outcome | Study design and number | Risk of bias | Consistency | Directness | Precisions | Strength of Evidence
Mortality | RCT (0) | --- | --- | --- | --- | Insufficient
| Observational (0) | --- | --- | --- | ---
HRQoL | RCT (0) | --- | --- | --- | --- | Insufficient
| Observational (0) | --- | --- | --- | ---
MACE | RCT (0) | --- | --- | --- | --- | Insufficient
| Observational (0) | --- | --- | --- | ---
Diabetes | RCT (0) | --- | --- | --- | --- | Insufficient
| Observational (0) | --- | --- | --- | ---
Psychological Comorbidities | RCT (1) | High risk of bias | NA | Direct | NA | Insufficient
| Observational (0) | --- | --- | --- | ---

HRQoL= health-related quality of ligr; MACE=major cardiovascular events; NA=not applicable; RCT=randomized controlled trials

Table 15 Strength of evidence for intermediate health outcomes comparing etanercept versus acitretin

Outcome | Study design and number | Risk of bias | Consistency | Directness | Precisions | Strength of Evidence
Plaque BSA | RCT (2) | Medium risk of bias | Consistent | Direct | NA | Insufficient
| Observational (0) | --- | --- | --- | ---
PASI | RCT (3) | Medium risk of bias | Consistent | Direct | NA | Moderate
| Observational (0) | --- | --- | --- | ---
PGA | RCT (1) | High risk of bias | NA | Direct | NA | Insufficient
| Observational (0) | --- | --- | --- | ---
Patient assessment of disease | RCT (1) | High risk of bias | NA | Direct | NA | Insufficient
| Observational (0) | --- | --- | --- | ---
Individual symptoms-joint pain | RCT (1) | High risk of bias | NA | Direct | NA | Insufficient
| Observational (0) | --- | --- | --- | ---
Individual symptoms-itching | RCT (1) | High risk of bias | NA | Direct | NA | Insufficient
| Observational (0) | --- | --- | --- | ---

BSA=body surface area; NA=not applicable; PASI=Psoriasis Area Severity Index; PGA=Physician’s Global Assessment; RCT=randomized controlled trial

Table 16 Strength of evidence for final health outcomes comparing etanercept versus methotrexate

Outcome | Study design and number | Risk of bias | Consistency | Directness | Precisions | Strength of Evidence
Mortality | RCT (0) | --- | --- | --- | --- | Insufficient
| Observational (0) | --- | --- | --- | ---
HRQoL | RCT (0) | --- | --- | --- | --- | Insufficient
| Observational (1) | Medium risk of bias | NA | Direct | NA
MACE | RCT (0) | --- | --- | --- | --- | Insufficient
| Observational (0) | --- | --- | --- | ---
Diabetes | RCT (0) | --- | --- | --- | --- | Insufficient
| Observational (0) | --- | --- | --- | ---
Psychological Comorbidities | RCT (0) | --- | --- | --- | --- | Insufficient
| Observational (0) | --- | --- | --- | ---

HRQoL= health-related quality of ligr; MACE=major cardiovascular events; NA=not applicable; RCT=randomized controlled trials

Table 17 Strength of evidence for intermediate health outcomes comparing etanercept versus methotrexate

Outcome | Study design and number | Risk of bias | Consistency | Directness | Precisions | Strength of Evidence
Plaque BSA | RCT (0) | --- | --- | --- | --- | Insufficient
| Observational (1) | High risk of bias | NA | Direct | NA
PASI | RCT (0) | --- | --- | --- | --- | Insufficient
| Observational (2) | Medium risk of bias | NA | Direct | NA
PGA | RCT (0) | --- | --- | --- | --- | Insufficient
| Observational (1) | High risk of bias | NA | Direct | NA
Patient assessment of disease | RCT (0) | --- | --- | --- | --- | Insufficient
| Observational (0) | --- | --- | --- | ---
Individual symptoms | RCT (0) | --- | --- | --- | --- | Insufficient
| Observational (0) | --- | --- | --- | ---

BSA=body surface area; NA=not applicable; PASI=Psoriasis Area Severity Index; PGA=Physician’s Global Assessment; RCT=randomized controlled trial

Table 18 Strength of evidence for final health outcomes comparing infliximab versus methotrexate

Outcome | Study design and number | Risk of bias | Consistency | Directness | Precisions | Strength of Evidence
Mortality | RCT (0) | --- | --- | --- | --- | Insufficient
| Observational (0) | --- | --- | --- | ---
HRQoL | RCT (1) | Medium risk of bias | NA | Direct | NA | Low
| Observational (0) | --- | --- | --- | ---
MACE | RCT (1) | Medium risk of bias | NA | Direct | NA | Insufficient
| Observational (0) | --- | --- | --- | ---
Diabetes | RCT (1) | Medium risk of bias | NA | Direct | NA | Insufficient
| Observational (0) | --- | --- | --- | ---
Psychological Comorbidities | RCT (0) | --- | --- | --- | --- | Insufficient
| Observational (0) | --- | --- | --- | ---

HRQoL= health-related quality of ligr; MACE=major cardiovascular events; NA=not applicable; RCT=randomized controlled trials

Table 19 Strength of evidence for intermediate health outcomes comparing infliximab versus methotrexate

Outcome | Study design and number | Risk of bias | Consistency | Directness | Precisions | Strength of Evidence
Plaque BSA | RCT (0) | --- | --- | --- | --- | Insufficient
| Observational (0) | --- | --- | --- | ---
PASI | RCT (1) | Medium risk of bias | NA | Direct | NA | Low
| Observational (1) | Medium risk of bias | NA | Direct | NA
PGA | RCT (1) | Medium risk of bias | NA | Direct | NA | Low
| Observational (0) | --- | --- | --- | ---
Patient assessment of disease | RCT (0) | --- | --- | --- | --- | Insufficient
| Observational (0) | --- | --- | --- | ---
Individual symptoms | RCT (0) | --- | --- | --- | --- | Insufficient
| Observational (0) | --- | --- | --- | ---

BSA=body surface area; NA=not applicable; PASI=Psoriasis Area Severity Index; PGA=Physician’s Global Assessment; RCT=randomized controlled trial

Table 20 Strength of evidence for final health outcomes comparing ustekinumab versus methotrexate

Outcome | Study design and number | Risk of bias | Consistency | Directness | Precisions | Strength of Evidence
Mortality | RCT (0) | --- | --- | --- | --- | Insufficient
| Observational (0) | --- | --- | --- | ---
HRQoL | RCT (0) | --- | --- | --- | --- | Insufficient
| Observational (1) | Medium risk of bias | NA | Direct | NA
MACE | RCT (0) | --- | --- | --- | --- | Insufficient
| Observational (0) | --- | --- | --- | ---
Diabetes | RCT (0) | --- | --- | --- | --- | Insufficient
| Observational (0) | --- | --- | --- | ---
Psychological Comorbidities | RCT (0) | --- | --- | --- | --- | Insufficient
| Observational (0) | --- | --- | --- | ---

HRQoL= health-related quality of ligr; MACE=major cardiovascular events; NA=not applicable; RCT=randomized controlled trials

Table 21 Strength of evidence for intermediate health outcomes comparing ustekinumab versus methotrexate

Outcome | Study design and number | Risk of bias | Consistency | Directness | Precisions | Strength of Evidence
Plaque BSA | RCT (0) | --- | --- | --- | --- | Insufficient
| Observational (1) | Medium risk of bias | NA | Direct | NA
PASI | RCT (0) | --- | --- | --- | --- | Insufficient
| Observational (1) | Medium risk of bias | NA | Direct | NA
PGA | RCT (0) | --- | --- | --- | --- | Low
| Observational (1) | Medium risk of bias | NA | Direct | NA
Patient assessment of disease | RCT (0) | --- | --- | --- | --- | Insufficient
| Observational (0) | --- | --- | --- | ---
Individual symptoms | RCT (0) | --- | --- | --- | --- | Insufficient
| Observational (0) | --- | --- | --- | ---

BSA=body surface area; NA=not applicable; PASI=Psoriasis Area Severity Index; PGA=Physician’s Global Assessment; RCT=randomized controlled trial

Table 22 Strength of evidence for final health outcomes comparing adalimumab with psoralen plus ultaviolet A

Outcome | Study design and number | Risk of bias | Consistency | Directness | Precisions | Strength of Evidence
Mortality | RCT (0) | --- | --- | --- | --- | Insufficient
| Observational (0) | --- | --- | --- | ---
HRQoL | RCT (0) | --- | --- | --- | --- | Insufficient
| Observational (0) | --- | --- | --- | ---
MACE | RCT (0) | --- | --- | --- | --- | Insufficient
| Observational (0) | --- | --- | --- | ---
Diabetes | RCT (0) | --- | --- | --- | --- | Insufficient
| Observational (0) | --- | --- | --- | ---
Psychological Comorbidities | RCT (0) | --- | --- | --- | --- | Insufficient
| Observational (0) | --- | --- | --- | ---

HRQoL= health-related quality of ligr; MACE=major cardiovascular events; NA=not applicable; RCT=randomized controlled trials

Table 23 Strength of evidence for intermediate health outcomes comparing adalimumab with psoralen plus ultaviolet A

Outcome | Study design and number | Risk of bias | Consistency | Directness | Precisions | Strength of Evidence
Plaque BSA | RCT (0) | --- | --- | --- | --- | Insufficient
| Observational (0) | --- | --- | --- | ---
PASI | RCT (0) | --- | --- | --- | --- | Insufficient
| Observational (1) | Medium risk of bias | NA | Direct | NA
PGA | RCT (0) | --- | --- | --- | --- | Insufficient
| Observational (0) | --- | --- | --- | ---
Patient assessment of disease | RCT (0) | --- | --- | --- | --- | Insufficient
| Observational (0) | --- | --- | --- | ---
Individual symptoms | RCT (0) | --- | --- | --- | --- | Insufficient
| Observational (0) | --- | --- | --- | ---

BSA=body surface area; NA=not applicable; PASI=Psoriasis Area Severity Index; PGA=Physician’s Global Assessment; RCT=randomized controlled trial

Table 24 Strength of evidence for final health outcomes comparing adalimumab with narrow band ultraviolet B

Outcome | Study design and number | Risk of bias | Consistency | Directness | Precisions | Strength of Evidence
Mortality | RCT (0) | --- | --- | --- | --- | Insufficient
| Observational (0) | --- | --- | --- | ---
HRQoL | RCT (0) | --- | --- | --- | --- | Insufficient
| Observational (1) | Medium risk of bias | NA | Direct | NA
MACE | RCT (0) | --- | --- | --- | --- | Insufficient
| Observational (0) | --- | --- | --- | ---
Diabetes | RCT (0) | --- | --- | --- | --- | Insufficient
| Observational (0) | --- | --- | --- | ---
Psychological Comorbidities | RCT (0) | --- | --- | --- | --- | Insufficient
| Observational (0) | --- | --- | --- | ---

HRQoL= health-related quality of ligr; MACE=major cardiovascular events; NA=not applicable; RCT=randomized controlled trials

Table 25 Strength of evidence for intermediate health outcomes comparing adalimumab with narrow band ultaviolet B

Outcome | Study design and number | Risk of bias | Consistency | Directness | Precisions | Strength of Evidence
Plaque BSA | RCT (0) | --- | --- | --- | --- | Insufficient
| Observational (1) | Medium risk of bias | NA | Direct | NA
PASI | RCT (0) | --- | --- | --- | --- | Insufficient
| Observational (1) | Medium risk of bias | NA | Direct | NA
PGA | RCT (0) | --- | --- | --- | --- | Insufficient
| Observational (1) | Medium risk of bias | NA | Direct | NA
Patient assessment of disease | RCT (0) | --- | --- | --- | --- | Insufficient
| Observational (0) | --- | --- | --- | ---
Individual symptoms | RCT (0) | --- | --- | --- | --- | Insufficient
| Observational (0) | --- | --- | --- | ---

Table 26 Strength of evidence for final health outcomes comparing etanercept with narrow band ultraviolet B

Outcome | Study design and number | Risk of bias | Consistency | Directness | Precisions | Strength of Evidence
Mortality | RCT (0) | --- | --- | --- | --- | Insufficient
| Observational (0) | --- | --- | --- | ---
HRQoL | RCT (0) | --- | --- | --- | --- | Insufficient
| Observational (1) | Medium risk of bias | NA | Direct | NA
MACE | RCT (0) | --- | --- | --- | --- | Insufficient
| Observational (0) | --- | --- | --- | ---
Diabetes | RCT (0) | --- | --- | --- | --- | Insufficient
| Observational (0) | --- | --- | --- | ---
Psychological Comorbidities | RCT (0) | --- | --- | --- | --- | Insufficient
| Observational (0) | --- | --- | --- | ---

HRQoL= health-related quality of ligr; MACE=major cardiovascular events; NA=not applicable; RCT=randomized controlled trials

Table 27 Strength of evidence for intermediate health outcomes comparing etanercept with narrow band ultraviolet B

Outcome | Study design and number | Risk of bias | Consistency | Directness | Precisions | Strength of Evidence
Plaque BSA | RCT (0) | --- | --- | --- | --- | Insufficient
| Observational (1) | Medium risk of bias | NA | Direct | NA
PASI | RCT (0) | --- | --- | --- | --- | Insufficient
| Observational (2) | Medium risk of bias | NA | Direct | NA
PGA | RCT (0) | --- | --- | --- | --- | Insufficient
| Observational (1) | Medium risk of bias | NA | Direct | NA
Patient assessment of disease | RCT (0) | --- | --- | --- | --- | Insufficient
| Observational (0) | --- | --- | --- | ---
Individual symptoms | RCT (0) | --- | --- | --- | --- | Insufficient
| Observational (0) | --- | --- | --- | ---

Table 28 Strength of evidence for final health outcomes comparing ustekinumab with narrow band ultraviolet B

Outcome | Study design and number | Risk of bias | Consistency | Directness | Precisions | Strength of Evidence
Mortality | RCT (0) | --- | --- | --- | --- | Insufficient
| Observational (0) | --- | --- | --- | ---
HRQoL | RCT (0) | --- | --- | --- | --- | Insufficient
| Observational (1) | Medium risk of bias | NA | Direct | NA
MACE | RCT (0) | --- | --- | --- | --- | Insufficient
| Observational (0) | --- | --- | --- | ---
Diabetes | RCT (0) | --- | --- | --- | --- | Insufficient
| Observational (0) | --- | --- | --- | ---
Psychological Comorbidities | RCT (0) | --- | --- | --- | --- | Insufficient
| Observational (0) | --- | --- | --- | ---

HRQoL= health-related quality of ligr; MACE=major cardiovascular events; NA=not applicable; RCT=randomized controlled trials

Table 29 Strength of evidence for intermediate health outcomes comparing ustekinumab with narrow band ultraviolet B

Outcome | Study design and number | Risk of bias | Consistency | Directness | Precisions | Strength of Evidence
Plaque BSA | RCT (0) | --- | --- | --- | --- | Insufficient
| Observational (1) | Medium risk of bias | NA | Direct | NA
PASI | RCT (0) | --- | --- | --- | --- | Insufficient
| Observational (1) | Medium risk of bias | NA | Direct | NA
PGA | RCT (0) | --- | --- | --- | --- | Insufficient
| Observational (1) | Medium risk of bias | NA | Direct | NA
Patient assessment of disease | RCT (0) | --- | --- | --- | --- | Insufficient
| Observational (0) | --- | --- | --- | ---
Individual symptoms | RCT (0) | --- | --- | --- | --- | Insufficient
| Observational (0) | --- | --- | --- | ---

Table 30 Strength of evidence for final health outcomes comparing infliximab with narrow band ultraviolet B

Outcome | Study design and number | Risk of bias | Consistency | Directness | Precisions | Strength of Evidence
Mortality | RCT (0) | --- | --- | --- | --- | Insufficient
| Observational (0) | --- | --- | --- | ---
HRQoL | RCT (0) | --- | --- | --- | --- | Insufficient
| Observational (0) | --- | --- | --- | ---
MACE | RCT (0) | --- | --- | --- | --- | Insufficient
| Observational (0) | --- | --- | --- | ---
Diabetes | RCT (0) | --- | --- | --- | --- | Insufficient
| Observational (0) | --- | --- | --- | ---
Psychological Comorbidities | RCT (0) | --- | --- | --- | --- | Insufficient
| Observational (0) | --- | --- | --- | ---

HRQoL= health-related quality of ligr; MACE=major cardiovascular events; NA=not applicable; RCT=randomized controlled trials

Table 31 Strength of evidence for intermediate health outcomes comparing infliximab with narrow band ultraviolet B

Outcome | Study design and number | Risk of bias | Consistency | Directness | Precisions | Strength of Evidence
Plaque BSA | RCT (0) | --- | --- | --- | --- | Insufficient
| Observational (0) | --- | --- | --- | ---
PASI | RCT (0) | --- | --- | --- | --- | Insufficient
| Observational (1) | High risk of bias | NA | Direct | NA
PGA | RCT (0) | --- | --- | --- | --- | Insufficient
| Observational (0) | --- | --- | --- | ---
Patient assessment of disease | RCT (0) | --- | --- | --- | --- | Insufficient
| Observational (0) | --- | --- | --- | ---
Individual symptoms | RCT (0) | --- | --- | --- | --- | Insufficient
| Observational (0) | --- | --- | --- | ---

Table 32 Strength of evidence for final health outcomes comparing alefacept with psoralen plus ultaviolet A

Outcome | Study design and number | Risk of bias | Consistency | Directness | Precisions | Strength of Evidence
Mortality | RCT (0) | --- | --- | --- | --- | Insufficient
| Observational (0) | --- | --- | --- | ---
HRQoL | RCT (0) | --- | --- | --- | --- | Insufficient
| Observational (0) | --- | --- | --- | ---
MACE | RCT (0) | --- | --- | --- | --- | Insufficient
| Observational (0) | --- | --- | --- | ---
Diabetes | RCT (0) | --- | --- | --- | --- | Insufficient
| Observational (0) | --- | --- | --- | ---
Psychological Comorbidities | RCT (0) | --- | --- | --- | --- | Insufficient
| Observational (0) | --- | --- | --- | ---

HRQoL= health-related quality of ligr; MACE=major cardiovascular events; NA=not applicable; RCT=randomized controlled trials

Table 33 Strength of evidence for intermediate health outcomes comparing alefacept with psoralen plus ultaviolet A

Outcome | Study design and number | Risk of bias | Consistency | Directness | Precisions | Strength of Evidence
Plaque BSA | RCT (0) | --- | --- | --- | --- | Insufficient
| Observational (0) | --- | --- | --- | ---
PASI | RCT (0) | --- | --- | --- | --- | Insufficient
| Observational (1) | Medium risk of bias | NA | Direct | NA
PGA | RCT (0) | --- | --- | --- | --- | Insufficient
| Observational (0) | --- | --- | --- | ---
Patient assessment of disease | RCT (0) | --- | --- | --- | --- | Insufficient
| Observational (0) | --- | --- | --- | ---
Individual symptoms | RCT (0) | --- | --- | --- | --- | Insufficient
| Observational (0) | --- | --- | --- | ---

BSA=body surface area; NA=not applicable; PASI=Psoriasis Area Severity Index; PGA=Physician’s Global Assessment; RCT=randomized controlled trial

Table 34 Strength of evidence for final health outcomes comparing etanercept with psoralen plus ultaviolet A

Outcome | Study design and number | Risk of bias | Consistency | Directness | Precisions | Strength of Evidence
Mortality | RCT (0) | --- | --- | --- | --- | Insufficient
| Observational (0) | --- | --- | --- | ---
HRQoL | RCT (0) | --- | --- | --- | --- | Insufficient
| Observational (0) | --- | --- | --- | ---
MACE | RCT (0) | --- | --- | --- | --- | Insufficient
| Observational (0) | --- | --- | --- | ---
Diabetes | RCT (0) | --- | --- | --- | --- | Insufficient
| Observational (0) | --- | --- | --- | ---
Psychological Comorbidities | RCT (0) | --- | --- | --- | --- | Insufficient
| Observational (0) | --- | --- | --- | ---

HRQoL= health-related quality of ligr; MACE=major cardiovascular events; NA=not applicable; RCT=randomized controlled trials

Table 35 Strength of evidence for intermediate health outcomes comparing etanercept with psoralen plus ultaviolet A

Outcome | Study design and number | Risk of bias | Consistency | Directness | Precisions | Strength of Evidence
Plaque BSA | RCT (0) | --- | --- | --- | --- | Insufficient
| Observational (0) | --- | --- | --- | ---
PASI | RCT (0) | --- | --- | --- | --- | Insufficient
| Observational (2) | Medium risk of bias | NA | Direct | NA
PGA | RCT (0) | --- | --- | --- | --- | Insufficient
| Observational (0) | --- | --- | --- | ---
Patient assessment of disease | RCT (0) | --- | --- | --- | --- | Insufficient
| Observational (0) | --- | --- | --- | ---
Individual symptoms | RCT (0) | --- | --- | --- | --- | Insufficient
| Observational (0) | --- | --- | --- | ---

BSA=body surface area; NA=not applicable; PASI=Psoriasis Area Severity Index; PGA=Physician’s Global Assessment; RCT=randomized controlled trial

Table 36 Strength of evidence for final health outcomes comparing infliximab versus psoralen plus ultaviolet A

Outcome | Study design and number | Risk of bias | Consistency | Directness | Precisions | Strength of Evidence
Mortality | RCT (0) | --- | --- | --- | --- | Insufficient
| Observational (0) | --- | --- | --- | ---
HRQoL | RCT (0) | --- | --- | --- | --- | Insufficient
| Observational (0) | --- | --- | --- | ---
MACE | RCT (0) | --- | --- | --- | --- | Insufficient
| Observational (0) | --- | --- | --- | ---
Diabetes | RCT (0) | --- | --- | --- | --- | Insufficient
| Observational (0) | --- | --- | --- | ---
Psychological Comorbidities | RCT (0) | --- | --- | --- | --- | Insufficient
| Observational (0) | --- | --- | --- | ---

HRQoL= health-related quality of ligr; MACE=major cardiovascular events; NA=not applicable; RCT=randomized controlled trials

Table 37 Strength of evidence for intermediate health outcomes comparing infliximab versus psoralen plus ultaviolet A

Outcome | Study design and number | Risk of bias | Consistency | Directness | Precisions | Strength of Evidence
Plaque BSA | RCT (0) | --- | --- | --- | --- | Insufficient
| Observational (0) | --- | --- | --- | ---
PASI | RCT (0) | --- | --- | --- | --- | Insufficient
| Observational (2) | Medium risk of bias | NA | Direct | NA
PGA | RCT (0) | --- | --- | --- | --- | Insufficient
| Observational (0) | --- | --- | --- | ---
Patient assessment of disease | RCT (0) | --- | --- | --- | --- | Insufficient
| Observational (0) | --- | --- | --- | ---
Individual symptoms | RCT (0) | --- | --- | --- | --- | Insufficient
| Observational (0) | --- | --- | --- | ---

BSA=body surface area; NA=not applicable; PASI=Psoriasis Area Severity Index; PGA=Physician’s Global Assessment; RCT=randomized controlled trial

Table 38 Strength of evidence for final health outcomes comparing ustekinumab versus psoralen plus ultaviolet A

Outcome | Study design and number | Risk of bias | Consistency | Directness | Precisions | Strength of Evidence
Mortality | RCT (0) | --- | --- | --- | --- | Insufficient
| Observational (0) | --- | --- | --- | ---
HRQoL | RCT (0) | --- | --- | --- | --- | Insufficient
| Observational (0) | --- | --- | --- | ---
MACE | RCT (0) | --- | --- | --- | --- | Insufficient
| Observational (0) | --- | --- | --- | ---
Diabetes | RCT (0) | --- | --- | --- | --- | Insufficient
| Observational (0) | --- | --- | --- | ---
Psychological Comorbidities | RCT (0) | --- | --- | --- | --- | Insufficient
| Observational (0) | --- | --- | --- | ---

HRQoL= health-related quality of ligr; MACE=major cardiovascular events; NA=not applicable; RCT=randomized controlled trials

Table 39 Strength of evidence for intermediate health outcomes comparing ustekinumab versus psoralen plus ultaviolet A

Outcome | Study design and number | Risk of bias | Consistency | Directness | Precisions | Strength of Evidence
Plaque BSA | RCT (0) | --- | --- | --- | --- | Insufficient
| Observational (0) | --- | --- | --- | ---
PASI | RCT (0) | --- | --- | --- | --- | Insufficient
| Observational (1) | Medium risk of bias | NA | Direct | NA
PGA | RCT (0) | --- | --- | --- | --- | Insufficient
| Observational (0) | --- | --- | --- | ---
Patient assessment of disease | RCT (0) | --- | --- | --- | --- | Insufficient
| Observational (0) | --- | --- | --- | ---
Individual symptoms | RCT (0) | --- | --- | --- | --- | Insufficient
| Observational (0) | --- | --- | --- | ---

BSA=body surface area; NA=not applicable; PASI=Psoriasis Area Severity Index; PGA=Physician’s Global Assessment; RCT=randomized controlled trial

Table 40 Strength of evidence for harms comparing adalimumab versus methotrexate

Outcome | Study design and number | Risk of bias | Consistency | Directness | Precision | Strength of Evidence
Hepatotoxicity | RCT (1) | Low risk of bias | NA | Direct | NA | Insufficient
| Observational (0) | --- | --- | --- | ---
Nephrotoxicity | RCT (0) | --- | --- | --- | --- | Insufficient
| Observational (0) | --- | --- | --- | ---
Hematologic toxicity | RCT (0) | --- | --- | --- | --- | Insufficient
| Observational (0) | --- | --- | --- | ---
Hypertension | RCT (0) | --- | --- | --- | --- | Insufficient
| Observational (0) | --- | --- | --- | ---
Alterations in metabolic parameters | RCT (0) | --- | --- | --- | --- | Insufficient
| Observational (0) | --- | --- | --- | ---
Injection site reaction | RCT (0) | --- | --- | --- | --- | Insufficient
| Observational (0) | --- | --- | --- | ---
Malignancy | RCT (0) | --- | --- | --- | --- | Insufficient
| Observational (0) | --- | --- | --- | ---
Infection | RCT (1) | Low risk of bias | NA | Direct | NA | Low
| Observational (0) | --- | --- | --- | ---
Study withdrawal | RCT (1) | Low risk of bias | NA | Direct | NA | Insufficient
| Observational (0) | --- | --- | --- | ---

NA=not applicable; RCT=randomized cotnrolled trial

Table 41 Strength of evidence for harms comparing alefacept versus cyclosporine

Outcome | Study design and number | Risk of bias | Consistency | Directness | Precision | Strength of Evidence
Hepatotoxicity | RCT (0) | --- | --- | --- | --- | Insufficient
| Observational (0) | --- | --- | --- | ---
Nephrotoxicity | RCT (0) | --- | --- | --- | --- | Insufficient
| Observational (0) | --- | --- | --- | ---
Hematologic toxicity | RCT (0) | --- | --- | --- | --- | Insufficient
| Observational (0) | --- | --- | --- | ---
Hypertension | RCT (0) | --- | --- | --- | --- | Insufficient
| Observational (0) | --- | --- | --- | ---
Alterations in metabolic parameters | RCT (0) | --- | --- | --- | --- | Insufficient
| Observational (0) | --- | --- | --- | ---
Injection site reaction | RCT (0) | --- | --- | --- | --- | Insufficient
| Observational (0) | --- | --- | --- | ---
Malignancy | RCT (0) | --- | --- | --- | --- | Insufficient
| Observational (0) | --- | --- | --- | ---
Infection | RCT (0) | --- | --- | --- | --- | Insufficient
| Observational (0) | --- | --- | --- | ---
Study withdrawal | RCT (0) | --- | --- | --- | --- | Insufficient
| Observational (0) | --- | --- | --- | ---

BSA=body surface area; NA=not applicable; PASI=Psoriasis Area Severity Index; PGA=Physician’s Global Assessment; RCT=randomized controlled trial

Table 42 Strength of evidence for harms comparing etanercept versus acitretin

Outcome | Study design and number | Risk of bias | Consistency | Directness | Precision | Strength of Evidence
Hepatotoxicity | RCT (2) | Low risk of bias | NA | Direct | NA | Insufficient
| Observational (0) | --- | --- | --- | ---
Nephrotoxicity | RCT (0) | --- | --- | --- | --- | Insufficient
| Observational (0) | --- | --- | --- | ---
Hematologic toxicity | RCT (0) | --- | --- | --- | --- | Insufficient
| Observational (0) | --- | --- | --- | ---
Hypertension | RCT (1) | High risk of bias | NA | Direct | NA | Insufficient
| Observational (0) | --- | --- | --- | ---
Alterations in metabolic parameters | RCT (0) | --- | --- | --- | --- | Insufficient
| Observational (0) | --- | --- | --- | ---
Injection site reaction | RCT (1) | High risk of bias | NA | Direct | NA | Insufficient
| Observational (0) | --- | --- | --- | ---
Malignancy | RCT (0) | --- | --- | --- | --- | Insufficient
| Observational (0) | --- | --- | --- | ---
Infection | RCT (1) | High risk of bias | NA | Direct | NA | Insufficient
| Observational (0) | --- | --- | --- | ---
Study withdrawal | RCT (3) | High risk of bias | Inconsistent | Direct | NA | Insufficient
| Observational (0) | --- | --- | --- | ---

BSA=body surface area; NA=not applicable; PASI=Psoriasis Area Severity Index; PGA=Physician’s Global Assessment; RCT=randomized controlled trial

Table 43 Strength of evidence for harms comparing etanercept versus cyclosporine

Outcome | Study design and number | Risk of bias | Consistency | Directness | Precision | Strength of Evidence
Hepatotoxicity | RCT (0) | --- | --- | --- | --- | Insufficient
| Observational (0) | --- | --- | --- | ---
Nephrotoxicity | RCT (0) | --- | --- | --- | --- | Insufficient
| Observational (0) | --- | --- | --- | ---
Hematologic toxicity | RCT (0) | --- | --- | --- | --- | Insufficient
| Observational (0) | --- | --- | --- | ---
Hypertension | RCT (0) | --- | --- | --- | --- | Insufficient
| Observational (0) | --- | --- | --- | ---
Alterations in metabolic parameters | RCT (0) | --- | --- | --- | --- | Insufficient
| Observational (0) | --- | --- | --- | ---
Injection site reaction | RCT (0) | --- | --- | --- | --- | Insufficient
| Observational (0) | --- | --- | --- | ---
Malignancy | RCT (0) | --- | --- | --- | --- | Insufficient
| Observational (0) | --- | --- | --- | ---
Infection | RCT (0) | --- | --- | --- | --- | Insufficient
| Observational (0) | --- | --- | --- | ---
Study withdrawal | RCT (0) | --- | --- | --- | --- | Insufficient
| Observational (0) | --- | --- | --- | ---

BSA=body surface area; NA=not applicable; PASI=Psoriasis Area Severity Index; PGA=Physician’s Global Assessment; RCT=randomized controlled trial

Table 44 Strength of evidence for harms comparing etanercept versus methotrexate

Outcome | Study design and number | Risk of bias | Consistency | Directness | Precision | Strength of Evidence
Hepatotoxicity | RCT (0) | --- | --- | --- | --- | Insufficient
| Observational (0) | --- | --- | --- | ---
Nephrotoxicity | RCT (0) | --- | --- | --- | --- | Insufficient
| Observational (0) | --- | --- | --- | ---
Hematologic toxicity | RCT (0) | --- | --- | --- | --- | Insufficient
| Observational (0) | --- | --- | --- | ---
Hypertension | RCT (0) | --- | --- | --- | --- | Insufficient
| Observational (0) | --- | --- | --- | ---
Total cholesterol | RCT (0) | --- | --- | --- | --- | Insufficient
| Observational (1) | Medium risk of bias | NA | Direct | NA
Weight and BMI | RCT (0) | --- | --- | --- | --- | Insufficient
| Observational (1) | Medium risk of bias | NA | Direct | NA
Injection site reaction | RCT (0) | --- | --- | --- | --- | Insufficient
| Observational (0) | --- | --- | --- | ---
Malignancy | RCT (0) | --- | --- | --- | --- | Insufficient
| Observational (0) | --- | --- | --- | ---
Infection | RCT (0) | --- | --- | --- | --- | Insufficient
| Observational (0) | --- | --- | --- | ---
Study withdrawal | RCT (0) | --- | --- | --- | --- | Insufficient
| Observational (0) | --- | --- | --- | ---

BSA=body surface area; NA=not applicable; PASI=Psoriasis Area Severity Index; PGA=Physician’s Global Assessment; RCT=randomized controlled trial

Table 45 Strength of evidence for harms comparing infliximab versus methotrexate

Outcome | Study design and number | Risk of bias | Consistency | Directness | Precision | Strength of Evidence
Hepatotoxicity | RCT (1) | Medium risk of bias | NA | Direct | NA | Insufficient
| Observational (0) | --- | --- | --- | ---
Nephrotoxicity | RCT (0) | --- | --- | --- | --- | Insufficient
| Observational (0) | --- | --- | --- | ---
Thrombocytopenia | RCT (1) | Medium risk of bias | NA | Direct | NA | Insufficient
| Observational (0) | --- | --- | --- | ---
Hypertension | RCT (1) | Medium risk of bias | NA | Direct | NA | Insufficient
| Observational (0) | --- | --- | --- | ---
Total cholesterol | RCT (0) | --- | --- | --- | --- | Insufficient
| Observational (1) | Medium risk of bias | NA | Direct | NA
Weight and BMI | RCT (0) | --- | --- | --- | --- | Insufficient
| Observational (1) | Medium risk of bias | NA | Direct | NA
Injection site reaction | RCT (1) | Medium risk of bias | NA | Direct | NA | Insufficient
| Observational (0) | --- | --- | --- | ---
Malignancy | RCT (1) | Medium risk of bias | NA | Direct | NA | Insufficient
| Observational (0) | --- | --- | --- | ---
Infection | RCT (1) | Medium risk of bias | NA | Direct | NA | Insufficient
| Observational (0) | --- | --- | --- | ---
Study withdrawal | RCT (1) | Medium risk of bias | NA | Direct | NA | Insufficient
| Observational (0) | --- | --- | --- | ---

BSA=body surface area; NA=not applicable; PASI=Psoriasis Area Severity Index; PGA=Physician’s Global Assessment; RCT=randomized controlled trial

Table 46 Strength of evidence for harms comparing infliximab versus methotrexate

Outcome | Study design and number | Risk of bias | Consistency | Directness | Precision | Strength of Evidence
Hepatotoxicity | RCT (0) | --- | --- | --- | --- | Insufficient
| Observational (0) | --- | --- | --- | ---
Nephrotoxicity | RCT (0) | --- | --- | --- | --- | Insufficient
| Observational (0) | --- | --- | --- | ---
Thrombocytopenia | RCT (0) | --- | --- | --- | --- | Insufficient
| Observational (0) | --- | --- | --- | ---
Hypertension | RCT (0) | --- | --- | --- | --- | Insufficient
| Observational (0) | --- | --- | --- | ---
Total cholesterol | RCT (0) | --- | --- | --- | --- | Insufficient
| Observational (0) | --- | --- | --- | ---
Weight and BMI | RCT (0) | --- | --- | --- | --- | Insufficient
| Observational (0) | --- | --- | --- | ---
Injection site reaction | RCT (0) | --- | --- | --- | --- | Insufficient
| Observational (0) | --- | --- | --- | ---
Malignancy | RCT (0) | --- | --- | --- | --- | Insufficient
| Observational (0) | --- | --- | --- | ---
Infection | RCT (0) | --- | --- | --- | --- | Insufficient
| Observational (0) | --- | --- | --- | ---
Study withdrawal | RCT (0) | --- | --- | --- | --- | Insufficient
| Observational (0) | --- | --- | --- | ---

BSA=body surface area; NA=not applicable; PASI=Psoriasis Area Severity Index; PGA=Physician’s Global Assessment; RCT=randomized controlled trial