# Quality and Characteristics of Included Trials and Studies

Table 4 Characteristics and quality assessment of included studies