# Baseline Characteristics for Included Studies and Trials

Table 3 Baseline characteristics of included studies

Study, Year | Group | N | Age (y) mean(SD) | Female n/N (%) | Race/ethnic group n/N (%) | Wt (kg) mean(SD) | BMI (kg/m^2^) mean(SD) | PASI mean(SD) | BSA (%) mean(SD) | Disease duration (y) mean(SD) | Psoriatic arthritis n/N (%)
CT5, 2012 | Etanercept | 21 | 38.57 (9.53) | 5/21 (23.8) | --- | --- | --- | 20.83 (14.02) | 32.98 (20.21) | --- | ---
CT5, 2012 | Acitretin | 18 | 42.39 (11.95) | 3/18 (16.7) | --- | --- | --- | 26.31 (13.63) | 39.75 (22.96) | --- | ---
Gelfand, 2012 | Adalimumab | 152 | 48.6 (15.5)^*^ | 352/713 (49.4)^*^ | W:606/713(85.0)^*^ | --- | 28.8 (25.3–33.0) *,† | --- | --- | 19 (8–29) *,‡ | 161/713 (22.6)^*^
Gelfand, 2012 | Etanercept | 191 | --- | --- | --- | --- | --- | --- | --- | --- | ---
Gelfand, 2012 | Ustekinumab | 73 | --- | --- | --- | --- | --- | --- | --- | --- | ---
Gelfand, 2012 | MTX | 174 | --- | --- | --- | --- | --- | --- | --- | --- | ---
Gelfand, 2012 | NB-UVB | 123 | --- | --- | --- | --- | --- | --- | --- | --- | ---
Barker, 2011 | Infliximab | 653 | 44.1 (18–78) § | 215/653 (32.9) | W:636/653(97.3) | 84.5(18.6) | 28.0(5.8) | 21.4(8.0)\|\| | 31.9(16.5)\|\| | 18.8(11.6) | 118/653 (18.1)
Barker, 2011 | MTX | 215 | 41.9 (18–69) § | 67/215 (31.2) | W:211/215(98.1) | 83.8(18.2) | 27.7(5.0) | 21.1(7.6) | 31.0(15.0) | 17.0(10.3) | 36/215 (16.7)
Emerit, 2011 | Etanercept | 10 | 55.1 (13.8)^¶^ | 18/40 (45)^¶^ | --- | --- | --- | 21.4(6.1) | --- | (2–37)^¶,**^ | ---
Emerit, 2011 | Infliximab | 10 | --- | --- | --- | --- | --- | 22.3(6.5) | --- | --- | ---
Emerit, 2011 | PUVA | 10 | --- | --- | --- | --- | --- | 21.9(6.3) | --- | --- | ---
Emerit, 2011 | NB-UVB | 10 | --- | --- | --- | --- | --- | 21.3(5.2) | --- | --- | ---
Inzinger, 2011^††^ | Biologics^‡‡^ | 130^§§^ | 46.2(11.8) | 61/172 (35.5)\|\|\|\| | --- | --- | --- | 16.9(7.3) | --- | 22.9(10.5) | ---
Inzinger, 2011^††^ | PUVA | 118^§§^ | 48.5(15.7) | | --- | --- | --- | 15.0(4.0) | --- | 23.4(11.9) | ---
Strober, 2011 | MTX to adalimumab | 41 | 47.4(13.1) | 13/41 (31.7) | W:39/41(95.1) | 89.5(17.5) | --- | 10.2(5.5) | 10.9(7.3) | 19.8(13.5) | 17/41 (41.5)
Strober, 2011 | NBUVB to adalimumab | 29 | 45.7(14.6) | 13/29 (44.8) | W:25/29(86.2) | 86.0(17.8) | --- | 12.8(5.7) | 14.5(12.6) | 23.0(14.1) | 7/29 (24.1)
Garavaglia, 2010 | CyA to etanercept | 4 | 58.3(12.2) | 1/4 (25.0) | --- | --- | --- | --- | --- | 17.0(12.0) | 1/4 (25.0)
Caproni, 2009 | Etanercept | 30 | NR (28–67)^¶¶^ | 17/30 (56.7) | --- | --- | --- | 21.5(9.1) | --- | --- | 0/30 (0)
Caproni, 2009 | Acitretin | 30 | NR (31–65)^¶¶^ | 19/30 (63.3) | --- | --- | --- | 22.3(5.7) | --- | --- | 0/30 (0)
Mazzotta, 2009^††^ | Nonbiologics or phototherapy to etanercept^***^ | 98 | --- | --- | --- | --- | --- | 16.1(7.1) | --- | --- | ---
Gisondi, 2008a | Etanercept | 22 | 55.3(10.9) | 10/22 (45.4) | --- | 79.5(9.4) | 27.3(6.0) | 11.0(4.6) | 12.6(6.3) | 23.5(10.9) | 0/22 (0)
Gisondi, 2008a | Acitretin | 20 | 55.0(11.3) | 8/20 (40.0) | --- | 78.4(10.3) | 27.2(3.1) | 10.4(5.3) | 11.1(7.3) | 18.8(16.6) | 0/20 (0)
Gisondi, 2008b | Etanercept | 58 | 50.2(11.1) | 19/58 (32.7) | --- | 80.1(16.2) | 27.6(5.0) | 18.8(7.4) | --- | 22.0(12.9) | 0/58 (0)
Gisondi, 2008b | Infliximab | 40 | 46.8(11.2) | 12/40 (30.0) | --- | 79.2(15.2) | 26.5(3.5) | 17.7(7.3) | --- | 17.5(13.4) | 0/40 (0)
Gisondi, 2008b | MTX | 43 | 53.1(12.7) | 17/43 (39.5) | --- | 81.0(12.6) | 27.4(3.6) | 8.2(3.1) | --- | 18.6(12.0) | 0/43 (0)
Saurat, 2008 | Adalimumab | 108 | 42.9(12.6) | 38/108 (35.2) | W:98/103(95.1) B:2/103(1.9) A:3/103(2.9) O:0/103(0) H:11/103(10.7) | 81.7(20.0) | --- | 20.2(7.5) | 33.6(19.9) | 17.9(10.1) | 23/108 (21.3)
Saurat, 2008 | MTX | 110 | 41.6(12.0) | 37/110 (33.6) | W:103/108(95.4) B:1/108(0.9) A:4/108(3.7) O:0/108(0) H:9/108(8.3) | 83.1(17.5) | --- | 19.4(7.4) | 32.4(20.6) | 18.9(10.2) | 19/110 (17.3)
Saurat, 2008 | MTX to adalimumab | 95 | --- | --- | --- | --- | --- | --- | --- | --- | ---
Magliocco, 2007 | CyA to alefacept | 11 | 45 (25–65) † | --- | --- | --- | --- | --- | --- | 22(7–32) ¶ | ---
Costanzo, 2005^††^ | Nonbiologics to etanercept^†††^ | 44 | 41.2(NR) | 16/44 (36.4) | --- | --- | --- | 15.6(NR) | 21.7(NR) | 15.5(NR) | 15/44 (34.1)

Table note: A=asian; B=black; BMI=body mass index; BSA=body surface area; CyA=cyclosporine; d=day(s); H=hispanic; kg=kilogram(s); m=meter(s); MTX=methotrexate; N=total population; NBUVB=narrowband ultraviolet B; NR=not reported; O=other; PASI=Psoriasis Area and Severity Index; PUVA=psoralen plus ultraviolet A; SD=standard deviation; W=white; Wt=weight; y=year(s); ---=not reported

* Total population, n=713

† Mean(IQR)

‡ Median(IQR)

§ Mean(range)

|| n=650

¶ Total population, n=40

** Range

†† Baseline characteristics reported by drug class, not individual agent

‡‡ Adalimumab, alefacept, etanercept, infliximab, ustekinumab

§§ Number corresponds to treatment courses, not patients

|||| Total population, n=172

¶¶ Median(range)

*** CyA, corticosteroids, fumaric acid esters, MTX, retinoids, PUVA

††† CyA, corticosteroids, MTX, retinoids