# Search Strategy

## Search 1: MEDLINE® and Cochrane Central Register of Controlled Trials (OVID)

1. psoriasis.mp. or Psoriasis/
2. Psoriasis/or plaque psoriasis.mp.
3. 1 or 2
4. methotrexate.mp. or Methotrexate/
5. cyclosporin.mp. or Cyclosporine/
6. cyclosporine.mp. or Cyclosporine/
7. ciclosporin.mp. or Cyclosporine/
8. calcineurin inhibitor.mp.
9. acitretin.mp. or Acitretin/
10. retinoids.mp. or Retinoids/
11. antimalarials.mp. or Antimalarials/
12. hydroxyurea.mp. or Hydroxyurea/
13. isotretinoin.mp. or Isotretinoin/
14. sulfasalazine.mp. or Sulfasalazine/
15. 6-thioguanine.mp. or Thioguanine/
16. azathioprine.mp. or Azathioprine/
17. cyclophasphamide.mp. or Cyclophosphamide/
18. mycophenolate mofetil.mp.
19. nsaid.mp. or Anti-Inflammatory Agents, Non-Steroidal/
20. antihistamine.mp. or Histamine Antagonists/
21. leflunomide.mp.
22. tacrolimus.mp. or Tacrolimus/
23. fish oil.mp. or Fish Oils/
24. ergocalciferols.mp. or Ergocalciferols/
25. bicillin l-a.mp. or Penicillin G Benzathine/
26. prednisone.mp. or Prednisone/
27. 4 or 5 or 6 or 7 or 8 or 9 or 10 or 11 or 12 or 13 or 14 or 15 or 16 or 17 or 18 or 19 or 20 or 21 or 22 or 23 or 24 or 25 or 26
28. etanercept.mp.
29. infliximab.mp.
30. adalimumab.mp.
31. alefacept.mp.
32. ustekinumab.mp.
33. cnto 1275.mp.
34. biologics.mp.
35. biologic agents.mp.
36. monoclonal antibody.mp. or Antibodies, Monoclonal/
37. t-cell modulator.mp.
38. tumor necrosis factor inhibitor.mp.
39. briakinumab.mp.
40. ABT 874.mp.
41. voclosporin.mp.
42. ISA-247.mp.
43. CP 690,550.mp.
44. certolizumab.mp.
45. cdp870.mp.
46. daclizumab.mp.
47. erlotinib.mp.
48. abatacept.mp.
49. rituximab.mp.
50. golimumab.mp.
51. 28 or 29 or 30 or 31 or 32 or 33 or 34 or 35 or 36 or 37 or 38 or 39 or 40 or 41 or 42 or 43 or 44 or 45 or 46 or 47 or 48 or 49 or 50
52. psoralen.mp. or Ficusin/
53. PUVA Therapy/or puva.mp.
54. phototherapy.mp. or Phototherapy/
55. uvb.mp.
56. uva.mp.
57. laser therapy.mp. or Laser Therapy/
58. Lasers, Excimer/or excimer.mp.
59. goeckerman.mp.
60. ingram.mp.
61. 52 or 53 or 54 or 55 or 56 or 57 or 58 or 59 or 60
62. 51 and 61
63. 3 and 62
64. 27 and 51
65. 3 and 64
66. 63 or 65

## Search 2: MEDLINE®, The Cochrane Database of Systematic Reviews, Database of Abstracts of Reviews of Effects, and Health Technology Assessment database

1. randomized controlled trials/
2. controlled clinical trial.sh.
3. clinical trial/
4. randomi$ control$ trial$.tw.
5. clinical trial$.tw.
6. trial$.tw.
7. 1 or 2 or 3 or 4 or 5 or 6
8. review literature/
9. meta-analysis.sh.
10. meta-analy$.tw.
11. metaanaly$.tw.
12. (meta adj analy$).tw.
13. 8 or 9 or 10 or 11 or 12
14. (indirect adj2 comparison$).tw.
15. (indirect adj2 evaluat$).tw.
16. (indirectly adj2 compar$).tw.
17. bayesian.tw.
18. (mixed treatment adj compar$).tw.
19. (mixed treatment adj evaluat$).tw.
20. MTC.tw.
21. 14 or 15 or 16 or 17 or 18 or 19 or 20
22. 7 and 13
23. 21 and 22
24. psoriasis.mp. [mp=ps, rs, ti, ot, ab, nm, hw, ui, an, tx, kw, sh, ct]
25. psoriasis/
26. chronic psoriasis.mp. [mp=ps, rs, ti, ot, ab, nm, hw, ui, an, tx, kw, sh, ct]
27. 24 or 25 or 26
28. 23 and 27
29. remove duplicates from 28