# Acronyms/Abbreviations

AHRQ: Agency for Healthcare Research and Quality
ALT: alanine aminotransferase
AST: aspartate aminotransferase
BMI: body mass index
BSA: body surface area
CER: Comparative Effectiveness Review
CI: confidence interval
CPP: chronic plaque psoriasis
DLQI: dermatology life quality index
EQ-5D: EuroQol 5-Dimension™ (test of health-related quality of life)
EQ-5D VAS: EQ-5D visual analogue scaleFDA = Food and Drug Administration
HAQ-DI: Health Assessment Questionnaire Disability Index
HRQoL: health-related quality of life
IL: interleukin
Kg: kilogram
Kg/m^2^: kilogram per meter squared
MACE: major adverse cardiovascular events
MCS: Mental Component Summary (part of SF-36)
NB-UVB: narrowband-ultraviolet B
NR: not reported
PASI: Psoriasis Area and Severity Index
PCS: Physical Component Summary (part of SF-36)
PGA: Physician’s Global Assessment
PsA: psoriatic arthritis
PSSQ: Psoriasis Subject Satisfaction Questionnaire
PUVA: psoralen plus ultraviolet A
RCT: randomized controlled trial
SCr: serum creatinine
SF-36: Short Form-36 Health Survey
SGA: Subject Global Assessment
SOE: strength of evidence
TCP: thrombocytopenia
TNF: tumor necrosis factor
ULN: upper limit of normal
UVB: ultraviolet B
5-MOP: 5- methoxypsoralen
8-MOP: 8-methoxypsoralen