# Results

This chapter reports on the results of the literature search and evidence synthesis. First, the results of the literature searching, selection process, and a summary of the study characteristics and methodological quality of the included studies are described. The results of analyses are presented by Key Question (KQ). We present the results of the comparative effectiveness of parenteral pharmacological interventions versus placebo, standard care, or active agents (KQ 1 and KQ 2). These results are organized by drug class (e.g., neuroleptics, opioids) and then are grouped by placebo-controlled studies or direct head to head comparisons of drugs or combinations of drugs. The adverse effect results (KQ 3) are organized by categories of adverse effects (e.g., sedation, nausea/vomiting) and then subgrouped by drug class. This is followed by results for the specific side effect, akathisia (KQ 4). Results related to subpopulations (KQ 5 and KQ 6) appear at the end of this chapter.

Metagraphs and tables reporting the strength of evidence for key outcomes are presented within each applicable section. Within each metagraph, the studies that provided data are identified by the name of the first author and year of publication. A list of acronyms is provided at the end of the report.

## Literature Search

The search identified 3,138 citations from electronic databases. Screening based on titles and abstracts, grey literature searches, and hand searching identified 231 potentially relevant studies that were evaluated for inclusion. Using a standardized inclusion–exclusion form (Appendix B), 71 studies (and three companion studies) were included, and 157 were excluded (Figure 2). Prospective cohort studies were screened for potential inclusion; however, none met the inclusion criteria. There are 69 randomized controlled trials (RCTs) and 2 nonrandomized controlled trials (NRCTs) in the review. One of the included studies had three associated publications. Three studies were published in non-English language journals; the articles were translated and data extracted by third party translators.

Figure 2 Flow diagram of study retrieval and selection

Figure 2 is a flow chart that summarizes study retrieval and selection. It begins with the total number of citations retrieved from the literature searches and ends with the number of studies that met all inclusion criteria of the report. This figure is described in the Section entitled “Literature Search” as follows: “The search identified 2,136 citations from electronic databases. Screening based on titles and abstracts identified 205 potentially relevant studies. We identified 21 additional studies by hand searching the reference lists from included studies, relevant systematic reviews, and conference proceedings. The full text of five articles could not be retrieved through the university interlibrary loan service. Therefore, the full texts of 226 potentially relevant reports were evaluated for inclusion. Using a standardized inclusion–exclusion form (Appendix B), 69 studies were included and 157 were excluded (Figure 2). We screened prospective cohort studies for potential inclusion; however, none met our inclusion criteria. There are 67 randomized controlled trials (RCT) and 2 nonrandomized controlled trials (NRCT) in the review. Three studies were published in non-English language journals; these articles were translated and data were extracted by third party translators. The most frequent reasons for exclusion were: ineligible intervention (53), ineligible study design (44), and ineligible population (18). Forty-two studies were excluded for other reasons (Figure 2). A complete list of excluded studies and reasons for exclusion can be found in Appendix C.

The most frequent reasons for study exclusion were: ineligible intervention (53), ineligible study design (44), and ineligible population (18). Forty-two studies were excluded for other reasons (Figure 2). A complete list of excluded studies and reasons for exclusion can be found in Appendix C.

## Description of Included Studies

There were 71 unique studies (69 RCTs and 2 NRCTs) that met the eligibility criteria. Nine different classes of drugs were investigated: antiemetics (metoclopramide), neuroleptics, ergotamines, nonsteroidal anti-inflammatory drugs (NSAIDs), opioids, corticosteroids, triptans, magnesium sulfate (MgSO_4_), and anithistamines. In addition, there were several studies that examined combinations of active agents compared with other active agents. For the mixed treatment analysis, we identified a group of drugs that were not easily classified and were infrequently studied (i.e., hydroxyzine (Atarax), lidocaine, MgSO_4_, sodium valproate, tramadol, and octreotide). We collectively referred to these drugs as “orphan agents”.

Most trials were of parallel design; three used a cross-over design. Most trials (60, 85 percent) had two study arms. Seven trials (10 percent) had three study arms, and four (6 percent) had four study arms. One study41 described a five armed trial where the efficacy of metamizole, diclofenac, chlorpromazine, MgSO_4_ and placebo were compared. Since this publication did not provide any extractable data, we included three associated publications that compared the placebo arm with diclofenac,42 chlorpromazine,43 and MgSO_4_.44 We did not include the publication on metamizole (dipyrone) since this drug is banned in the United States. In the body of this review, we only cite the three publications from which data were extracted.

Evidence tables that describe the studies in more detail are presented in the results section. The studies were published between 1986 and 2011 (median = 2001 [interquartile range (IQR), 1993 to 2004]). The majority of studies were conducted in the United States (62 percent). The rest were conducted in Canada (13 percent), Turkey (8 percent), and other countries (15 percent). The most commonly reported measure of pain was the visual analogue scale (VAS). While there is no consensus on the minimally clinically important difference, a summary of the research suggests that a change in score between 1 and 2 cm (10–20 mm) on the VAS is considered clinically significant.45–51 In 43 studies (61 percent) migraine was classified using the criteria established by the International Headache Society.

## Methodological Quality of Included Studies

A summary of the risk of bias assessments is presented in Figure 3; the detailed consensus assessments are presented in Appendix D. Overall, 60.6 percent (n = 43) of the trials had an unclear risk of bias, 28.2 percent (n = 20) had low risk, and 11.0 percent (n = 8) had high risk of bias. Risk of bias was generally low for incomplete outcome data, selective reporting, and other bias. This means that these methodological sources of bias were uncommon in this body of evidence. Approximately 50 percent of studies were assessed as unclear risk of bias for sequence generation and allocation concealment.

Figure 3 Risk of bias summary for acute migraine headache trials

Figure 3 displays a Risk of Bias summary chart. This figure is described further in the section “Methodological quality of included studies” as follows: “The risk of bias assessments for the 69 RCTs and 2 NRCTs are presented in Appendix D. A summary of the risk of bias for the 71included studies is presented in Figure 3. Risk of bias was mostly generally low for incomplete outcome data, selective reporting, and other bias. The two domains that were mostly split between low and unclear were sequence generation and allocation concealment. There were marginal amounts of high risk of bias in three domains (sequence generation, allocation concealment and incomplete outcome data). The domain where high risk of bias was the most frequent was blinding of subjective outcomes. Overall, 60.6 percent% of the studies trials had an unclear risk of bias, 28.2 percent% had low risk, and 11.0 percent% had high risk of bias. Eleven studies were funded by industry, seven studies were funded by associations and foundations, eleven studies were funded by industry, one received government funding, and two had other sources of funding. Funding was not reported by 47 studies.”

Twelve studies were funded by industry,52–63 seven were funded by associations and foundations,19,20,64–68 one received government funding,69 and two had other sources of funding.70,71 Funding was not reported by 47 (68 percent) studies.21,22,29,32,42,43,72–112

## Key Question 1 Effectiveness of Parenteral Pharmacological Interventions Versus Standard Care, Placebo or an Active Treatment

The findings for KQ 1 are presented by drug class, comparing the drug class with placebo, if applicable, and then with other active agents. Note that some studies included both head to head and placebo comparisons and appear in both sections. For studies that assessed antiemetics, all but one79 examined metoclopramide. Therefore, we titled the section “Metoclopramide”. As appropriate, we highlight the outcomes that include results from the study that assessed the combination of trimethobenzamide and diphenhydramine.79

### Metoclopramide

#### Key Points

- Patients who received metoclopramide had greater improvement in pain intensity as measured by VAS (mm) compared with those on placebo based on five RCTs (moderate strength of evidence).
- Single trials assessed headache recurrence and headache relief for patients who received metoclopramide compared with placebo (insufficient strength of evidence).
- There was insufficient strength of evidence for improvement in pain intensity (VAS) for patients who received metoclopramide in combination with either dihydroergotamine (DHE) or dexamethasone.
- In general, neuroleptics were more effective than metoclopramide for pain relief based on four trials (low strength of evidence).
- There was no statistically significant difference in change in pain intensity (VAS) for patients receiving metoclopramide compared with prochlorperazine based on two RCTs (low strength of evidence).
- For all other head to head comparisons, single trials compared metoclopramide with another active agent for headache relief, pain free response, headache response, and headache recurrence at various timepoints (insufficient strength of evidence).

#### Results

The results for the metoclopramide studies are summarized below. Table 4 and Table 5 and provide the strength of evidence grades for all key outcomes. See Table 6 for details on study and patient characteristics.

Table 4 Strength of evidence for metoclopramide versus placebo

Comparison | Outcome (N Studies; N Patients) | Strength of Evidence Domains | | | | Strength of Evidence
Comparison | Outcome (N Studies; N Patients) | ROB | Consistency | Direct | Precision | Strength of Evidence
Metoclopramide monotherapy vs. placebo | Pain intensity–VAS (5; 328) | Moderate | Consistent | Direct | Precise | Moderate
Metoclopramide monotherapy vs. placebo | Headache relief (1; 50) | Moderate | Unknown | Direct | Precise | Insufficient
Metoclopramide monotherapy vs. placebo | Headache recurrence (1; 77) | Low | Unknown | Direct | Imprecise | Insufficient
Metoclopramide+ DHE or dexamethasone vs. placebo | Pain improvement (1 RCT [3 arms]; 20) | Moderate | Unknown | Direct | Precise | Insufficient

DHE = dihydroergotamine; N = number; ROB = risk of bias; RCT = randomized control trial; VAS = visual analogue scale

Table 5 Strength of evidence for metoclopramide versus active agents

Comparison | Outcome (N Studies; N Patients) | Strength of Evidence Domains | | | | Strength of Evidence
Comparison | Outcome (N Studies; N Patients) | ROB | Consistency | Direct | Precision | Strength of Evidence
Metoclopramide vs. neuroleptics | Change in pain–VAS (4; 271) | Moderate | Inconsistent | Direct | Precise | Low
Metoclopramide vs. prochlorperazine | Change in pain–VAS (2; 137) | Moderate | Consistent | Direct | Imprecise | Low
Metoclopramide vs. prochlorperazine | Headache recurrence (1; 91) | Low | Unknown | Direct | Imprecise | Insufficient
Metoclopramide vs. prochlorperazine + DPH | Change in pain–VAS (1; 77) | Moderate | Unknown | Direct | Imprecise | Insufficient
Metoclopramide vs. chlorpromazine | Change in pain–VAS (1; 57) | Low | Unknown | Direct | Precise | Insufficient
Metoclopramide + DPH vs. prochlorperazine + DPH | Sustained headache relief (24 hrs) (1; 77) | Moderate | Unknown | Direct | Imprecise | Insufficient
Metoclopramide + DPH vs. prochlorperazine + DPH | Pain free (2 hrs) (1; 77) | Moderate | Unknown | Direct | Imprecise | Insufficient
Metoclopramide + DPH vs. prochlorperazine + DPH | Headache relief (2hrs) (1; 77) | Moderate | Unknown | Direct | Imprecise | Insufficient
Metoclopramide vs. MgSO_4_ | Change in pain (<2 hrs)–VAS (1; 73) | Low | Unknown | Direct | Imprecise | Insufficient
Metoclopramide vs. MgSO_4_ | Headache recurrence (1; 73) | Low | Unknown | Direct | Imprecise | Insufficient
Metoclopramide + paracetemol vs. ondansetron + paracetamol | Change in pain (<2 hrs)–VAS (1; 60) | Moderate | Unknown | Direct | Imprecise | Insufficient
Metoclopramide + paracetemol vs. ondansetron + paracetamol | Change in pain intensity at 24 hrs– NRS (1; 60) | Moderate | Unknown | Direct | Imprecise | Insufficient
Metoclopramide vs. pethidine | Change in pain (<2 hrs)–VAS (1; 99) | Moderate | Unknown | Direct | Precise | Insufficient
Metoclopramide vs. sumatriptan | Change in pain (<2 hrs)–VAS (1; 78) | Moderate | Unknown | Direct | Imprecise | Insufficient
Trimethobenzamide + DPH vs. sumatriptan | Change in pain (<2 hrs)–VAS (1; 40) | Low | Unknown | Direct | Imprecise | Insufficient
Trimethobenzamide + DPH vs. sumatriptan | Pain free response (1 hr) (1; 40) | Low | Unknown | Direct | Imprecise | Insufficient
Trimethobenzamide + DPH vs. sumatriptan | Pain free response (2 hr) (1; 40) | Low | Unknown | Direct | Imprecise | Insufficient
Trimethobenzamide + DPH vs. sumatriptan | Pain free response (24 hrs) (1; 40) | Low | Unknown | Direct | Imprecise | Insufficient
Trimethobenzamide + DPH vs. sumatriptan | Headache response (1 hr) (1; 40) | Low | Unknown | Direct | Imprecise | Insufficient
Trimethobenzamide + DPH vs. sumatriptan | Headache response (2 hr) (1; 40) | Low | Unknown | Direct | Imprecise | Insufficient
Trimethobenzamide + DPH vs. sumatriptan | Headache response (24 hrs) (1; 40) | Low | Unknown | Direct | Imprecise | Insufficient

DPH = diphenhydramine; MgSO_4_ = magnesium sulfate; N = number; NRS = numerical rating scale; ROB = risk of bias; VAS = visual analogue scale

Table 6 Patient and study characteristics of trials comparing metoclopramide with placebo or active agents

Comparison | Author, Year, Country Study Fesign | Timepoints Measured in the ED (Post ED Followup) | Intervention, N Randomized, Dosage, Route of Administration | Mean Age (SD), Females (%), White (%) | Description of Migraine Severity: Mean (SD); Duration of Migraine Prior to Coming Into ED | Primary Outcomes; Secondary Outcomes
Metoclopramide vs. placebo | Cete, 2004, Turkey, RCT83 | 30min, (24 hr) | G1: MET, n=37, 10 mg IV G2: MgSO_4_, n=36, 2 g IV P: Placebo, n=40, 100 mlIV | G1: 40 (13), 33 (89.2), NR G2: 40 (12), 27 (75.0), NR P: 40 (11), 35 (87.5), NR | G1: VAS: 73 mm (25), NR G2: VAS: 70 mm (22), NR P: VAS: 69 mm (19), NR | 1: pain intensity at 30 min (VAS) 2: adverse reactions, need for rescue medication, recurrence at 24 hr
Metoclopramide vs. placebo | Cicek, 2004, Turkey, RCT113 | 45 min, (4 hr) | G1: MET, n=196 (Vascular headache); 140 (tension headache), IM Placebo + MET 10 mg IV G2: MET+PET, n=49, MET 10 mg IV+PET 50 mg IM G3: PET, n=49, IV Placebo+PET 50 mg IM P: Placebo, n=48, NR IV/IM | Total: 38.8 (11.1) vascular headache; 42.1 (13.8) for tension headache; mean age of all subjects 40.2 (12.4), 7.1 (female to male ratio for vascular headache), 2.5 (in tension headache group) | G1: NR, NR G2: NR, NR P: NR, NR | 1: pain intensity (VAS) 2: side effects
Metoclopramide vs. placebo | Coppola, 1995, U.S., RCT92 | 30 min, (48hr) | G1: MET, n=24, 10mg IV G2: PCZ, n=22, 10mg IV P: placebo, n=24, NR IV | G1: NR, NR, NR G2: NR, NR, NR P: NR, NR, NR | G1: nonhatched VAS: 8.1, NR G2: nonhatched VAS:8.7, NR P: nonhatched VAS: 7.6, NR | 1: median pain scores (nonhatched VAS) 2: median nausea scores, median sedation scores
Metoclopramide vs. placebo | Jones, 1996, U.S., RCT91 | 60 min (48 hr) | G1: PCZ, n=28, 10 mg IM G2: MET, n=29, 10 mg IM P: Placebo, n=29, 2 ml IM | Total: 32.1 (2.1), 63 (73.3), NR | G1: VAS: 8.1 (range 6–10), NR G2: VAS: 8.5 (range 7–10), NR P: VAS: 8.0 (range 6–10), NR | 1: median pain scores (VAS) 2: nausea and vomiting
Metoclopramide vs. placebo | Klapper, 1989, U.S., RCT107 | 30 min, (24 hr) | G1: MET+DHE, n=11, 5–10mg MET and 0.75–1.0mg DHE IV G2: MET+DEX, n=9, 5–10mg MET IV, and 6mg DEX IV P: Placebo, n=10, NR IV | G1: NR, NR, NR G2: NR, NR, NR P: NR, NR, NR | G1: NR, NR G2: NR, NR P: NR, NR | 1: improvement by at least one unit (4-pt scale) 2: level of functioning (4-pt scale)
Metoclopramide vs. placebo | Tek, 1990, U.S., RCT95 | 60 min (48hr) | G1: MET, n=24, 10mg IV P: Placebo, n=26, 2 ml IV | G1: NR, NR, NR P: NR, NR, NR | G1: NR, NR P: NR, NR | 1: mean relief score
Metoclopramide vs. neuroleptics | Cameron, 1995, U.S., RCT65 | 45 min, (48hr) | G1: CPZ, n=47, 0.1mg/kg IV G2: MET, n=44, 0.1mg/kg IV | G1: Mean (range): 32.6(17–55), 38 (80.9), NR G2: Mean (range): 31.6(19–54), 35 (79.5), NR | G1: VAS: 7.15 cm; 38.9 hr G2: VAS: 7.76 cm; 47.2 hr | 1: pain relief (VAS) 2: treatment failure, systolic blood pressure, headache recurrence
Metoclopramide vs. neuroleptics | Coppola, 1992, U.S., RCT92 | 30 min, (48hr) | G1: MET, n=24, 10mg IV G2: PCZ, n=22, 10mg IV P: Placebo, n=24, NR IV | G1: NR, NR, NR G2: NR, NR, NR P: NR, NR, NR | G1: nonhatched VAS: 8.1, NR G2: nonhatched VAS:8.7, NR P: nonhatched VAS: 7.6, NR | 1: median pain scores (nonhatched VAS) 2: median nausea scores, median sedation scores
Metoclopramide vs. neuroleptics | Friedman, BW, 2008, U.S., RCT22 | 120 min, (24 hr) | G1: PCZ, n=39, 10 mg IV G2: MET, n=38, 20 mg IV (Both groups receive 25mg of DPH as well) | G1: 34 (10), 33 (84.6), Hispanic: 24 (61.5); Nonhispanic: 15 (38.5); White: 20 (51.3); Black: 35.9); Asian: 1 (2.6); Other: 4 (10.3) G2: 38 (12), 36 (94.7), Hispanic: 26 (68.4); Nonhispanic 12(31.6); White: 20 (52.3); Black: 16 (42.1); Asian: 0 (0.0); Other: 2 (5.3) | G1: 11-pt numerical rating scale: 8.4, 48 hr (median) G2: 11-pt numerical rating scale: 8.8, 72 hr (median) | 1: change in pain intensity 2: sustained pain-free; sustained headache relief; sustained normal functioning; 2hr pain free; 2hr headache relief; rescue medication; adverse events; akathisia; drowsiness
Metoclopramide vs. neuroleptics | Jones, 1996, U.S., RCT 91 | 60 min (48 hr) | G1: PCZ, n=28, 10 mg IM G2: MET, n=29, 10 mg IM P: Placebo, n=29, 2 ml IM | Total: 32.1 (2.1), 63 (73.3), NR | G1: VAS: 8.1 (range 6–10), NR G2: VAS: 8.5 (range 7–10), NR P: VAS: 8.0 (range 6–10), NR | 1: median pain scores (VAS) 2: nausea and vomiting
Metoclopramide versus other active agents | Aktas, 2011, Turkey, NRCT105 | 60 min, (NA) | G1: Ondansetron + Paracetamol, n=30, 4mg Ondansetron IV + 1g Paracetamol IV G2: MET+ Paracetamol, n=30, 10mg MET IV+1g paracetamol IV | G1: 35.3 (9.3), NR, NR G2: 37 (9.3), NR, NR | G1: NR, NR G2: NR, NR | 1: pain severity (10-pt numeric rating scale; 0 is absence of pain, 10 is severe pain) 2: additional analgesia, mean durations of ED stay
Metoclopramide versus other active agents | Cete, Y, 2004, Turkey, RCT83 | 30min, (24 hr) | G1: MET, n=37, 10 mg IV G2: MgSO_4_, n=36, 2 g IV P: Placebo, n=40, 100 mlIV | G1: 40 (13), 33 (89.2), NR G2: 40 (12), 27 (75.0), NR P: 40 (11), 35 (87.5), NR | G1: VAS: 73 mm (25), NR G2: VAS: 70 mm (22), NR P: VAS: 69 mm (19), NR | 1: pain intensity at 30 min (VAS) 2: adverse reactions, rescue medication, recurrence at 24 hr
Metoclopramide versus other active agents | Cicek, 2004, Turkey, RCT113 | 45 min, (4 hr) | G1: MET, n=196 (Vascular headache); 140 (tension headache), IM placebo + MET 10 mg IV G2: MET+PET, n=49, MET 10 mg IV + PET 50 mg IM G3: PET, n=49, IV placebo + PET 50 mg IM P: Placebo, n=48, NR IV/IM | Total: 38.8 (11.1) vascular headache; 42.1 (13.8) for tension headache; mean age of all subjects 40.2 (12.4), 7.1 (female to male ratio for vascular headache), 2.5 (in tension headache group), | G1: NR, NR G2: NR, NR P: NR, NR | 1: pain intensity (VAS) 2: side effects
Metoclopramide versus other active agents | Friedman, BW, 2005, U.S., RCT82 | 120 min, (24 hr) | G1: MET, n=40, 20 mg IV G2: SUM, n=38, 6 mg SC | G1: 34, 35 (87.5), Latino: 25 (62.5); Black: 12 (30.0; White: 2 (5.0) G2: 34, 32 (84.2), Latino: 24 (63.2); Black: 10 (26.3); White: 2 (5.3) | G1: NR, 32 hr G2: NR, 29 hr | 1: change in NRS score 2: 24-hr pain score, pain-free headache response at 2 and 24 hr, need for rescue medication, adverse reactions
Metoclopramide versus other active agents | Friedman, BW, 2006, U.S., RCT79 | ED discharge, (24 hr) | G1: TMB and DPH, n=20, TMB 200 mg SC + DPH 25 mg SC G2: SUM, n=20, 6mg SC | G1: 34 (9.7); 17 (85.0); Latino: 11 (55.0), Black: 8 (40.0), White: 1 (5.0) G2: 32 (8.9); 20 (100.0); Latino: 14 (70.0), Black: 5 (25.0), White: 0 (0.0) | G1: NR, 37 hr (SD: 24) G2: NR, 32 hr (SD: 36) | 1: change in pain intensity between BL and 2 hr (11-point NRS for pain) 2: pain-free and headache response, pain intensity >24 hr, rescue therapy, nausea, limitation to usual daily activities

BL = baseline; CPZ = chlorpromazine; DEX = dexamethasone; DHE = dihydroergotamine; DPH = diphenhydramine; ED = emergency department; G1 = group 1; G2 = group 2; G3 = group 3; IM = intramuscular; IV = intravenous; MET = metoclopramide; MgSO_4_ = magnesium sulfate; NR = not reported; NRCT = non randomized controlled trial; NRS = Numerical Rating Scale for Pain; P = placebo; PET = pethidine; PCZ = prochlorperazine; pt = point; RCT = randomized controlled trial; SC = subcutaneous; SD = standard deviation; SUM = sumatriptan; TMB = trimethobenzamide; VAS = visual analogue scale

##### Metoclopramide Versus Placebo

###### Description of Included Studies

Six RCTs83,91,92,95,107,113 assessed the effectiveness of metoclopramide compared with placebo. One three-armed trial107 compared a combination of metoclopramide plus dihydroergotamine (DHE) with placebo and metoclopramide plus dexamethasone with placebo. The studies were all conducted in the ED. The mean ages of participant groups ranged from 32.1 to 40.0 years. Participants were predominantly female, and no study reported the race or ethnicity of study participants. All studies reported pain relief or severity as the primary outcome. Timepoints measured in the ED ranged from 30 to 60 minutes. Post-ED followup timepoints ranged from 4 to 48 hours. In all but one study,91 the secondary outcomes were adverse effects or ability to function.

Two studies had a low risk of bias;83,91 the remaining four 92,95,107,113 had an unclear risk of bias (Appendix D).

###### Effectiveness Results

The detailed analyses of results are provided below. Results are presented by outcome. Studies in which metoclopramide monotherapy was compared with placebo are presented first, followed by studies in which metoclopramide was administered in combination with another drug and compared with placebo.

##### Metoclopramide Monotherapy Versus Placebo

Five RCTs83,91,92,95,113 assessed metoclopramide monotherapy compared with placebo. In each study, participants were administered 10 mg of metoclopramide.

###### Change in Pain Intensity (VAS)

The change in pain intensity was measured by change in VAS (mm). The pooled results (Figure 4) showed that those who received metoclopramide experienced a statistically significant, homogeneous decrease in pain intensity compared with those who received placebo (MD = −21.88; 95% CI: −27.38, −16.38; I^2^ = 0%).

Figure 4 Change in pain intensity (VAS) in trials comparing metoclopramide and placebo

VAS = visual analogue scale

Figure 4 displays a forest plot of studies reporting change in pain intensity using the Visual Analogue Scale, metoclopramide vs. placebo. Five studies reported pain intensity. The pooled results showed a significant decrease in pain intensity in those receiving metoclopramide (MD = −21.88, 95% CI: −27.38, −16.38; I2 = 0%).

###### Headache Relief

One study95 measured relief of headache using a questionnaire given to patients 1 hour after treatment. The difference in headache relief between the two groups was statistically significant in favor of the metoclopramide group (RR = 3.47; 95% CI: 1.50, 8.01).

###### Relief of Nausea and Vomiting

One study assessed the relief of nausea and vomiting91 and reported that significantly more patients receiving metoclopramide experienced relief compared with those who received placebo (RR = 4.19; 95% CI: 1.35, 13.03).

###### Headache Recurrence

Patients in one study were contacted 24 hours after discharge from the ED to determine headache recurrence.83 A lower proportion of patients who received metoclopramide experienced recurrence of headache (16/37) compared with those who received placebo (21/40); however, the difference between groups was not statistically significant (RR = 0.82; 95% CI: 0.51, 1.32).

##### Metoclopramide in Combination Versus Placebo

###### Pain Improved by at Least One Unit

One study compared metoclopramide plus DHE and metoclopramide plus dexamethasone versus placebo.107 Participants were administered 5 to 10 mg of metoclopramide. Patients were asked to rate their headache on a scale from zero to three (three being the most severe headache). Comparisons of metoclopramide plus DHE versus placebo (RR = 3.89; 95% CI: 1.07, 14.10) and metoclopramide plus dexamethasone versus placebo (RR = 4.09; 95% CI: 1.15, 14.57) significantly favored the metoclopramide combination therapy (Figure 5).

Figure 5 Pain improved by at least one unit (four-point scale) in trials comparing metoclopramide in combination with other active agents and placebo

Figure 5 displays a forest plot of studies reporting pain improvement by at least one unit on a four point scale, metoclopramide plus DHE and metoclopramide plus dexamethasone vs. placebo. One study reported pain improvement. Comparisons of metoclopramide plus DHE versus placebo (RR = 3.89, 95% CI: 1.07, 14.10) and metoclopramide plus dexamethasone versus placebo (RR = 4.09; 95% CI: 1.15, 14.57) significantly favored the metoclopramide combination therapy.

###### Return to Normal Functioning

In one study107 patients were asked to rate their ability to function on a scale from zero (normal functioning) to three (requiring bed rest) 30 minutes after injection. More patients who were administered metoclopramide plus DHE improved their function compared with those who were given placebo (RR = 9.90; 95% CI: 0.61, 161.73). Similarly, more patients who were administered metoclopramide plus dexamethasone improved their ability to function compared with those who were administered placebo (RR = 10.08; 95% CI: 0.63, 162.06). The differences in both comparisons were not statistically significant.

##### Metoclopramide Versus Active Agents

###### Description of Included Studies

Eight RCTs and one NRCT22,65,79,82,83,91,92,105,113 assessed the effectiveness of metoclopramide versus other active agents. Of these, four22,65,91,92 specifically compared metoclopramide with neuroleptics. All interventions were delivered in the ED with timepoints measured between 30 and 120 minutes. Post-ED followup timepoints ranged from 4 to 48 hours. For all trials, the number of participants who were randomized ranged from 40 to 342 (median = 78; IQR = 70, 91). The mean ages of intervention groups ranged from 31.6 to 40.0 years. All studies had a pain related primary outcome (e.g., pain relief, change in pain intensity, pain free status). The secondary outcomes were varied and included adverse effects, time in ED, and use of rescue medication. See Table 6 for details on study and patient characteristics.

Four trials65,79,83,91 had a low risk of bias, while five22,82,92,105,113 had an unclear risk of bias (Appendix D).

###### Effectiveness Results

###### Metoclopramide Versus Neuroleptics

Three studies65,91,92 assessed metoclopramide monotherapy compared with neuroleptics (i.e., prochlorperazine and chlorpromazine). In one study, patients who received metoclopramide or prochlorperazine were also administered 25mg of IV diphenhydramine.22 Participants were administered 0.1 mg/kg,65 10 mg,91,92 and 20 mg22 of metoclopramide.

###### Change in Pain Intensity (VAS)

All four studies reported change in pain scores as measured on the VAS (mm) (Figure 6).22,65,91,92 Results were consistent across studies in favor of neuroleptic agents. Two studies compared metoclopramide monotherapy with prochlorperazine.65,92 While both studies favored the neuroleptic, only one study reported statistically significant results (MD = 34.0; 95% CI: 19.68, 48.32; I^2^= 90%).92 Statistically significant results favoring the neuroleptic were found in the one study comparing chlorpromazine with metoclopramide (MD = 25.0; 95% CI: 12.14, 37.86).91 In the study where the antihistamine diphenhydramine was administered to both the metoclopramide and prochlorperazine groups, the differences in pain scores were not statistically significant.22 The pooled results are statistically significant in favor of the neuroleptic agents (MD = 16.45; 95% CI: 2.08, 30.83; I^2^ = 81%).

Figure 6 Change in pain (VAS) in trials comparing metoclopramide and neuroleptics

VAS = visual analogue scale

Figure 6 displays a forest plot of studies reporting change in pain using the Visual Analogue Scale, metoclopramide vs. neuroleptics. Four studies reported change in pain. One study comparing prochlorperazine and metoclopramide showed significant difference in favor of prochlorperazine (MD = 34.0; 95% CI: 19.68, 48.32). Another study comparing metoclopramide and chlorpromazine showed significant difference in favor of chlorpromazine (MD = 25.0; 95% CI: 12.14, 37.86).

###### Severe Headache Recurrence

In one study,65 patients were contacted by a nurse by telephone 48 hours post discharge to evaluate recurrence of headache. Patients who received metoclopramide had less headache recurrence compared with patients who received prochlorperazine; however, the results were not statistically significant (RR = 0.41; 95% CI: 0.11, 1.51).

###### Relief of Nausea and Vomiting

One study91 assessed relief of nausea and vomiting post-treatment and found no statisically signicant difference between metoclopramide and prochlorperazine (RR = 0.71; 95% CI: 0.44, 1.16).

###### Additional Outcomes

One study compared prochlorperazine and diphenhydramine versus metoclopramide and diphenhydramine.22 The study assessed whether patients could sustain a pain free state (achieving a pain-free state within 2 hours of medication administration and maintaining it for 24 hours), sustained headache relief (for 24 hours), sustained normal functioning, 2 hour pain free, and 2 hour headache relief. For every outcome measurement, the results were not statistically significant.

###### Metoclopramide Versus Other Active Agents (Excluding Neuroleptics)

Four studies investigated the efficacy of metoclopramide compared with other active agents including: MgSO_4_,83 ondansetron plus paracetemol,105 pethidine,113 and sumatriptan.82 In one study the dose of metoclopramide was 20 mg;82 in the other four studies the dose was 10 mg. In one study, trimethobenzamide plus diphenhydramine was compared with sumatriptan.79

###### Change in Pain Intensity (VAS)

Five studies79,82,83,105,113 measured pain or change in pain intensity using the VAS (mm) (Figure 7). In the figure, a negative number is a ‘change from baseline’ while a positive is a final pain score. Results were inconsistent across studies. While three studies reported nonsignificant pain or change in pain intensity,79,83,105 one study reported a statistically significant difference favoring metoclopramide versus pethidine.113 The results of the study that compared trimethobenzamine and diphenhydramide with sumatriptan showed that sumatriptan was more effective but the difference was not statistically significant.79

Figure 7 Change in pain intensity (<2 hours) (VAS) in trials comparing metoclopramide and other active agents (excluding neuroleptics)

VAS = visual analogue scale

Figure 7 displays a forest plot of studies reporting change in pain intensity of less than 2 hours using the Visual Analogue Scale, metoclopramide vs. other active agents (excluding neuroleptics). Five studies reported pain intensity. One study had significant results when comparing metoclopramide to pethidine in favor of metoclopramide (−10.00; 95% CI: −19.21, −0.79). There were no differences found for any of the other comparisons.

###### Headache Recurrence

One study measured headache recurrence at 24 hours and found no statistically significant difference between metoclopramide and MgSO_4_83 (RR = 0.82; 95% CI: 0.51, 1.33)

###### Other Outcomes

One study assessed the administration of paracetemol with both metoclopramide and ondansetron.105 The study measured the use of additional analgesia, mean duration of ED stay (minutes), and change in pain intensity at 24 hours (measured using a numerical rating system). There were no statistically significant differences between groups for any of the outcomes.

There were no statistically significant differences in the single study of sumatriptan versus trimethobenzamine plus diphenhydramine in the measurement of pain free response at 1, 2, and 24 hours, or for headache response at 1 and 2 hours.79 The same study assessed headache response at 24 hours, limitation to activities, and whether patients wanted the same medication in the future. There were no statistically significant differences for any of the outcomes.

### Neuroleptic Agents

#### Key Points

- Patients who received neuroleptic agents had greater improvement in pain intensity as measured by VAS (mm) compared with those receiving placebo based on four RCTs (moderate strength of evidence).
- Patients who received neuroleptic agents had greater headache relief at 1 hour compared with those receiving placebo based on five RCTs (moderate strength of evidence).
- Fewer patients who received neuroleptic agents experienced headache recurrence compared with those receiving placebo based on two RCTs (low strength of evidence).
- More patients who received droperidol experienced headache relief compared with patients who received prochlorperazine based on two RCTs (moderate strength of evidence).
- For all other head to head comparisons, single trials compared a neuroleptic agent with another active agent for headache relief, pain free response, headache response, and headache recurrence at various timepoints (insufficient strength of evidence).

#### Results

The results from studies that compared neuroleptics with placebo or with other active agents are presented below. Note that the studies that specifically compared neuroleptics and metoclopramide were described previously in the metoclopramide section. Table 7 and Table 8 provide the strength of evidence grades for all key outcomes. See Table 9 for details on study and patient characteristics.

Table 7 Strength of evidence for neuroleptics versus placebo

Comparison | Outcome (N Studies; N Patients) | Strength of Evidence Domains | | | | Strength of Evidence
Comparison | Outcome (N Studies; N Patients) | ROB | Consistency | Direct | Precision | Strength of Evidence
Neuroleptics vs. placebo | Pain intensity–VAS (4; 273) | Moderate | Consistent | Direct | Precise | Moderate
Neuroleptics vs. placebo | Headache relief at 1 hr (5; 408) | Moderate | Consistent | Direct | Precise | Moderate
Neuroleptics vs. placebo | Pain free at 1 hr (4; 368) | Moderate | Consistent | Direct | Precise | Moderate
Neuroleptics vs. placebo | Headache recurrence (2; 250) | Moderate | Inconsistent | Direct | Imprecise | Low
Neuroleptics vs. placebo | Patient satisfaction (1; 36) | Moderate | Unknown | Direct | Precise | Insufficient

N = number; ROB = risk of bias; VAS = visual analogue scale

Table 8 Strength of evidence for neuroleptics versus active agents

Comparison | Outcome (N Studies; N Patients) | Strength of Evidence Domains | | | | Strength of Evidence
Comparison | Outcome (N Studies; N Patients) | ROB | Consistency | Direct | Precision | Strength of Evidence
Metoclopramide vs. neuroleptics | Change in pain–VAS (2; 271) | Moderate | Inconsistent | Direct | Precise | Low
Prochlorperazine vs. sodium valproate | Change in pain–VAS (1; 39) | Low | Unknown | Direct | Precise | Insufficient
Prochlorperazine vs. MgSO_4_ | Change in pain–VAS (1; 36) | Low | Unknown | Direct | Precise | Insufficient
Chlorpromazine vs. DHE | Change in pain–VAS (1; 50) | High | Unknown | Direct | Precise | Insufficient
Chlorpromazine vs. DHE | Headache relief (1; 50) | High | Unknown | Direct | Imprecise | Insufficient
Chlorpromazine vs. lidocaine | Change in pain–VAS (1; 50) | High | Unknown | Direct | Precise | Insufficient
Chlorpromazine vs. lidocaine | Headache relief (1; 50) | High | Unknown | Direct | Precise | Insufficient
Prochlorperazine vs. ketorolac | Change in pain–VAS (1; 64) | Moderate | Unknown | Direct | Precise | Insufficient
Chlorpromazine hydrochloride vs. ketorolac tropethamine | Change in pain–VAS (1; 30) | Low | Unknown | Direct | Imprecise | Insufficient
Droperidol vs. meperidine | Change in pain–VAS (1; 29) | Moderate | Unknown | Direct | Imprecise | Insufficient
Methotrimeprazine vs. meperidine + dimenhydrinate | Change in pain–VAS (1; 82) | Low | Unknown | Direct | Imprecise | Insufficient
Chlorpromazine vs. meperidine + dimenhydrinate | Change in pain–VAS (1; 46) | Moderate | Unknown | Direct | Precise | Insufficient
Prochlorperazine + DPH vs. sumatriptan | Change in pain–VAS (1; 66) | Low | Unknown | Direct | Precise | Insufficient
Prochlorperazine vs. promethazine | Change in pain–VAS (1; 70) | Moderate | Unknown | Direct | Imprecise | Insufficient
Prochlorperazine vs. promethazine | Headache recurrence (1; 70) | Moderate | Unknown | Direct | Imprecise | Insufficient
Prochlorperazine vs. droperidol | Change in pain–VAS (2; 263) | Moderate | Inconsistent | Direct | Imprecise | Insufficient
Prochlorperazine vs. droperidol | Headache relief (2; 263) | Moderate | Consistent | Direct | Precise | Moderate
Prochlorperazine vs. droperidol | Pain free at 30 mins (1; 95) | Moderate | Unknown | Direct | Imprecise | Insufficient
Prochlorerpazine vs. octreotide | Change in pain–VAS (1; 44) | Moderate | Unknown | Direct | Precise | Insufficient
Prochlorerpazine vs. octreotide | Headache relief (1; 43) | Moderate | Unknown | Direct | Precise | Insufficient
Olanzapine vs. droperidol | Change in pain–VAS (1; 87) | Moderate | Unknown | Direct | Imprecise | Insufficient
Haloperidol vs. dexamethasone | Pain free at 30 mins (1; 29) | Moderate | Unknown | Direct | Imprecise | Insufficient
Haloperidol vs. dexamethasone | Headache recurrence (1; 29) | Moderate | Unknown | Direct | Imprecise | Insufficient

DHE = dihydroergotamine; DPH = diphenhydramine; MgSO_4_ = magnesium sulfate; N = number; NRS = numerical rating scale; ROB = risk of bias; VAS = visual analogue scale

Table 9 Patient and study characteristics of trials comparing neuroleptics with placebo or other active agents

Comparison | Author, Year, Country, Study Design | Timepoint Measured in the ED (Post ED Followup) | Intervention, N Randomized, Dosage, Route of Administration | Mean Age (SD), Females (%), White (%) | Description of Migraine Severity: Mean (SD); Duration of Migraine Prior to Coming Into ED | Primary Outcomes; Secondary Outcomes
Neuroleptics versus placebo | Bigal, 2002, Brazil, RCT 43 | 60 min, (24 hr) | G1: CPZ, n=68, 0.1mg/kg IV P: Placebo, n=60, 10ml NR | G1: 34.7 (10.9), 50 (73.5), NR P: 27.7 (9.2), 41 (68.3), NR | G1: NR, NR P: NR, NR | 1: pain intensity (10-pt verbal analogical scale and traditional 4-pt scale) 2: pain free, therapeutic gain, recurrence of pain, use of rescue medication, assessment of aura, associated symptoms
Neuroleptics versus placebo | Coppola, 1992, U.S., RCT 92 | 30 min, (48hr) | G1: MET, n=24, 10mg IV G2: PCZ, n=22, 10mg IV P: Placebo, n=24, NR IV | G1: NR, NR, NR G2: NR, NR, NR P: NR, NR, NR | G1: nonhatched VAS: 8.1, NR G2: nonhatched VAS:8.7, NR P: nonhatched VAS: 7.6, NR | 1: median pain scores (nonhatched VAS) 2: median nausea scores, median sedation scores
Neuroleptics versus placebo | Drotts, 1999, U.S., NRCT 90 | 60 min, (48 hr) | G1: PCZ, n=100, 10 mg IV G2: Placebo or antibiotics, n=40, NR IV | G: 29.6 (10), 71 (71.0), NR G2: 31 (11), 16 (40.0), NR | G1: NR, NR G2: NR, NR | 1: incidence of akathisia (Akathisia scale)
Neuroleptics versus placebo | Honkaniemi, 2006, Finland, RCT 80 | 1–3 hr, (1 mo) | G1: Haloperidol, n=20, 5 mg IV P: Placebo, n=NA, 500 ml IV | Total: 36, 41 (87.2), NR | G1: VAS: 7.7, 75 hr (total) P: VAS: 7.2, NA | 1: pain (VAS) 2: relief from pain, side effects
Neuroleptics versus placebo | Jones, 1989, U.S., RCT 68 | 60 min, (48hr) | G1: PCZ, n=42, 10mg IV P: Placebo, n=40, 2 ml IV | G1: 31.7(1.2), 28 (66.7), NR P: 32.4(0.9), 27 (67.5), NR | G1: NR, 9.7 (1.9)hr P: NR, 8.3 (2.1)hr | 1: pain relief at 60 min (subjects asked to rate whether drug gave complete, partial, or no relief) 2: tx failures
Neuroleptics versus placebo | Jones, 1996, U.S., RCT 91 | 60 min, (48 hr) | G1: PCZ, n=28, 10 mg IM G2: MET, n=29, 10 mg IM P: Placebo, n=29, 2 ml IM | Total: 32.1 (2.1), 63 (73.3), NR | G1: VAS: 8.1 (range 6–10), NR G2: VAS: 8.5 (range 7–10), NR P: VAS: 8.0 (range 6–10), NR | 1: median pain score (VAS) 2: nausea and vomiting
Neuroleptics versus placebo | McEwen, 1987, Canada, RCT97 | 60min, (24hr) | G1: CPZ, n=19, 50mg IM P: Placebo, n=17, 2 ml IM | G1: 30, 18 (94.7), NR P: 36, 15 (88.2), NR | G1: NR, 27hr P: NR, 49hr | 1: response to tx 2: successful tx response, measures of dissatisfaction
Neuroleptics versus placebo | Silberstein, 2003, U.S., RCT63 | 240min, (7d) | G1: DRO, n=61, 8.25mg IM P: Placebo, n=61, NR IM | G1: 42(10), 47(77.0), NR P: 44(9.7), 52(85.2), NR | G1: Moderate (64%), severe (36%); NR P: Moderate (56%), severe (44%), NR | 1: 2 hr headache response and tolerability 2: headache assessment (other timepoints), pain-free response rates, recurrence, resolution of nonheadache symptoms, use of rescue medications
Neuroleptics versus active agents | Bell, 1990, Canada, RCT 96 | 60 min (24hr) | G1: CPZ, n=24, 12.5mg IV G2: DHE, n=26, 1mg IV G3: LID, n=26, 50mg IV | Total: NR, 60 (79), NR | G1: Median intensity score (10-pt scale): 8.5; NR G2: Median intensity score (10-pt scale): 7.5; NR G3: Median intensity score (10-pt scale): 8.0; NR | 1: headache response (10-pt scale, with 10 denoting the worst headache)
Neuroleptics versus active agents | Blanda, 2001, U.S., RCT 88 | 30 min, (NR) | G1: PCZ + LID, n=27, 10 mg PCZ + 2 ml of 4% LID IV and Intranasal G2: PCZ + Placebo, n=22, 10 mg PCZ + 2 ml saline IV and intranasal | G1: NR, 19 (86.4), NR G2: NR, 23 (85.2), NR | G1: VAS: 8.4, <4 hr: 5(18.5%); 4 to <12 hr: 8 (29.6%); 12 to 23 hr: 9 (33%) G2: VAS: 8.6, <4 hr: 2(9%); 4 to <12 hr: 10 (45.4%); 12 to 23 hr: 4 (18.1%) | 1: pain reduction (VAS) 2: rescue medication, adverse reactions, dystonia, willingness to use IV delivery at home, return visits
Neuroleptics versus active agents | Callan, 2007, U.S., RCT 75 | 60 min, (NA) | G1: PMZ, n=35, 25 mg IV G2: PCZ, n=35, 10 mg IV | G1: 29.5, 30 (85.7), 15 (42.9) G2: 28.3, 27 (77.1), 19 (54.3) | G1: VAS: 70.7 mm, NR G2: VAS: 75.2 mm, NR | 1: pain reduction (VAS) 2: headache w/i 5 d, akathisia, rescue medication, patient satisfaction, drowsiness, agitation, nausea
Neuroleptics versus active agents | Ginder, 2000, U.S., RCT 89 | 30 min, (NA) | G1: MgSO_4_, n=16, 2g IV G2: PCZ, n=20, 10 mg IV | G1: NR, 9 (56.3), NR G2: NR, 16 (80.0), NR | G1: VAS: 8.11 (1.98), NR G2: VAS: 8.25 (1.08), NR | 1: Mean pain reduction (VAS)
Neuroleptics versus active agents | Hill, 2008, U.S., RCT 74 | 60 min, (NA) | G1: Olanzapine, n=50, 10 mg IM G2: DRO, n=50, 5 mg IM | G1: 32.5 (10.8), 35 (77.8), NR G2: 34.6 (9.3), 31 (73.8), NR | G1: VAS: 84.2 mm, 3 d (IQR: 1–4) G2: VAS: 83.9 mm, 3 d (IQR: 1–5) | 1: pain (VAS) 2: nausea; median AMS score; median BAS awareness, distress
Neuroleptics versus active agents | Kostic, 2010, U.S., RCT 64 | 80 min (51 patients), (NA) | G1: PCZ with DPH, n=32, 10 mg PCZ, 12.5 mg DPH IV G2: SUM, n=34, 6 mg SC | G1: 31 (10), 19 (61.3), NR G2: 28 (6), 23 (65.7), NR | G1: VAS: 76 mm (10), 2.7 (3.3) d G2: VAS: 71 mm (22), 1.7 (2.2) d | 1: mean change in pain intensity for 80 min after tx (VAS) 2: mean degree of nausea and sedation
Neuroleptics versus active agents | Lane, 1989, Canada, RCT 67 | 105min, (60 min) | G1: CPZ, n=24, 0.04ml (0.1 mg/kg)/kg IV G2: MEP + DMH, n=22, 0.1mg 0.4 mg/kg + 25mg IV | G1: 31.0 (range: 21–47), 21 (87.5), NR G2: 31.1 (range: 19–48), 18 (81.8), NR | G1: NR, 54.6 hr (range: 2–336) G2: NR, 41.8 hr (range: 2–216) | 1: pain severity (VAS) 2: adverse side effects
Neuroleptics versus active agents | Miller, 2009, U.S., RCT 73 | 60 min (48 hr) | G1: Octreotide, n=24, 100 μg IV G2: PCZ, n=20, 10 mg IV | GI: 31.1 (11.1), 19 (79.2), NR G2: 27.5 (5.8), 14 (70.0), NR | GI: VAS: 75.4 (17.7), NR G2: VAS: 71.6 (15.3), NR | 1: pain (VAS) 2: change in pain, nausea, sedation, occurrence of side effects (i.e., restlessness or akathisia)
Neuroleptics versus active agents | Miner, 2001, U.S., RCT 87 | 60 min, (24 hr) | G1: IV (33/82), IM (49/82); DRO, n=82, 5 mg (IM) or 2.5 mg (IV) G2: IV (29/86), IM (57/86 ); PCZ, n=86, 10 mg (IM) or 10 mg (IV) | G1: 31.7 (8.23), 42 (51.2), NR G2: 33.9 (12.1), 45 (52.3), NR | G1: VAS: 79.8 mm (95% CI: 75.7, 83.9), NR G2: VAS: 74.3 mm (95% CI: 69.6, 78.9), NR | 1: pain (VAS) 2: side effects, rebound headaches, side effects beginning after discharge from the ED, seeking care elsewhere
Neuroleptics versus active agents | Monzillo, 2004, Brazil, RCT 114 (Portugese) | 120 min, (120 min) | G1: Haloperidol, n=14. 5 mg IV G2: DEX, n=15, 4 mg IV | Total: 31.5 (NR), 25 (86.2), NR | G1: NR, NR G2: NR, NR | 1: pain intensity 2: pain recurrence, adverse effects
Neuroleptics versus active agents | Richman, 2002, U.S., RCT 85 | 30 min, (NA) | G1: DRO, n=15, 2.5 mg IM G2: MEP, n=14, 1.5 mg/kg IM | G1: 30.7 (8.9), 11 (73.3), NR G2: 32.7 (9.9), 10 (71.4), NR | G1: VAS: 88 mm, 24.7 hr (28.3) G2: VAS: 76 mm, 18.3 hr (25.8) | 1: pain (VAS) 2: drug preference (Likert scale)
Neuroleptics versus active agents | Seim, 1998, U.S., RCT 71 | 60 min (NA) | G1: PCZ, n=29, 10 mg IV G2: KET, n=35, 30 mg IV | G1: 34 (15), 27 (93.1), NR G2: 31 (9), 32 (91.4), NR | G1: VAS: 8.3 cm (2.1), NR G2: VAS: 8.4 cm (1.7), NR | 1: pain score (VAS)
Neuroleptics versus active agents | Shrestha, 1996, U.S., RCT 54 | 120 min, (48 hr) | G1: KET, n=15, 60 mg IM G2: CPZ, n=15, 25 mg IV | G1: 30.8 (1.9), 11 (73.3), NR G2: 30.5 (1.45), 13 (86.7), NR | G1: Moderate to severe: 15 (100%), 4–72 hr duration: 15 (100%) G2: Moderate to severe: 15 (100%), 4–72 hr duration: 15 (100%) | 1: mean pain scores (Wong-Baker Faces Rating Scale)
Neuroleptics versus active agents | Stiell, 1991, Canada, RCT 66 | 60 min (48hr) | G1: MTM, n=41, 37.5mg (25mg/ml) IM G2:MEP + DMH, n=41, 75mg + 50mg IM | G1: ), 30.9 (7.3), 25 (67.6), NR G2: 32.5 (8.9), 31 (83.8), NR | G1: VAS: 7.97 (1.57), 23.9 (27.9) G2: VAS: 7.92 (13.50), 27.2 (32.6) | 1: change in pain intensity (VAS) 2: % patients with relief of ≥7.0 cm on VAS, residual nausea or vomiting
Neuroleptics versus active agents | Tanen, 2003, U.S., RCT 69 | 60 min, (NA) | G1: VAL, n=20, 500 mg IV G2: PCZ, n=20, 10 mg IV | G1: 31.0 (9.3), 11 (78.6), NR G2: 31.0 (10.0), 14 (70.0), NR | G1: VAS: 69.8 mm (18.3), NR G2: VAS: 76.1 mm (19.0), NR | 1: pain (VAS)
Neuroleptics versus active agents | Vinson, 2001, U.S., RCT 29 | 60 min (NR) | G1: PCZ+ DMH, n=50, 10 mg + 50 mg IV G2: PCZ + Placebo, n=50, 10 mg IV | G1:31 (12.0), 32 (64.0) NR G2: 27 (9.3), 35 (70.0) NR | G1: NR, NR G2: NR, NR | 1: akathisia 2: median sedation scores (VAS)
Neuroleptics versus active agents | Weaver, 2003, U.S., RCT 70 | 60 min, (24 hr) | G1: DRO, n=48, 2.5 mg IV G2: PCZ, n=48, 10 mg IV | G1: 30 (range: 18–68), 44 (91.7), White: 22 (45.8); Black: 26 (54.2); Other: 0 (0.0) G2: 34 (range: 19–64), 39 (81.3), White: 23 (47.9); Black: 23 (47.9: 2 (4.2) ); Other | G1: VAS median: 68 mm (range: 18–100), NR G2: VAS median: 79 mm (range: 21–100), NR | 1: pain reduction at 30 min (VAS) 2: akathisia

AMS = Altered Mental Status; BAS = Barnes Akathisia Scale; CPZ = chlorpromazine; DEX = dexamethasone; DHE = dihydroergotamine; DMH = dimenhydrinate; DPH = diphenhydramine; DRO = droperidol; ED = emergency department; G1 = group 1; G2 = group 2; G3 = group 3; IM = intramuscular; IV = intravenous; LID = lidocaine; MEP = meperidine; MET = metoclopramide; mg = milligram(s); MgSO_4_ = magnesium sulfate; MTM = methotrimeprazine; N = number; NA = not applicable; NR = not reported; NRCT = non randomized controlled trial; P = placebo; PCZ = prochlorperazine; PMZ = promethazine; pt = point; RCT = randomized controlled trial; SC = subcutaneous; SD = standard deviation; SUM = sumatriptan; tx = treatment; VAL = valproate; VAS = visual analogue scale

##### Neuroleptic Agents Versus Placebo

###### Description of Included Studies

Seven RCTs43,63,68,80,91,92,97 and one NRCT90 evaluated the effectiveness of neuroleptics versus placebo. The neuroleptics included prochlorperazine,68,90–92 chlorpromazine,43,97 haloperidol,80 and droperidol.63 Most trials took place in the ED; one took place in a headache clinic.63 The mean ages of the participant groups ranged from 29.6 and 41.0 years; age was not reported in one study.92 In seven studies, the majority of patients were female; in one study, 40 percent of the placebo group was female.90 Race or ethnicity was not reported in any of the studies. The primary outcomes were pain related,43,63,68,80,91,92 incidence of akathisia,90 and response to treatment.97 Secondary outcomes included therapeutic gain, nausea, vomiting, sedation, treatment failures, and successful treatment response or therapeutic gain. The timepoints measured in the ED ranged from 30 minutes to 4 hours. The followup timepoints after discharge ranged from 24 hours to 1 month.

Two studies had a low risk of bias,68,91 five43,63,80,92,97 had an unclear risk of bias, and one90 had a high risk of bias (Appendix D).

###### Effectiveness Results

###### Change in Pain Intensity (VAS)

The change in pain intensity was reported by change in VAS (Figure 8). The pooled result was statistically significant in favor of neuroleptics (MD = −46.59; 95% CI: −54.87, −38.32; I^2^ = 46%).43,80,91,92 In all but one study43 authors reported pain as change from baseline (negative numbers); when these data were not reported, end of study data were presented (positive numbers).

Figure 8 Change in pain intensity (VAS) in trials comparing neuroleptics and placebo

VAS = visual analogue scale

Figure 8 displays a forest plot of studies reporting change in pain intensity using the Visual Analogue Scale, neuroleptics vs. placebo. Four studies reported change in pain intensity. Two studies compared prochlorperazine to placebo and both significantly favored prochlorperazine (MD = −50.80; 95% CI: −70.39, −31.20; I2 = 76%). One study compared haloperidol to placebo and results favored haloperidol (MD = −45.00; 95% CI: −58.98, −31.02). One study compared chlorpromazine to placebo and there was a significant difference in favor of chlorpromazine (MD = −42.50; 95% CI: −51.14, −33.86). The pooled result of all of these studies was MD = −46.59; 95%CI: −54.87, −38.32.

###### Headache Relief (1–2 hours)

Five studies evaluated relief of headache at 1 hour (Figure 9).43,63,68,80,97 All studies reported a statistically significant result in favor of the neuroleptics; the pooled result was RR = 2.69 (95% CI: 1.66, 4.34; I^2^ = 76%). In two studies, the neuroleptic used was chlorpromazine.43,97 In one study43 patients were given an IV injection of 5.0 ml/kg 0.9 percent normal saline solution followed by IV chlorpromazine, 0.1 mg/kg diluted to 10 ml of 0.9 percent normal saline. In the remaining studies, patients were administered 50 mg/2ml of chlorpromazine97 or 2.75 mg droperidol.63

Figure 9 Headache relief (1 hour) in trials comparing neuroleptics and placebo

Figure 9 displays a forest plot of studies reporting relief of pain at one hour, neuroleptics vs. placebo. Four studies reported relief of pain at one hour. All studies showed a significant difference in favor of the neuroleptic drugs. One study compared haloperidol vs. placebo (RR = 5.33; 95% CI: 1.84, 15.49). Two studies reported chlorpromazine vs. placebo (RR = 3.66; 95% CI: 1.56, 8.57). One study reported prochlorperazine vs. placebo (RR = 1.96; 95% CI: 1.37, 2.81). One study reported droperidol vs. placebo (RR = 1.67; 95% CI: 1.21, 2.29). The pooled result of all these studies was RR = 2.69; 95%CI: 1.66, 4.34 which showed a significant difference in favor of neuroleptics.

One study assessed headache response at 2 hours.63 Significantly more participants who received droperidol experienced relief of pain at 2 hours (RR = 1.51; 95% CI: 1.19, 1.92).

###### Pain Free (1 hour)

Four studies reported on pain free status of participants at 1 hour (Figure 10).43,63,68,97 The pooled results of two studies43,97 comparing chlorpromazine and placebo had statistically significant results favoring the neuroleptic (RR = 4.03; 95% CI: 1.02, 15.93; I^2^ = 78%). The different concentrations of chlorpromazine may explain some of the heterogeneity. The pooled result was statistically significant in favor of the neuroleptics (RR = 3.38; 95% CI: 1.16, 9.83; I^2^ = 90%).

Figure 10 Pain free (1 hour) in trials comparing neuroleptics and placebo

Figure 10 displays a forest plot of studies reporting being pain free at one hour, neuroleptics vs. placebo. Four studies reported being pain free at one hour. Two studies compared chlorpromazine vs. placebo; one study was significantly in favor of chlorpromazine (RR = 7.76; 95% CI: 3.29, 18.30),. There was no difference in the other study. One study reported prochlorperazine vs. placebo and found a difference in favor of prochlorperazine (RR = 5.90; 95% CI: 2.55, 13.67). One study found significant difference in favor of droperidol over placebo (RR = 3.38; 9% CI: 1.16, 9.83).

Pain free status was also measured at 2 hours in one study.63 The results were statistically significant in favor of droperidol versus placebo (RR = 2.11; 95% CI: 1.37, 3.26).

###### Headache Recurrence (24 hours)

One study considered recurrence of pain to occur when patients stated that they were pain free any time after administration of the intervention, only to have the headache return within 24 hours.43 In this study, patients who received chlorpromazine had significantly lower rates of headache recurrence than those who were given placebo (RR = 0.28; 95% CI: 0.15, 0.55).43 Another study63 recorded the number of patients whose headache improved at 2 hours but recurred within 24 hours. There was no significant difference in the rates of headache recurrence for those who received droperidol and those who received placebo (RR = 0.69; 95% CI: 0.43, 1.12). The pooled results favor neuroleptics, however, the difference was not statistically significant (RR = 0.46; 95% CI; 0.19, 1.10; I^2^ = 78%).

###### Nausea and Vomiting

One study assessed relief of nausea and vomiting 60 minutes after the administration of prochlorperazine or placebo.91 Participants who received prochlorperazine experienced significantly greater relief than those who received placebo (RR = 5.89; 95% CI: 1.98, 17.57). One study reported the percentage of patients who experienced nausea and vomiting 2 hours post-treatment.63 The difference between the droperidol and placebo groups was not statistically significant for either nausea or vomiting (RR = 0.36; 95% CI: 0.12, 1.08 and RR = 0.33; 95% CI: 0.01, 8.03, respectively).

###### Patient Satisfaction

One study reported patient dis-satisfaction as the number of patients who asked for a second drug at the end of 1 hour.97 We used the inverse of this number to determine patient satisfaction. Significantly more patients who received placebo asked for more medication compared with those who received chlorpromazine (RR= 3.28; 95% CI: 1.10, 9.82).

##### Neuroleptic Agents Versus Active Agents

###### Description of Included Studies

There were 17 RCTs29,54,64,66,67,69–71,73–75,85,87–89,96,114 that assessed the effectiveness of neuroleptics versus other active agents. The neuroleptics included prochlorperazine,29,64,69–71,73,75,87–89 chlorpromazine,54,67,96 haloperidol,114 droperidol,85 methotrimeptrazine,66 and olanzapine.74 One study was a three-arm trial that compared chlorpromazine, DHE, and lidocaine.96 The active comparators included anticonvulsants (sodium valproate and MgSO_4_),69,89 dexamethasone,114 DHE,96 neuroleptics (droperidol and prochlorperazine),29,70,74,87,88,96 NSAIDs (ketorolac and ketorolac tropethamine),54,71 opioids (meperidine),66,67,85 somatostatin analog,73 sumatriptan,64 and lidocaine.88

All studies took place in the ED with timepoints that ranged between 30 and 120 minutes. Post-ED followup ranged from 2 to 45 hours. Eight studies did not report any followup data after discharge from the ED.64,69,71,74,75,85,88,89 The number of participants who were randomized ranged from 29 to 168 (median = 64; IQR: 40, 82). The mean age of patients ranged from 27 to 35 years.

Every study but one had a pain related primary outcome. The one study measured akathisia as its primary outcome.29 While the VAS was the primary means to measure pain, one study used the Wong-Baker Faces Rating Scale to assess pain scores.54 Secondary outcomes varied across studies and included headache recurrence, patient satisfaction, nausea, and sedation.

Seven studies had low risk of bias,29,54,64,66,69,88,89 nine had an unclear risk of bias,67,70,71,73–75,85,87,114 and one had a high risk of bias96 (Appendix D).

###### Effectiveness Results

###### Change in Pain Intensity (VAS)

Fourteen studies reported change in pain scores. Twelve studies specifically stated that pain was measured using the VAS (mm).54,66,67,69,71,85,89,64,73–75,87 One reported using a headache scale ranging from 1 to 10,^96^ while another used the Wong-Baker Faces Rating Scale.54

Eight studies64,67,69,71,73,87,89,96 reported statistically significant results in favor of the neuroleptic agents (Figure 11). In four studies the neuroleptic was favored over the other active agent, although the differences were not statistically significant.54,74,75,85 In one study, the participants who received meperidine plus dimenhydrinate experienced more improvement in pain scores compared with those who received methotrimeptrazine; however, the difference was not statistically significant.66 We did not pool the results due to statistical and clinical heterogeneity.

Figure 11 Change in pain (VAS) in trials comparing neuroleptics and active agents

VAS = visual analogue scale

Figure 11 displays a forest plot of studies reporting change in pain intensity using the Visual Analogue Scale, neuroleptics vs. other active agents. Fourteen studies reported pain intensity using this scale. There were four studies in which the neuroleptic was favored over the other active agent, though the differences were not statistically significant. In one study, the participants who received meperidine plus dimenhydrinate experienced more improvement in pain scores than those who received methotrimeprazine; however, the difference was not statistically significant. In one of the two studies comparing prochlorperazine with droperidol, the interventions were considered to be equally effective (MD = 0.00, 95% CI: −8.53, 8.53, I2 = 75%). However, in the other study, those administered prochlorperazine experienced significantly greater change in pain scores than those administered droperidol (MD = 18.10, 95% CI: 10.17, 26.03, I2 = 75%).

###### Headache Relief

Headache relief was evaluated in four studies (Figure 12).70,73,87,96 One of the trials had three study arms in which chlorpromazine, DHE, and lidocaine were compared.96 In one study, significantly more participants in the prochlorperazine group experienced headache relief compared with those in the octerotide group (RR = 1.59; 95% CI: 1.08, 2.34).73 In the two studies comparing prochlorperazine with droperidol, one study did not report a significant difference between groups,70 while the other study showed a statistically significant difference favoring droperidol.87

Figure 12 Headache relief in trials comparing neuroleptics and active agents

Figure 12 displays a forest plot of studies reporting headache relief, neuroleptics vs. other active agents. Four studies reported headache relief. Significantly more participants in the octerotide group experienced headache relief than those in the prochlorperazine group (RR = 1.59, 95% CI: 1.08, 2.34). In the two studies comparing prochlorperazine with droperidol, one study did not report a significant difference between groups, while the other study showed a statistically significant difference favoring droperidol (RR = 0.81, 95% CI: 0.68, 0.98; I2 = 8%).

###### Pain Free at 30 Minutes

Two studies reported the number of patients who were pain free 30 minutes after administration of the interventions (Figure 13).70,114 In one study, haloperidol was found to be more effective than dexamethasone,114 while in the other study more people in the droperidol group were free from pain at 30 minutes compared with those in the prochlorperazine group.70 Neither of these differences were statistically significant. At 120 minutes, haloperidol was signifantly more effective than dexamethasone (RR = 2.06; 95% CI: 1.21, 3.50) (metagraph not shown).114

Figure 13 Pain free at 30 minutes in trials comparing neuroleptics and active agents

Figure 13 displays a forest plot of studies reporting being pain free at 30 minutes, neuroleptics vs. other active agents. Two studies reported pain free status at 30 minutes. There was no difference at this timepoint.

###### Headache Recurrence

Three studies assessed headache recurrence 24 hours after discharge (Figure 14).75,87,114 In the study comparing haloperidol with dexamethasone, no patients in either group reported a recurrent headache.114 There were no statistically significant differences between groups for proclorperazine versus promethazine,75 or prochlorperazine versus droperidol.87

Figure 14 Headache recurrence in trials comparing neuroleptics and active agents

Figure 14 displays a forest plot of studies reporting headache recurrence 24 hours after discharge, neuroleptics vs. other active agents. Three studies reported headache recurrence. There was no difference reported in any of the comparisons.

###### Patient Satisfaction

One study measured patient satisfaction and found no difference between those who were administered prochlorperazine and those administered promethazine (RR = 1.00; 95% CI: 0.65, 1.54).75

###### Nausea

Three studies assessed the effect of a neuroleptic versus another active agent on nausea as a symptom of migraine (Figure 15).69,73,74 One study reported a statistically significant result in which the prochlorperazine group experienced a greater reduction in nausea than the sodium valproate group (MD = −33.5; 95% CI: −51.55, −15.45).69

Figure 15 Nausea in trials comparing neuroleptics and active agents

Figure 15 displays a forest plot of studies reporting nausea, neuroleptics vs. other active agents. Three studies reported nausea. Only one study reported statistically significant results in which the prochlorperazine group experienced a greater reduction in nausea than the sodium valproate group (MD = −33.5, 95% CI: −51.55, −15.45).

One study reported no statistically significant difference between methotrimetprazine and meperidine plus dimenhydrinate for residual nausea and vomiting (RR = 0.80; 95% CI: 0.36, 1.80).66 In another study, resolution of nausea while in the ED was measured.75 More patients who received prochlorperazine experienced nausea resolution compared with those receiving promethazine; the results were not statistically significant (RR = 1.34; 95% CI: 0.99, 1.83).

###### Sedation

Three studies assessed the reduction of migraine-related sedation (Figure 16).29,69,73 One study favored octerotide over prochlorperazine (MD = 22.4; 95% CI: 3.23, 41.57).73 In another study,29 patients who received prochlorperazine experienced a significant reduction in sedation compared with those who received prochlorperazine plus diphenhydramine (MD = −21.0; 95% CI: −30.85, −11.15).

Figure 16 Sedation in trials comparing neuroleptics and active agents

Figure 16 displays a forest plot of studies reporting sedation, neuroleptics vs. other active agents. Three studies reported sedation. One study significantly favored octreotide over prochlorperazine (MD = 22.4, 95% CI: 3.23, 41.57). In another study, those who received prochlorperazine experienced a significant reduction in sedation compared to those who received prochlorperazine plus diphenhydramine (MD = −21.0, 95% CI: −30.85, −11.15).

###### More Than One Dose Required

One study reported no significant difference between those receiving chlorpromazine or meperidine and dimenhydrinate when comparing the need for another dose of medication (RR = 1.18; 95% CI: 0.80, 1.74).67

###### Other Outcomes

In one study, patients were contacted at home 1 day after discharge to determine rates of home drowsiness and agitation.75 There was no significant difference in agitation between those who received prochlorperazine and those who received promethazine. When home drowsiness was reported, those in the prochlorperazine group experienced significantly less drowsiness.

### Nonsteroidal Anti-Inflammatory Drugs

#### Key Points

- More patients who received nonsteroidal anti-inflammatory drugs (NSAIDs) were pain free at 1–2 hours compared with those on placebo based on two RCTs (moderate strength of evidence).
- There was insufficient strength of evidence for headache recurrence for patients receiving NSAIDs versus placebo based on one RCT.
- For all head to head comparisons single trials compared NSAIDs with another active agent for change in pain (VAS), pain response, pain free at 1–2 hours, need for additional analgesia, and headache recurrence at various timepoints (insufficient strength of evidence).

#### Results

The results for studies that assessed nonsteroidal anti-inflammatory drugs (NSAIDs) are summarized below. Table 10, Table 11, and Table 12 present results or the strength of evidence grades for all key outcomes. See Table 13 for study and patient characteristics.

Table 10 Strength of evidence for NSAIDs versus placebo

Comparison | Outcome (N Studies; N Patients) | Strength of Evidence Domains | | | | Strength of Evidence
Comparison | Outcome (N Studies; N Patients) | ROB | Consistency | Direct | Precision | Strength of Evidence
NSAIDs vs. placebo | Pain free 1–2 hr (2; 149) | Moderate | Consistent | Direct | Precise | Moderate
NSAIDs vs. placebo | Headache recurrence (1; 120) | Moderate | Unknown | Direct | Precise | Insufficient

N = number; NSAID = nonsteroidal anti-inflammatory drug; ROB = risk of bias; VAS = visual analogue scale

Table 11 Pain response after treatment in trials comparing NSAIDs and other active agents

Comparison | Study, Year Study Design (# Patients) | Interventions | Risk of Bias | Outcomes | Data Source
NSAIDs vs. neuroleptics | Seim, 1998 RCT (n = 64) | Prochlorperazine vs. ketorolac | Unclear | Pain intensity–VAS: (MD = −19.00 (95% CI: −34.97, −3.03); favors prochlorperazine | Figure 11
NSAIDs vs. neuroleptics | Shrestha, 1996 RCT (n = 30) | Chlorpromazine hydrochloride vs. ketorolac tropethamine | Low | Pain intensity–VAS: (MD = −5.30 (95% CI: −24.89, 14.29); no significant difference between groups | Figure 11

CI = confidence interval; MD = mean difference; N = number; NSAID = nonsteroidal anti-inflammatory drug; VAS = visual analogue scale

Table 12 Strength of evidence for NSAIDs versus active agents

Comparison | Outcome (N Studies; N Patients) | Strength of Evidence Domains | | | | Strength of Evidence
Comparison | Outcome (N Studies; N Patients) | ROB | Consistency | Direct | Precision | Strength of Evidence
Ketorolac vs. meperidine + promethazine | Change in pain–VAS (1; 42) | Moderate | Unknown | Direct | Imprecise | Insufficient
Ketorolac vs. meperidine + promethazine | Pain response (1; 42) | Moderate | Unknown | Direct | Imprecise | Insufficient
Ketorolac vs. meperidine + hydroxyzine | Change in pain–VAS (1; 50) | Moderate | Unknown | Direct | Imprecise | Insufficient
Ketorolac vs. meperidine + hydroxyzine | Required additional analgesia (1; 50) | Moderate | Unknown | Direct | Imprecise | Insufficient
Ketorolac vs. meperidine | Pain response (1; 31) | Moderate | Unknown | Direct | Imprecise | Insufficient
Ketorolac vs. meperidine | Pain free (1–2 hrs) (1; 31) | Moderate | Unknown | Direct | Imprecise | Insufficient
Ketorolac vs. sumatriptan | Change in pain–VAS (1; 29) | Moderate | Unknown | Direct | Precise | Insufficient
Prochlorperazine vs. ketorolac | Change in pain–VAS (1; 64) | Moderate | Unknown | Direct | Precise | Insufficient
Chlorpromazine hydrochloride vs. ketorolac tropethamine | Change in pain–VAS (1; 30) | Low | Unknown | Direct | Imprecise | Insufficient
Lysine acetylsalicylic acid vs. ergotamine | Pain response (1; 112) | Moderate | Unknown | Direct | Precise | Insufficient
Diclofenac vs. tramadol | Pain response (1; 40) | Low | Unknown | Direct | Imprecise | Insufficient
Diclofenac vs. tramadol | Pain free (1–2 hrs) (1; 40) | Low | Unknown | Direct | Imprecise | Insufficient
Diclofenac vs. tramadol | Headache recurrence (48 hrs) (1; 40) | Low | Unknown | Direct | Imprecise | Insufficient
Diclofenac sodium vs. paracetemol | Pain free (1–2 hrs) (1; 85) | Moderate | Unknown | Direct | Precise | Insufficient

N = number; NRS = numerical rating scale; ROB = risk of bias; VAS = visual analogue scale

Table 13 Patient and study characteristics of trials comparing NSAIDs with placebo or active agents

Comparison | Author, Year, Country, Study Design | Timepoint Measured in the ED (Post ED Followup) | Intervention, N Randomized, Dosage, Route of Administration | Mean Age (SD), Females (%), White (%) | Description of Migraine Severity: Mean (SD); Duration of Migraine Prior to Coming Into ED | Primary Outcomes; Secondary Outcomes
NSAIDs versus placebo | Bigal, 2002, Brazil, RCT42 | 60 min, (24 hr) | G1: Diclofenac, n=60, 75mg +10ml IM P: Placebo, n=60, 10ml IV | G1: NR, NR, NR P: NR, NR, NR | G1: NR, NR P: NR, NR | 1: pain intensity (VAS) 2: analgesic efficacy, recurrence, rescue medication
NSAIDs versus placebo | Krymchantowski, 2003, Brazil, RCT100 | 120 min, (2 hr) | G1: Lysine clonixinate, n=17, 200mg IV P: Placebo, n=15, 25ml IV | Total: 32(2), 21 (72.4), NR | G1: NR, NR P: NR, NR | 1: pain free (VAS) 2: rescue medication
NSAIDs versus active agents | Davis, 1995, U.S., RCT55 | 60 min (NA) | G1: KET, n=20, 60mg IM G2: MEP + PMZ, n=22, 75mg MEP + 25mg PMZ IM | G1: 37.6, 17 (85.0), G2: 38.2, 17 (77.3), | G1: NR, NR G2: NR, NR | 1: change in perceived headache pain (borg scale: patient subjective measurements)
NSAIDs versus active agents | Duarte, 1992, Canada, RCT94 | 60 min (NA) | G1: KET, n=25, 60mg IM G2: MEP + HDZ, n=25, 100mg + 50mg IM | G1: 34.9 (10.1), 20 (80.0), NR G2: 34.4 (12.3), 20 (80.0), NR | G1: VAS: 7.74 cm (1.84), 41.4 (38.1) G2: VAS: 8.28 cm (1.65), 16.5 (20.5) | 1: pain-intensity scores (VAS) 2: required additional anesthesia at 30 and 60 min
NSAIDs versus active agents | Engindeniz, 2005, Turkey, RCT81 | 120 min, (48 hr) | G1: Diclofenac, n=24, 75 mg IM G2: Tramadol, n=23, 100 mg IM | G1: 37.9 (13.3), 14 (70.0), NR G2: 37.0 (11.06), 17 (85.0), NR | G1: NR, NR G2: NR, NR | 1: pain response 2: 2-hr pain free, 48-hr pain and pain-free, associated symptoms, rescue treatment, recurrence, adverse events
NSAIDs versus active agents | Karachalios, 1992, Greece, RCT111 | 180 min, (2–4 hr) | G1: Diclofenac sodium, n=46, 75mg IM G2: Paracetamol, n=40, 500 mg IM | G1: 47.5, 21 (53.8), NR G2: 48.3, 26 (63.4), NR | G1: Severity of symptoms: slight (1), moderate (10), severe (35); NR G2: Severity of symptoms: slight (1), moderate (10), severe (30); NR | 1: Partial or complete relief of pain
NSAIDs versus active agents | Larkin, 1992, U.S., RCT101 | 60 min, (24hr) | G1: KET, n=15, 30mg IM G2: MEP, n=16, 75mg IM | G1: 31.5 (4.4), 12 (80.0), NR G2: 33.8 (5.0), 12 (75.0), NR | G1: Grade 3 (most severe): 11 (73.3), Grade 2 (marked): 4 (26.7), Grade 1 (mild): 0 (0.0); NR G2: Grade 3 (most severe): 14 (87.5), Grade 2 (marked): 2 (12.5), Grade 1 (mild): 0 (0.0); NR | 1: reduction in pain (4-pt verbal analogue scale) 2: assessment of clinical disability
NSAIDs versus active agents | Limmroth, 1999, Germany, RCT56 | 120min, (2hr) | G1: Lysine acetylsalicylic acid, n=56, 1000mg IV G2: Ergotamine, n=56, 0.5mg SC | Total: 41 (10.3), 48 (85.7) NR | G1: NR, NR G2: NR, NR | 1: pain relief, (VAS) 2: improvement of nausea and vomiting
NSAIDs versus active agents | Meredith, 2003, U.S., RCT84 | 60 min, (NA) | G1: KET, n=13, 30 mg IV G2: SUM, n=16, 20 mg Nasal | G1: 33 (range: 18–54), total: 25 (86.2), NR G2: 34 (range: 19–56), total: 25 (86.2), NR | G1: VAS: 92.39 mm (10.94), NR G2: VAS: 84.63 mm (18.10), NR | 1: pain score (VAS)

ED = emergency department; G1 = group 1; G2 = group 2; HDZ = hydroxyzine; IM = intramuscular; IV = intravenous; KET = ketorolac; MEP = meperidine; NR = not reported; NSAID = nonsteroidal anti-inflammatory drug; P = placebo; PMZ = promethazine; pt = point; RCT = randomized controlled trial; SD = standard deviation; SUM = sumatriptan; VAS = visual analogue scale

##### NSAIDs Versus Placebo

###### Description of Included Studies

Two RCTs assessed the effectiveness of NSAIDs compared with placebo in the treatment of acute migraine headaches.42,100 The NSAIDs included lysine clonixinate100 and diclofenac.42 One study100 was conducted in a headache clinic and one42 was conducted in a public health clinic. The mean age of participant groups was 32 years in one study.100 The participants were predominantly female and neither study reported the race or ethnicity of participants. Both studies reported pain relief or severity as the primary outcome at 60 to 120 minutes after administration. Post-ED followup timepoints ranged from 2 to 24 hours. The secondary outcomes included recurrence, use of rescue medication, and analgesic efficacy.

One study42 had an unclear risk of bias, and the other100 had a high risk of bias (Appendix D).

###### Effectiveness Results

###### Change in Pain Intensity (Pain Free)

The change in pain intensity was measured as pain free at 1–2 hours in two studies42,100 (Figure 17). The pooled results show that those who received NSAIDs experienced a greater decrease in pain intensity compared with those who received placebo (RR = 2.74; 95% CI: 1.26, 5.98; I^2^= 47%).

Figure 17 Pain free at 1–2 hours in trials comparing NSAIDs and placebo

Figure 17 displays a forest plot of studies reporting being pain free at 1–2 hours, NSAID vs. placebo. Two studies reported pain free status. One study showed a significant difference in favor of diclofenac when compared to placebo (RR = 4.20; 95% CI: 1.70, 10.41). When pooled, the overall risk ratio was in favor of NSAIDs (RR = 2.74; 95% CI: 1.26, 5.98; I2 = 47%).

###### Analgesic Efficacy at 1 and 24 Hours

One study measured analgesic efficacy at 1 hour and then again at 24 hours for diclofenac versus placebo.42 The authors found that diclofenac was superior to placebo at 1 hour (RR = 3.11; 95% CI: 1.61, 6.02); however, no difference was found at 24 hours (RR = 1.14; 95% CI: 0.93, 1.39).

###### Headache Recurrence

One study42 reported headache recurrence, defined as return of pain within 24 hours after administration of the drug, and found that there was a statistically significant difference in favor of diclofenac (RR = 0.32; 95% CI: 0.17, 0.62).

##### NSAIDs Versus Active Agents

###### Description of Included Studies

Nine RCTs54–56,71,81,84,94,101,111 assessed the effectiveness of NSAIDs versus other active agents. The NSAIDs included ketorolac,55,94,101 diclofenac81,111 and lysine acetylsalicylic acid.56 Comparators included meperidine monotherapy or in combination with other agents,55,94,101 sumatriptan,84 paracetamol,111 ergotamine,56 and tramadol.81 Two studies have been described in another section of the report (neuroleptics) and compared NSAIDs with prochlorperazine71 and chlorpromazine hydrochloride.54

All interventions were delivered in the ED, and assessments occurred between 60 and 180 minutes following administration. Followup ranged from 2 to 48 hours after patient discharge. The number of participants who were randomized ranged from 29 to 112 (median = 47; IQR = 37, 68). The mean ages of intervention groups ranged from 18 to 56 years. All studies had a pain related primary outcome. The secondary outcomes varied and included use of rescue medication, adverse effects, and assessment of clinical disability. See Table 13 for study and patient characteristics. Table 9 reports study and patient characteristics for the studies described previously.54,71

Two studies54,81 had a low risk of bias, while the remaining seven studies had an unclear risk of bias (Appendix D).

###### Effectiveness Results

###### Pain Intensity (VAS)

Five studies54,55,71,84,94 reported pain intensity using the VAS (mm) (Figure 18, Table 11). Table 8 describes the two studies that were analyzed in the neuroleptics section. All studies compared ketorolac with an active agent. One study84 showed a significant difference in favor of ketorolac compared with nasal sumatriptan (MD = −48.53; 95% CI: −65.54, −31.51). One study showed a signficant difference in favor of prochlorperazine (MD = −19.00 (95% CI: −34.97, −3.03).71 There was no difference when comparing ketorolac with meperidine plus hydroxyzine, ketorolac with meperidine plus promethazine (Figure 20), or ketorolac tropethamine with chlorpromazine hydrochloride (Table 8).

Figure 18 Pain intensity (VAS) in trials comparing NSAIDs and other active agents

VAS = visual analogue scale

Figure 18 displays a forest plot of studies reporting pain intensity using the Visual Analogue Scale, NSAID vs. other active agents Two studies reported pain intensity. One study reported a difference in favor of ketorolac when compared to sumatriptan (MD = −48.53; 95% CI: −65.54, −31.51).

Figure 20 Pain free at 1–2 hours in trials comparing NSAIDs and other active agents

Figure 20 displays a forest plot of studies reporting being pain free at 1–2 hours, NSAID vs. other active agents Three studies reported pain free status. One study favored diclofenac sodium when compared to paracetamol (RR = 5.08; 95% CI: 2.57, 10.03).

###### Pain Response

Four studies reported a pain response after treatment (Figure 19).55,56,81,101 One study 56 comparing lysine acetylsalicylic acid and ergotamine significantly favored NSAIDs (RR = 1.92; 95% CI: 1.10, 3.36). There was no statistically significant difference between NSAIDs and the other three active agents.55,81,101 One study81 also reported a pain response at 48 hours and found no difference between diclafenec and tramadol (RR = 0.92; 95% CI; 0.57, 1.49).

Figure 19 Pain response after treatment in trials comparing NSAIDs and other active agents

Figure 19 displays a forest plot of studies reporting pain response after treatment, NSAID vs. other active agents. Four studies reported pain response. Only one study was significant and it favored lysine acetylsalicyclic acid when compared to ergotamine (RR = 1.92; 95% CI: 1.10, 3.36).

###### Pain Free at 1–2 Hours

Three studies reported being pain free at 1–2 hours (Figure 20).81,101,111 One study111 showed a significant difference in favor of NSAIDs when comparing diclofenac sodium and paracetamol (RR = 5.08; 95% CI: 2.57, 10.03). There was no statistically significant difference in the other two studies.81,101 One study81 reported being pain free at 48 hours and found no difference between diclofenac and tramadol (RR = 1.33; 95% CI: 0.57, 3.14).

###### Headache Recurrence at 48 Hours

One study81 reported the recurrence of headache at 48 hours and found no difference between diclofenac and tramadol (RR = 1.50; 95% CI: 0.28, 8.04).

###### Additional Analgesia

One study94 reported the need for additional analgesia and found no difference between ketorolac and meperidine plus hydroxyzine (RR = 1.29; 95% CI: 0.57, 2.91).

###### Disability at 1 Hour

One study101 reported disability at 1 hour and found no difference between ketorolac and meperidine (RR = 0.64; 95% CI: 0.31, 1.32).

### Opioids

#### Key Points

- Patients who received opioids had greater improvement in pain intensity as measured by VAS (mm) compared with those receiving placebo based on three RCTs (moderate strength of evidence).
- For all head to head comparisons, single trials compared opioids with other active agents for pain intensity, pain free, and headache recurrence (insufficient strength of evidence).

#### Results

The results for studies that assessed the effectiveness of opioids are summarized below. Table 14, Table 15, and Table 16 provide results or strength of evidence grades for all key outcomes. See Table 17 for details on study and patient characteristics.

Table 14 Strength of evidence for opioids versus placebo

Comparison | Outcome (N Studies; N Patients) | Strength of Evidence Domains | | | | Strength of Evidence
Comparison | Outcome (N Studies; N Patients) | ROB | Consistency | Direct | Precision | Strength of Evidence
Opioids vs. placebo | Pain intensity–VAS (3; 178) | Moderate | Consistent | Direct | Precise | Moderate

N = number; ROB = risk of bias; VAS = visual analogue scale

Table 15 Opioids versus active agents in acute migraine

Comparison | Study, Year Study Design (# Patients) | Interventions | Risk of Bias | Outcomes | Data Source
Metoclopramide vs. opioids | Cicek, 2004, RCT (n = 99) | Metoclopramide vs. pethidine | Unclear | Pain intensity–VAS: (MD = −10.00; 95% CI: −19.21, −0.79); favors metoclopramide | Figure 7
Neuroleptics vs. opioids | Hoag, 1986, RCT (n = 40) | Meperidine + dimenhydrinate vs. methotrimeprazine | High | Pain intensity–VAS: (MD = 15.00; 95% CI: −2.75, 32.75) | Figure 22
Neuroleptics vs. opioids | Lane, 1989, RCT (n=46) | Chlorpromazine vs. meperidine + dimenhydrinate | Unclear | Pain intensity–VAS: (MD = −26.10; 95% CI: −40.10, −12.10); favors chlorpromazine | Figure 11
Neuroleptics vs. opioids | Richman, 2002, RCT (n=28) | Droperidol vs. meperidine | Unclear | Pain intensity–VAS: (MD = −10.00; 95% CI: −30.03, 10.03); | Figure 11
Neuroleptics vs. opioids | Stiell, 1991, RCT (n=74) | Methotrimeprazine vs. meperidine + dimenhydrinate | Low | Pain intensity–VAS: (MD = 6.30; 95% CI: −4.77, 17.37) | Figure 11
Opioids vs. NSAIDs | Davis, 1995, RCT (n=42) | Ketorolac vs. meperidine + promethazine | Unclear | Pain intensity–VAS: (MD = 0.00; 95% CI: −7.51, 7.51) Pain response (post tx): (RR = 0.81; 95% CI: 0.49, 1.31) | Figure 18 Figure 19
Opioids vs. NSAIDs | Duarte, 1992, RCT (n=50) | Ketorolac vs. meperidine + hydroxyzine | Unclear | Pain intensity–VAS: (MD = 5.20; 95% CI: −10.08, 20.48) | Figure 18
Opioids vs. NSAIDs | Engindinez, 2005, RCT (n=40) | Diclofenac vs. tramadol | Low | Pain response (post tx): (RR = 1.00; 95% CI: 0.73, 1.36); Pain free (1–2hr): (RR = 1.29; 95% CI: 0.60, 2.77) Headache recurrence (48hr): (RR = 1.50; 95% CI: 0.28, 8.04) | Figure 19 Figure 20
Opioids vs. NSAIDs | Larkin, 1992, RCT (n=31) | Ketorolac vs. meperidine | Unclear | Pain response (post tx): (RR = 0.53; 95% CI: 0.24, 1.20) Pain free (1–2hr): (RR = 0.21; 95% CI: 0.03, 1.62) | Figure 19 Figure 20
Opioids vs. DHE | Carleton,1988, RCT (n=156) | DHE vs. meperidine | Low | Pain intensity–VAS: (MD = 2.20; 95% CI: −10.03, 14.43); | Figure 23
Opioids vs. opioids | Belgrade, 1989, RCT (n = 64) | Butorphanol vs. meperidine + hydroxyzine | High | Pain intensity–VAS: (MD = −17.00; 95% CI: −31.41, −2.59); favors opioid | Figure 22
Opioids vs. opioids | Tek, 1987, RCT (n = 46) | Nalbuphine vs. nalbuphine + hydroxyzine | Low | Pain intensity–VAS: (MD = −15.80; 95% CI: −32.66, 1.06); | Figure 22
Opioids vs. corticosteroid | Taheraghdam, 2011, RCT (n = 190) | Morphine vs. dexamethasone | Unclear | Pain intensity–VAS: (MD = −8.20; 95% CI: −12.58, −3.82); favors morphine | Figure 22

CI = confidence interval; DHE = dihydroergotamine; RR = risk ratio; RCT = randomized controlled trial; Tx = treatement; VAS = visual analogue scale

Table 16 Strength of evidence for opioids versus active agents

Comparison | Outcome (N Studies; N Patients) | Strength of Evidence Domains | | | | Strength of Evidence
Comparison | Outcome (N Studies; N Patients) | ROB | Consistency | Direct | Precision | Strength of Evidence
Nalbuphine vs. nalbuphine + hydroxyzine | Pain intensity–VAS (1; 46) | Low | Unknown | Direct | Imprecise | Insufficient
Butorphanol vs meperidine + hydroxyzine | Pain intensity–VAS (1; 41) | High | Unknown | Direct | Precise | Insufficient
Nalbuphine vs hydoxyzine | Pain intensity–VAS 1; 47) | Low | Unknown | Direct | imprecise | Insufficient
Nalbuphine + hydroxyzine vs hydroxyzine | Pain intensity–VAS (1;47) | Low | Unknown | Direct | Imprecise | Insufficient
Meperidine + dimenhydrinate vs methotri-meprazine | Pain intensity–VAS (1;40) | High | Unknown | Direct | Imprecise | Insufficient
Morphine vs dexamethasone | Pain intensity–VAS (1; 190) | Moderate | Unknown | Direct | Precise | Insufficient
Diclofenac vs. tramadol | Headache recurrence (48 hrs) | Low | Unknown | Direct | Imprecise | Insufficient

N = number; ROB = risk of bias; VAS = visual analogue scale

Table 17 Patient and study characteristics of trials comparing opioids with placebo or active agents

Comparison | Author, Year, Country Study Design | Timepoints Measured in the ED (Post ED Followup) | Intervention, N randomized, Dosage, Route of Administration | Mean Age (SD), Females (%), White (%) | Description of Migraine Severity: Mean (SD); Duration of Migraine Prior to Coming Into ED | Primary Outcomes; Secondary outcomes
Opioids versus placebo | Alemdar, 2007, Turkey RCT77 | 60 min, (24 hr) | G1: Tramadol, n=17, 100 mg IV P: Placebo, n=17, 100 ml IV | G1: 42 (11.5), 13 (76.5), NR P: 37.1 (9), 15 (88.2), NR | G1: NR, NR P: NR, NR | 1: pain response at 60 min (VAS) 2: pain-free response, adverse effects, headache recurrence
Opioids versus placebo | Cicek, 2004, Turkey RCT113 | 45 min, (4 hr) | G1: MET, n=196 (Vascular headache); 140 (tension headache), IM Placebo + 10 mg IV MET G2: MET+PET, n=49, 10 mg IV MET+50 mg IM PET G3: PET, n=49, IV Placebo + 50 mg IM PET P: Placebo, n=48, NR IV and IM | Total: 38.8 (11.1) vascular headache; 42.1 (13.8) for tension headache; mean age of all subjects 40.2 (12.4), 7.1 (female to male ratio for vascular headache), 2.5 (in tension headache group), | G1: NR, NR G2: NR, NR P: NR, NR | 1: pain intensity (VAS) 2: side effects
Opioids versus placebo | Tek, 1987, U.S. RCT98 | 60min, (7d) | G1: NAL, n=23, 10mg IM G2: NAL + HDZ, n=23, 10mg + 50mg IM G3: HDZ, n=24, 50mg IM P: Placebo, n=24, 2 ml IM | G1: NR, NR, NR G2: NR, NR, NR G3: NR, NR, NR P: NR, NR, NR | G1: NR, NR G2: NR, NR G3: NR, NR P: NR, NR | 1: pain relief (4-pt scale)
Opioids versus active agents | Belgrade, 1989, U.S. RCT110 | 30 min (72 hr) | G1: MEP+ HDZ, n=22, 75mg MEP+ 50mg HDZIM G2: BUT, n=19, 2mg IM G3: MET, n=23, 1mg DHE + 10mg MET IV | G1: 33 (11), 13 (59.1), NR G2: 29 (9), 11 (57.9), NR G3: 29(8), 13 (61.9), NR | G1: Initial pain score (1–100): 82(18), NR G2: Initial pain score (1–100): 84(11), NR G3: Initial pain score (1–100): 83(19), NR | 1: pain score improvement (1 to 100 where 100 is worst possible pain) 2: blood pressure
Opioids versus active agents | Hoag, 1986, Canada RCT112 | Post tx, (24 hr) | G1: MEP+DMH, n=18, 75 mg + 50 mg IM G2: MTM, n=22, 25 mg IM | G1: NR, NR, NR G2: NR, NR, NR | G1: VAS: 8.1, NR G2: VAS: 8.4, NR | 1: pain severity (VAS) 2: nausea
Opioids versus active agents | Taheraghdam, 2011, Iran RCT115 | 60 min, (24 hr) | G1: Morphine, n=97, 0.1mg/kg IV G2: Dexamethasone, n=93, 8 mg IV | G1: 42.3 (16.2), 65 (67%), NR G2: 45.93 (16.1), 52 (55.9%), NR | G1: VAS: 8.75 (1.43), NR G2: VAS: 8.49 (1.5), NR | 1: pain severity (VAS)
Opioids versus active agents | Tek, 1987, U.S. RCT98 | 60 min, (7d) | G1: NAL, n=23, 10mg IM G2: NAL+HDZ, n=23, 10mg + 50mg IM G3: HDZ, n=24, 50mg IM P: Placebo, n=24, 2 ml IM | G1: NR, NR, NR G2: NR, NR, NR G3: NR, NR, NR P: NR, NR, NR | G1: NR, NR G2: NR, NR G3: NR, NR P: NR, NR | 1: pain relief (4-pt scale)

BUT = butorphanol; DHE = dihydroergotamine; DMH = dimenhydrinate; ED = emergency department; G1 = group 1; G2 = group 2; G3 = group 3; HDZ = hydroxyzine; IM = intramuscular; IV = intravenous; MET = metoclopramide; MTM = methotrimeprazine; N = number; NAL = nalbuphine; NR = not reported; P = placebo; PET = pethidine; RCT = randomized controlled trial; SD = standard deviation; VAS = visual analogue scale

##### Opioids Versus Placebo

###### Description of Included Studies

Three RCTs assessed the effectiveness of opioids versus placebo in patients with acute migraine headache.77,98,113 One study was a four-arm trial that compared nalbuphine monotherapy, nalbuphine plus hydroxyzine, hydroxyzine monotherapy, and placebo. The opioids included pethidine,113 nalbuphine,98 nalbuphine plus hydroxyzine,98 and tramadol.77 All studies were performed in the ED. The mean age of patient groups ranged from 37 to 40 years. The participants were predominantly female. None of the studies reported the race or ethnicity of participants. All studies reported pain relief or severity as the primary outcome at a range from 45 to 60 minutes after administration of the drugs. Followup occurred 4 hours to 7 days after ED discharge. Secondary outcomes included headache recurrence and adverse effects.

One study98 had a low risk of bias, one113 had an unclear risk of bias, and one77 had a high risk of bias (Appendix D).

###### Effectiveness Results

###### Change in Pain Intensity (VAS)

All three studies assessed pain intensity using the VAS (mm) (Figure 21). Pooled results demonstrated that opioids significantly decreased pain intensity compared with placebo (MD = −16.73; 95% CI: −24.12, −9.33; I^2^ = 0%).

Figure 21 Pain intensity (VAS) in trials comparing opioids and placebo

VAS = visual analogue scale

Figure 21 displays a forest plot of studies reporting change in pain intensity using the Visual Analogue Scale, opioids vs. placebo. Three studies reported pain intensity. The two studies that significantly favored opioids were using pethidine and nalbuphine. The overall pooled estimate favored opioids when compared to placebo (MD = −16.73; 95% CI: −24.12, −9.33; I2 = 0%).

###### Pain Free Response

One study77 reported “pain free after treatment” and found no significant difference between tramadol and placebo (RR = 2.50; 95% CI: 0.56, 11.16).

##### Opioids Versus Active Agents

###### Description of Included Studies

Thirteen RCTs assessed the effectiveness of opioids versus other active agents. The opioids included meperidine,55,94,101 pethidine,113 tramadol,81 nalbuphine,98 meperidine plus dimenhydrinate,66,112 nalbuphine plus hydroxyzine,98 butorphanol,110 and morphine.115 The other active agents included nalbuphine plus hydroxyzine,98 hydroxyzine,98 meperidine plus hydroxyzine,110 methotrimeprazine,112 metoclopramide, methotrimeprazine, droperidol, chlorpromazine ketorolac, ketorolac plus promethazine, and DHE. Nine studies 53,55,66,67,81,85,94,101,113 have been described in other sections of the report (metoclopramide, neuroleptics, NSAIDs, and DHE).

All interventions took place in the ED with outcomes assessed between 30 and 120 minutes after treatment. Post-ED followup ranged from 24 hours to 7 days. The mean age of intervention groups ranged from 29 to 46 years. See the following tables for details on study and patient characteristics: Table 6 (metoclopramide), Table 9 (neuroleptics), Table 13 (NSAIDs), Table 17 (opioids), and Table 19 (DHE).

Table 19 Patient and study characteristics of trials comparing DHE and active agents

Author, Year, Country, Study Design | Timepoints Measured in the ED (Post ED Followup) | Intervention, N Randomized, Dosage, Route of Administration | Mean Age (SD), Females (%), White (%) | Description of Migraine Severity: Mean (SD); Duration of Migraine Prior to Coming Into ED | Primary Outcomes; Secondary Outcomes
Carleton, 1998, U.S., RCT53 | 60 min (24 hr) | G1: DHE, n=85, 1mg IM G2: MEP, n=85, 1.5mg/kg IM | G1: 32.52(8.82), 70 (82.3), NR G2: 32.36(8.78), 70 (82.3), NR | G1: Mean vascular score: 6.74(1.63), 33.75 hr (45.36) G2: Mean vascular score: 6.85 (1.82), 24.81 hr (25.71) | 1: headache pain (VAS) 2: functional impairment, nausea, physician global assessment, vital signs, adverse events
Jovicic, 1995, Serbia, RCT93 (Serbian) | After tx, (8 hr) | G1: DHE, n=17, 1mg IM G2: Diclofenac, n=17, 75mg IM | G1: 37.5 (10), 12 (70.6), NR G2: 38.4(8.4), 13 (76.5), NR | G1: Headache index: 30 (4), NR G2: Headache index: 34.2(4.5), NR | 1: headache index
Bell, 1990, Canada, RCT96 | 60 min (24hr) | G1: CPZ, n=24, 12.5mg IV G2: DHE, n=26, 1mg IV G3: LID, n=26, 50mg IV | Total: NR, 60 (79), NR | G1: Median intensity score (10-pt scale): 8.5; NR G2: Median intensity score (10-pt scale): 7.5; NR G3: Median intensity score (10-pt scale): 8.0; NR | 1: headache response (10-pt scale, with 10 denoting the worst headache)
Winner, 1996, U.S., RCT61 | 2 hr (24hr) | G1: DHE, n=152, 1mg SC G2: SUM, n=158, 6mg SC | G1: 40.5 (8.6), 133 (87.5), NR G2: 41.5, 139 (88.0), NR | G1: NR, NR G2: NR, NR | 1: % patients with relief (4-pt scale: none, mild, moderate, severe) 2: recurrence, functional ability, physicians global rating, nausea &; emesis, safety

CPZ = chlorpromazine; DHE = dihydroergotamine; ED = emergency department; G1 = group 1; G2 = group 2; G3 = group 3; IM = intramuscular; IV = intravenous; LID = lidocaine; MEP = meperidine; NR = not reported; PET = pethidine; pt = point; RCT = randomized controlled trial; SC = subcutaneous; SD = standard deviation; SUM = sumatriptan; tx = treatment; VAS = visual analogue scale

Four studies had low risk of bias,53,66,81,98 seven studies55,67,85,94,101,113,115 had unclear risk of bias, and two studies110,112 had a high risk of bias (Appendix D).

###### Effectiveness Results

###### Change in Pain Intensity (VAS)

The four studies98,110,112,115 that have not been reported in other sections of the report used the VAS (mm) to measure pain intensity (Figure 22). Two studies110,115 showed a significant result in favor of opioids when comparing butorphanol versus meperidine plus hydroxyzine and morphine versus dexamethasone (MD = −17.00; 95% CI: −31.41, −2.59 and MD = −8.2; 95% CI: −12.58, −3.82 respectively). There was no statistically significant difference between opioids and other active agents in the other two studies. The studies that assessed pain intensity in other sections of the report are summarized in Table 15.

Figure 22 Pain intensity (VAS) in trials comparing opioids and other active agents

VAS = visual analogue scale

Figure 22 displays a forest plot of studies reporting pain intensity using the Visual Analogue Scale, opioids vs. other active agents. Four studies reported pain intensity. One study showed a significant result in favor of opioids when comparing butorphanol versus meperidine plus hydroxyzine (MD = −17.00, 95% CI: −31.41, −2.59). Another study reported significant difference in morphine over dexamethasone (MD = 8.20; 95% CI: −12.58, −3.82). There was no difference seen between opioids and other active agents in the remaining studies.

One study measured pain intensity (VAS) at 24 hours115 and found no statistically significant difference between patients who received morphine and those who received dexamethasone (MD = 1.30, 95% CI: −2.47, 5.07).

###### Pain Free Response

Three studies55,81,101 reported “pain free after treatment” and found no difference between opioids and other active agents. One trial81 reported “pain free after 2 hours” and found a statistically significant difference in favor of opioids (RR = 1.29; 95% CI: 0.60, 2.77). The studies that assessed pain free status in previous sections of the report are summarized in Table 15.

###### Headache Recurrence

One study81 reported the recurrence of headache at 2 days following the intervention and found no difference between diclofenac and tramadol (RR = 1.50; 95% CI: 0.28, 8.04). The study that assessed headache recurrence previously in another section of the report is summarized in Table 15.

### Dihydroergotamine (DHE)

#### Key Points

- For all head to head comparisons, single trials compared DHE with other active agents for pain intensity, headache relief, pain response, and headache recurrence (insufficient strength of evidence).

#### Results

The results for studies that assessed DHE are summarized below. Table 18 provides the strength of evidence grades for all key outcomes. See Table 19 for details on study and patient characteristics.

Table 18 Strength of evidence for DHE versus active agents

Comparison | Outcome (N Studies; N Patients) | Strength of Evidence Domains | | | | Strength of Evidence
Comparison | Outcome (N Studies; N Patients) | ROB | Consistency | Direct | Precision | Strength of Evidence
DHE vs Meperidine | Pain intensity–VAS (1; 156) | Low | Unknown | Direct | Imprecise | Insufficient
DHE vs Diclofenac | Pain intensity–VAS (1; 46) | Moderate | Unknown | Direct | Imprecise | Insufficient
DHE vs Sumatriptan | Headache relief (1hr) (1; 295) | Moderate | Unknown | Direct | Precise | Insufficient
DHE vs Sumatriptan | Headache relief (2 hrs) (1; 295) | Moderate | Unknown | Direct | Precise | Insufficient
DHE vs Sumatriptan | Headache relief (3 hrs) (1; 295) | Moderate | Unknown | Direct | Imprecise | Insufficient
DHE vs Sumatriptan | Headache relief (4 hrs) (1; 295) | Moderate | Unknown | Direct | Imprecise | Insufficient
DHE vs Sumatriptan | Headache relief (24 hrs) (1; 295) | Moderate | Unknown | Direct | Precise | Insufficient
DHE vs Sumatriptan | Headache recurrence (1; 295) | Moderate | Unknown | Direct | Precise | Insufficient
Lysine acetyl-salicylic acid vs. DHE | Pain response (1; 112) | Moderate | Unknown | Direct | Precise | Insufficient

DHE = dihydroergotamine; N = number; ROB = risk of bias; VAS = visual analogue scale

##### DHE Versus Active Agents

###### Description of Included Studies

Five RCTs,53,56,61,93,96 with six comparisons, assessed the effectiveness of DHE versus other active agents. Active agents included meperidine,53 diclofenac,93 sumatriptan,61 chlorpromazine,96 lidocaine,96 and lysine acetylsalicylic acid.56 One study56 was described in a previous section (NSAIDs) of this report (Table 13).

Three studies53,56,96 were conducted in the ED, and two61,93 were conducted in clinics that managed patients with acute headaches. Assessments occurred immediately after treatment to 2 hours after treatment; followup assessments ranged from 2 to 24 hours following patient discharge. The number of participants who were randomized ranged from 34 to 310. The mean age of intervention groups ranged from 32 to 42 years. All studies had a pain related primary outcome. Secondary outcomes included adverse effects, functional impairment, recurrence, vital signs, and physician global rating.

One study53 had a low risk of bias, three had an unclear risk of bias,56,61,93 and one96 had a high risk of bias (Appendix D).

###### Effectiveness Results

###### Change in Pain Intensity (VAS)

Change in pain intensity was reported in two studies at 30 minutes53 and 60 minutes.53,93 There was no statistically significant difference between DHE and meperidine at 30 minutes,53 nor was there a difference at 60 minutes between DHE versus diclofenac or DHE versus meperidine (Figure 23).

Figure 23 Pain intensity (VAS) at 60 minutes in trials comparing DHE and other active agents

VAS = visual analogue scale

Figure 23 displays a forest plot of studies reporting pain intensity at 60 minutes using the Visual Analogue Scale, DHE vs. other active agents. Two studies reported pain intensity. There was no difference shown for either of the studies.

###### Headache Relief

Headache relief was reported at 1, 2, 3, 4, and 24 hours in one study.61 At both 1 and 2 hours, sumatriptan was significantly more effective than DHE (RR = 0.73; 95% CI: 0.61, 0.86 and RR = 0.86; 95% CI: 0.76, 0.96, respectively). There were no differences at the 3 and 4 hour assessments. At 24 hours, DHE was more effective than sumatriptan (RR = 1.17; 95% CI: 1.05, 1.30).

###### Pain Response

One study56 comparing lysine acetylsalicylic acid and ergotamine showed a statistically significant difference that favored NSAIDs (RR = 1.92; 95% CI: 1.10, 3.36) (Figure 19).

###### Improvement of Functional Impairment

Two studies53,61 assessed improvement of functional impairment. One study53 found that patients receiving DHE had greater functional improvement compared with patients receiving meperidine (RR = 2.27; 95% CI: 1.20, 4.29). The second study61 found that patients receiving sumatriptan had greater functional improvement compared with patients receiving DHE (RR = 0.65; 95% CI: 0.53, 0.80).

###### Headache Recurrence

One study reported headache recurrence and found a statistically significant difference in favor of DHE versus sumatriptan (RR = 0.39; 95% CI: 0.26, 0.59).61

###### Nausea and Vomiting

Two studies reported nausea, and one reported vomiting. One study61 showed a difference in favor of sumatriptan when compared with DHE for nausea (RR = 1.60; 95% CI: 1.10, 2.32). There was no statistically significant difference when comparing DHE with meperidine (RR = 0.94; 95% CI: 0.66, 1.35).53 One study61 compared DHE versus sumatriptan for emesis and found no statistically significant difference (RR = 1.38; 95% CI: 0.49, 3.88).

### Triptans

#### Key Points

- Patients who received sumatriptan had greater headache relief at 60 minutes compared with those receiving placebo based on four RCTs (moderate strength of evidence).
- More patients who received sumatriptan were pain free at discharge compared with those receiving placebo based on five RCTs (moderate strength of evidence).
- Fewer patients who received sumatriptan experienced headache recurrence compared with those receiving placebo based on four RCTs (low strength of evidence).
- For all head to head comparisons, single trials compared sumatriptan with other active agents for change in pain (VAS), headache relief, and headache recurrence (insufficient strength of evidence).

#### Results

The results for studies comparing triptans and placebo and active comparators are summarized below. Table 20, Table 21, and Table 22 present results or the strength of evidence grades for all key outcomes. See Table 23 for details on study and patient characteristics.

Table 20 Strength of evidence for triptans versus placebo

Comparison | Outcome (N Studies; N Patients) | Strength of Evidence Domains | | | | Strength of Evidence
Comparison | Outcome (N Studies; N Patients) | ROB | Consistency | Direct | Precision | Strength of Evidence
Sumatriptan vs placebo | Headache relief at 60 min (5; 1,789) | Moderate | Consistent | Direct | Precise | Moderate
Almotriptan vs placebo | Headache relief at 60 min (1; 123) | Moderate | Unknown | Direct | Imprecise | Insufficient
Sumatriptan vs placebo | Headache relief at 120 min (4; 1,177) | Moderate | Consistent | Direct | Precise | Moderate
Almotriptan vs placebo | Headache relief at 120 min (1; 123) | Moderate | Unknown | Direct | Precise | Insufficient
Sumatriptan vs placebo | Headache relief–VAS at 30 min (2; 628) | Moderate | Consistent | Direct | Precise | Moderate
Sumatriptan vs placebo | Headache relief–VAS at 60 min (1; 577) | Moderate | Unknown | Direct | Precise | Insufficient
Sumatriptan vs placebo | Headache relief–VAS at 120 min (1; 577) | Moderate | Unknown | Direct | Precise | Insufficient
Sumatriptan vs placebo | Pain free status (5; 2,394) | Moderate | Consistent | Direct | Precise | Moderate
Almotriptan vs placebo | Pain free status (1; 123) | Moderate | Unknown | Direct | Imprecise | Insufficient
Sumatriptan vs placebo | Headache recurrence–ED setting (4; 330) | Moderate | Inconsistent | Direct | Precise | Low
Sumatriptan vs placebo | Headache recurrence–non-ED setting (1; 315) | Moderate | Unknown | Direct | Precise | Insufficient
Sumatriptan vs placebo | Headache severity at discharge (1; 136) | Moderate | Unknown | Direct | Precise | Insufficient

ED = emergency department; N = number; RCT = randomized controlled trial; ROB = risk of bias

Table 21 Triptans vs. other active agents

Other Active Agents | Study, Year Study Design (# Patients) | Interventions | Risk of Bias | Outcomes | Data Source
Metoclopramide vs. triptans | Friedman, 2005 RCT (n = 78) | Metoclopramide vs. sumatriptan | Unclear | Pain intensity–VAS: (MD = −9.00; 95% CI: −20.99, 2.99) | Figure 7
Metoclopramide vs. triptans | Friedman, 2006 RCT (n = 40) | TMB + DPH vs. sumatriptan | Low | Pain intensity–VAS: (MD = 17.00; 95% CI: −0.08, 34.08) | Figure 7
Neuroleptics vs. triptans | Kostic, 2010 RCT (n=66) | PCZ + DPH vs. sumatriptan | Low | Pain intensity–VAS: (MD = −23.00; 95% CI: −35.50, 10.50); favors neuroleptic | Figure 11
NSAIDs vs. triptans | Meredith, 2003 RCT (n = 29) | KET vs. sumatriptan | Unclear | Pain intensity–VAS: (MD = −48.53; 95% CI: −65.54, −31.51); favors NSAIDs | Figure 18

CI = confidence interval; CPZ = chlorpromazine; DHE = dihydroergotamine; DPH = diphenhydramine; KET = ketorolac; MD = mean difference; PCZ = prochlorperazine; RCT = randomized controlled trial; TMB = trimethobenzamide; VAS = visual analogue scale

Table 22 Strength of evidence for sumatriptan versus other active agents

Comparison | Outcome (N Studies; N Patients) | Strength of Evidence Domains | | | | Strength of Evidence
Comparison | Outcome (N Studies; N Patients) | ROB | Consistency | Direct | Precision | Strength of Evidence
Metoclopramide vs. sumatriptan | Change in pain (<2 hr)–VAS (1; 78) | Moderate | Unknown | Direct | Imprecise | Insufficient
Trimethobenzamine + diphen-hydramine vs. sumatriptan | Change in pain (<2 hr)–VAS (1; 40) | Low | Unknown | Direct | Imprecise | Insufficient
Prochlorperazine + DPH vs. sumatriptan | Change in pain–VAS (1; 66) | Low | Unknown | Direct | Precise | Insufficient
Ketorolac vs. sumatriptan | Change in pain–VAS (1; 29) | Moderate | Unknown | Direct | Precise | Insufficient
Sumatriptan vs. DHE | Headache relief (1hr) (1; 295) | Moderate | Unknown | Direct | Precise | Insufficient
Sumatriptan vs. DHE | Headache relief (2 hr) (1; 295) | Moderate | Unknown | Direct | Precise | Insufficient
Sumatriptan vs. DHE | Headache relief (3 hr) (1; 295) | Moderate | Unknown | Direct | Imprecise | Insufficient
Sumatriptan vs. DHE | Headache relief (4 hr) (1; 295) | Moderate | Unknown | Direct | Imprecise | Insufficient
Sumatriptan vs. DHE | Headache relief (24 hr) (1; 295) | Moderate | Unknown | Direct | Precise | Insufficient
Sumatriptan vs. DHE | Headache recurrence (1; 270) | Moderate | Unknown | Direct | Precise | Insufficient

DHE = dihydroergotamine; DPH = diphenhydramine; N = number; ROB = risk of bias; VAS = visual analogue scale

Table 23 Patient and study characteristics of trials comparing triptans and placebo

Author, Year, Country, Study Design | Timepoints Measured in the ED (Post ED Followup) | Intervention, N Randomized, Dosage, Route of Administration | Mean Age (SD), Females (%), White (%) | Description of Migraine Severity: Mean (SD); Duration of Migraine Prior to Coming Into ED | Primary Outcomes; Secondary Outcomes
Akpunonu, 1995, U.S., RCT 106 | discharge, (24 hr) | G1: SUM, n=88, 6mg SC P: Placebo, n=48, NR SC | G1: 39.8 (10); 78 (88.6); White: 78 (88.6), Black: 10 (11.4), Other: 0 (0.0) P: 39.8 (9.4); 41 (85.4); White: 44 (91.7), Black: 3 (6.3), Other: 1 (2.1) | G1: 4-pt pain scale: moderate 33 (37.5), severe 55 (62.5); 13hr (median) P: 4-pt pain scale: moderate 22 (45.8), severe 26 (54.2); 16 hr (median) | 1: severity of headache (4-pt scale, 0-no pain, 1-mild, 2-moderate, 3- severe) 2: presence of nausea, vomiting, phonophobia or photophobia, clinical disability, time to "meaningful relief of headache”
Cabarrocas, 2001, Spain, RCT 62 | 120 min, (3–5 d) | G1: ALMO, n=31, 2 mg SC G2: ALMO, n=29, 6 mg SC G3: ALMO, n=31, 10 mg SC P: Placebo, n=32, NR SC | G1: male and female: 39.5, 27 (87.1), NR G2: male: 39.6; female: 39.4, 22 (75.9), NR G3: male: 41.2; female: 40, 25 (80.6), NR P: male: 38.3; female: 41, 26 (81.3), NR | G1: NR, NR G2: NR, NR G3: NR, NR P: NR, NR | 1: pain relief at 2 hr (self-assessed 4-pt scale) 2: pain relief at 1 hr, pain free at 2 hr, use of escape medication, mean time between dosing and end of attack, mean duration of attack
Cady, 1991, U.S., RCT 60 | 120 min, (NA) | G1: SUM, n=187, 6 mg SC P: Placebo, n=370, 0.5 ml SC | G1: NR, NR, NR P: NR, NR, NR | G1: NR, NR P: NR, NR | 1: headache severity (4-pt scale) 2: pain relief, clinical disability, nausea, vomiting, photophobia
Mushet, 1996, U.S., RCT 58 | 120 min, (24 hr) | G1: SUM, n=40+39, 6 mg SC P: Placebo, n=40+39, NR SC | G1: 40.3, 36 (90.0) + 37 (94.9), NR P: 39, 33 (82.5) + 31 (79.5), NR | G1: NR, NR P: NR, NR | 1: headache relief 2: nausea, vomiting, photophobia and phonophobia, clinical disability, meaningful relief of headache, would patient use the medication again to treat migraine, headache relief (reduction in score from 3 or 2 before tx or 1 or 0 at 60 min on 4-pt scale)
Subcutaneous Sumatriptan Study Group, 1991, the Netherlands, RCT116 | 120 min, (24 hr) | G1: SUM, n=423. 6mg SC P: Placebo, n=106, | G1: 41 (11), 344 (81.3), NR P: 39 (11), 88 (80), NR | G1: NR; 425 median (min) P: NR; 357 median (min) | 1: headache relief 2: headache improvement, functional disability and headache recurrence.
Thomson, 1993, New Zealand, RCT59 | 120 min, (24 hr) | G1: SUM, n=28, 4mg SC P: Placebo, n=23, 0.5ml SC | Total: 41, 43 (86.0), NR | G1: 4-pt pain scale:2.2; 7.8 hr (median) P: 4-pt pain scale: 2.2; 5.3 hr (median) | 1: number of patients obtaining headache improvement from severe or moderate grade 3 or 2 to 1 or 0 within 30 min of receiving injection 2: change in nausea, vomiting, photophobia; disability level; rescue medication; recurrence; headache improvement
Wendt, 2006, U.S., RCT 57 | 120 min, (12–24 hr) | G1: SUM, n=384, 0.66ml SC (corresponds with to 4mg) P: Placebo, n=193, 0.66ml SC | G1: 38.3 (9.5), 331 (86.2), White: 366(95.3), Black: 10 (2.6), Other: 8 (2.1) P: 38.1(9.7), 170 (88.1), White: 175 (90.7), Black: 7 (3.6), Asian: 1 (0.5), Other: 10 (5.2) | G1: Severity of pain mild: 3 (0.80), moderate: 179 (46.6), severe: 202 (52.6); at least 72 hr P: Severity of painmild: 2 (1.0), moderate: 99 (51.3), severe: 92 (47.7); at least 72 hr | 1: headache severity (4-pt scale) 2: pain relief, presence or absence of nausea, vomiting or photophobia

ALMO = almotriptan; ED = emergency department; G1 = group 1; G2 = group 2; G3 = group 3; NA = not applicable; NR = not reported; P = placebo; RCT = randomized controlled trial; SC = subcutaneous; SD = standard deviation; SUM = sumatriptan; VAS = visual analogue scale

##### Triptans Versus Placebo

###### Description of Included Studies

Eight RCTs (in seven publications) compared the effectiveness of triptans versus placebo in the treatment of acute migraine.57–60,62,106,116 Most studies were conducted in the ED; one study was conducted in neurology departments, pain clinics, and physicians’ offices.116 One publication reported the results of two separate trials;58 in all metagraphs and analyses these individual trials are labeled as Mushet (1) and Mushet (2). All of the triptans were administered subcutaneously. Six studies evaluated sumatriptan (4–6 mg) and one evaluated almotriptan (2–10 mg).62

Most participants were female. The mean age ranged from 38 and 41 years. Two studies reported the ethnicity of participants.57,58 Six studies evaluated participants at 120 minutes, while in one study patients were assessed at discharge.106 For one study,116 we extracted data for the 60 minute timepoint. In this study patients who still had headache at 60 minutes were randomized to receive either placebo or additional medication. Followup timepoints ranged from 12 hours to 5 days; patients were not contacted following discharge in one study.60 All studies had primary outcomes that were related to pain. Secondary outcomes included nausea, vomiting, disability level, mean duration of migraine attack, headache improvement, functional disability, and headache recurrence.

All RCTs had an unclear risk of bias (Appendix D).57–60,62,106,116

###### Effectiveness Results

###### Headache Relief at 60 Minutes

Five trials reported the number of patients who experienced headache relief at 60 minutes (Figure 24).58,60,62,116 In the four trials involving sumatriptan, the pooled results demonstrated that significantly more patients who received sumatriptan achieved headache relief than those who received placebo (RR = 3.03; 95% CI: 2.59, 3.54, I^2^ = 0%). There was no statistically significant difference between patients who received almotriptan and those who received placebo.62

Figure 24 Headache relief at 60 minutes in trials comparing triptans and placebo

Figure 24 displays a forest plot of studies reporting headache relief at 60 minutes, triptan vs. placebo. Four studies reported headache relief. In the four trials involving sumatriptan, the pooled results demonstrated that significantly more patients who received sumatriptan achieved headache relief than those who received placebo (RR = 3.03, 95% CI: 2.59, 3.54, I2= 0%). Patients who received almotriptan did not have significantly different results compared with those who received a placebo.

###### Headache Relief at 120 Minutes

There were five comparisons that evaluated the number of patients who experienced headache relief at 120 minutes (Figure 25).57,58,62,106 The differences between the triptan and placebo groups were statistically significant for sumatriptan (RR = 2.61; 95% CI: 2.09, 3.26; I^2^ = 21%) and almotriptan (RR = 1.65; 95% CI: 1.15, 2.36).

Figure 25 Headache relief at 120 minutes in trials comparing triptans and placebo

Figure 25 displays a forest plot of studies reporting headache relief at 120 minutes, triptan vs. placebo. Five trials reported this outcome. The difference between the triptan and placebo groups were statistically significant when participants were given sumatriptan (RR = 2.61, 95% CI: 2.09, 3.26, I2 = 21%) or almotriptan (RR = 1.65, 95% CI: 1.15, 2.36).

###### Headache Relief

One study measured headache relief on the VAS (mm) at 30, 60, and 120 minutes.57 A second study measured headache relief at 30 minutes. 59 Patients receiving triptans experienced more relief compared with those receiving placebo. The differences were statistically significant at all timepoints, and the differences increased at each timepoint: 30 minutes—MD = −15.45; 95% CI: −19.49, −11.41(I^2^ = 0%), 60 minutes—MD = −25.0; 95% CI: −29.32, −20.68, and 120 minutes—MD = −30.70; 95% CI: −35.02, −26.38.

###### Pain Free

Six studies measured pain free status at discharge,106 and at 30,^59^ 60,^57,60,62,116^ and 120 minutes.57,60,62 In the studies that compared sumatriptan and placebo,57,59,60,106,116 the pooled results showed a statistically significant difference in favor of sumatriptan (RR = 4.73; 95% CI: 3.77, 5.94, I^2^ = 0%). In the study comparing almotriptan with placebo, there was no statistically significant difference between groups. (Figure 26).

Figure 26 Pain free status in trials comparing triptans and placebo

Figure 26 displays a forest plot of studies reporting being pain free at discharge, triptan vs. placebo. Five studies reported pain free status. In the studies that compared sumatriptan versus placebo, the pooled results showed a significant difference between groups (RR = 4.73: 95% CI: 3.77, 5.94, I2 = 0%).

###### Headache Recurrence

In five comparisons, patients were contacted within 24 hours of discharge to assess recurrence of migraine headache (Figure 27).58,59,106,116 The results were inconsistent across comparisons. A subgroup analysis by study setting (i.e., ED vs. other settings116) reduced the heterogeneity. The four studies that took place in the ED showed statistically significant results in favor of sumatriptan (RR = 0.72; 95% CI: 0.57, 0.90) while the study that took place in neurology departments, pain clinics, and physicians’ offices showed a significant effect in favor of placebo (RR = 2.40; 95% CI: 1.45, 3.97).

Figure 27 Headache recurrence at 24 hours in trials comparing triptans and placebo

Figure 27 displays a forest plot of studies reporting headache recurrence at 24 hours, triptan vs. placebo. Four trials reported this outcome. Two studies showed a significant difference in favor of sumatriptan and the overall pooled estimate favored sumatriptan (RR = 0.72; 95% CI: 0.57, 0.90; I2 = 23%).

###### Functional Disability

One study measured functional disability 60 minutes after injection of sumatripan or placebo.116 Significantly more patients who received sumatriptan experienced an improvement in their ability to function compared with those who received placebo (RR = 5.11; 95% CI: 2.69, 9.70).

###### Nausea

Three comparisons assessed the effectiveness of sumatriptan in decreasing nausea at 60 minutes (Figure 28).58,60 The pooled results demonstrated that sumatriptan significantly decreased nausea (RR = 0.52; 95% CI: 0.45, 0.60; I^2^ = 0%).

Figure 28 Nausea at 60 minutes in trials comparing triptans and placebo

Figure 28 displays a forest plot of studies reporting nausea at 60 minutes, triptan vs. placebo. Three trials reported nausea. All studies favored sumatriptan (RR = 0.52; 95% CI: 0.45, 0.60, I2 = 0%).

###### Vomiting

Two trials58 assessed vomiting after the administration of sumatriptan versus placebo and found no statistically significant difference between groups (RR = 0.33; 95% CI: 0.03, 3.06; I^2^ = 0%).

###### Photophobia

Three trials examined the effect of sumatriptan versus placebo on photophobia.58,60 The pooled results show a significant difference between groups in favor of sumatriptan (RR = 0.57; 95% CI: 0.52, 0.62, I^2^ = 0%).

###### Phonophobia

Three studies compared sumatriptan and placebo and found a significant difference between groups for the occurrence of phonophobia in favor of sumatriptan (RR = 0.57; 95% CI: 0.42, 0.77, I^2^ = 0%).58,60

###### Clinical Disability

Two trials compared clinical disability rates between the sumatriptan and placebo groups at 120 minutes.58 Significantly more patients in the placebo group were still experiencing clinical disability 1 hour after administration of the interventions (RR = 0.38; 95% CI: 0.25, 0.57, I^2^ = 0%).

###### Other Outcomes

One study assessed the difference in time to relief, time to discharge, and headache severity at discharge for participants receiving sumatriptan compared with placebo.106 Each outcome was statistically significant in favor of sumatriptan (MD = −23.0; 95% CI: −36.33, −9.67; MD = −36.0; 95% CI: −53.58; −18.42; MD = −0.80; 95% CI: −1.40, −0.20, respectively).

Another study compared the duration of attack (hours), and time between dosing and attack (hours) for those who were administered almotriptan versus placebo.62 For both outcomes, the differences between groups were not statistically significant.

Patient satisfaction with medication was assessed in two studies58 in which participants were asked if they would “take the injectable form of medication again”. In both studies, significantly more patients who were given sumatriptan responded with “yes, definitely” and “probably” compared with those who were given placebo (RR = 1.53; 95% CI: 1.23, 1.89, I^2^ = 0%).

##### Triptans Versus Active Agents

###### Description of Included Studies

Six studies compared sumatriptan with other active agents. The active agents included prochlorperazine and diphenhydramine,64 metoclopramide,82 chlorpromazine and metoclopramide,32 trimethobenzamide and diphenhydramine,79 DHE,61 and ketorolac.84 These studies are described in other sections of the report (i.e., metoclopramide, neuroleptics, NSAIDs, DHE).

The interventions took place in the ED in all but one study.61 Outcomes were assessed in the ED between 60 and 120 minutes; the post-ED followup, if applicable, occurred at 24 hours. The mean age of the participant groups ranged from 28 to 42 years. Refer to the following tables for details on study and patient characteristics: Table 6 (metoclopramide), Table 9 (neuroleptics), Table 13 (NSAIDs), Table 19 (DHE).

Two studies had low risk of bias,64,79 three had unclear risk of bias,61,82,84 and one32 had high risk of bias (Appendix D).

###### Effectiveness Results

###### Pain Intensity (VAS)

Four studies reported on this outcome (Table 21). Two studies comparing sumatriptan with antiemetics (metoclopramide and trimethobenzamide) found no statistically significant difference. One study comparing a neuroleptic agent and sumatriptan reported a statistically significant difference in favor of the neuroleptic agent. One study comparing NSAIDs and sumatriptan reported a statistically significant difference in favor of NSAIDs.

###### Headache Relief

Headache relief was reported at 1, 2, 3, 4, and 24 hours in one study.61 At both 1 and 2 hours, sumatriptan was more effective than DHE (RR = 0.73; 95% CI: 0.61, 0.86 and RR = 0.86; 95% CI: 0.76, 0.96, respectively). There were no differences at 3 and 4 hour assessments. At 24 hours, DHE was more effective than sumatriptan (RR = 1.17; 95% CI: 1.05, 1.30).

###### Headache Recurrence

One study reported headache recurrence and found a significant difference in favor of DHE versus sumatriptan (RR = 0.39; 95% CI: 0.26, 0.59).61

### Magnesium Sulfate

#### Key Points

- Patients who received MgSO_4_ had greater improvement in pain intensity as measured by the VAS (mm) compared with those receiving placebo based on three RCTs (moderate strength of evidence).
- There was no difference in headache recurrence for patients who received MgSO_4_ compared with those receiving placebo based on two RCTs (low strength of evidence).
- For head to head comparisons, single trials compared MgSO_4_ and other active agents for pain intensity measured by the VAS (insufficient strength of evidence).

#### Results

The results of the studies that assessed magnesium sulfate (MgSO_4_) are summarized below. Table 24, Table 25, and Table 26 provide the results and strength of evidence grades for all key outcomes. See Table 27 for details on study and patient characteristics.

Table 24 Strength of evidence for MgSO_4_ versus placebo

Comparison | Outcome (N Studies; N Patients) | Strength of Evidence Domains | | | | Strength of Evidence
Comparison | Outcome (N Studies; N Patients) | ROB | Consistency | Direct | Precision | Strength of Evidence
MgSO_4_ vs placebo | Pain intensity–VAS (3; 238) | Moderate | Consistent | Direct | Precise | Moderate
MgSO_4_ vs placebo | Pain reduction (2; 72) | Moderate | Inconsistent | Direct | Not pooled | Insufficient
MgSO_4_ vs placebo | Headache recurrence (2; 196) | Moderate | Consistent | Direct | Imprecise | Low
MgSO_4_ vs placebo | Headache response at (60 min) (1; 120) | Moderate | Unknown | Direct | Precise | Insufficient

MgSO_4_ = magnesium sulfate; N = number; ROB = risk of bias; VAS = visual analogue scale

Table 25 Pain response in trials comparing MgSO_4_ and other active agents

Comparison | Study, Year Study Design (# Patients) | Interventions | Risk of Bias | Outcomes | Data Source
Metoclopramide vs. MgSO_4_ | Cete, 2004 RCT (n = 113) | Metoclopramide vs. MgSO_4_ | Low | Pain intensity–VAS: (MD = −5.00; 95% CI: −15.80, 5.80) | Figure 7
Neuroleptic vs. MgSO_4_ | Ginder, 2000 RCT (n=36) | PCZ vs. MgSO_4_ | Low | Pain intensity–VAS: (MD = −23.00; 95% CI: −44.67, −1.33); favors neuroleptic | Figure 11

CI = confidence interval; MD = mean difference; MgSO_4_ = magnesium sulfate; PCZ = prochlorperazine; RCT = randomized controlled trial; VAS = visual analogue scale

Table 26 Strength of evidence for MgSO_4_ versus active agents

Comparison | Outcome (N Studies; N Patients) | Strength of Evidence Domains | | | | Strength of Evidence
Comparison | Outcome (N Studies; N Patients) | ROB | Consistency | Direct | Precision | Strength of Evidence
Metoclopramide vs. MgSO_4_ | Pain intensity–VAS (1; 113) | Low | Unknown | Direct | Imprecise | Insufficient
Prochlorperazine vs. MgSO_4_ | Pain intensity–VAS (1; 36) | Low | Unknown | Direct | Precise | Insufficient

MgSO_4_ = magnesium sulfate; N = number; ROB = risk of bias; VAS = visual analogue scale

Table 27 Patient and study characteristics of trials comparing MgSO_4_ and placebo

Author, Year, Country Study Design | Timepoints Measured in the ED (Post ED Followup) | Intervention, N Randomized, Dosage, Route of Administration | Mean Age (SD), Females (%), White (%) | Description of Migraine Severity: Mean (SD); Duration of Migraine Prior to Coming Into ED | Primary Outcomes; Secondary Outcomes
Bigal,, 2002, Brazil, RCT44 | 60min, (24hr) | G1: MgSO_4_, n=60, 1 g IV P: Placebo, n=60, NR IV | G1: 29.25, n=45, NR P: 27.6, n=37, NR | G!: NR, 4.4 hr P: NR, 3.65hr | 1: pain intensity (10-point VAS) 2: headache response, therapeutic gain, pain recurrence, rescue medication, intensity of adverse events.
Cete, 2004, Turkey, RCT83 | 30min, (24 hr) | G1: MgSO_4_, n=36, 2 g IV P: Placebo, n=40, 100 ml IV | G1: 40 (12), 27 (75.0), NR P: 40 (11), 35 (87.5), NR | G1: VAS: 70 mm (22), NR P: VAS: 69 mm (19), NR | 1: pain intensity at 30 min (VAS) 2: adverse effects, rescue medication, recurrence at 24 hr
Frank, 2004, Canada, RCT 99 | 30 min, (NA) | G1: MgSO_4_, n= 21, NR IV P: Placebo, n=21, NR IV | G1: 36 (8), 15 (71.4), White: 18 (85.7) P: 29(8), 17 (81.0), White: 18 (85.7) | G1: VAS: 80 mm (13), NR P: VAS: 78 mm (16), NR | 1: median difference in VAS pain score 2: changes in nausea, vomiting and photophobia, % patients achieving a 50% reduction in pain, % patients needing rescue medication
Demirkaya, 2001, Turkey, RCT 72 | 120 min, (24hr) | G1: MgSO_4_,, n=15, 1g IV P: Placebo, n=15, 10 ml IV | G1: NR, NR, NR P: NR, NR, NR | G1: NR, NR P: NR, NR | 1: pain intensity (categorized into four groups: 0 = no pain; 1 = mild pain, is not interfering with daily activities; 2 = moderate pain, is affecting daily activities but not hindering them; 3 = severe pain) 2: side effects

ED = emergency department; g = gram(s); G1 = group 1; IV = intravenous; MgSO_4_ = magnesium sulfate; NR = not reported; P = placebo; RCT = randomized controlled trial; SD = standard deviation; VAS = visual analogue scale

##### Magnesium Sulfate Versus Placebo

###### Description of Included Studies

Four RCTs44,72,83,99 assessed the effectiveness of MgSO_4_ compared with placebo. Two studies44,72 were conducted in headache clinics, and two83,99 took place in the ED. The mean age of participant groups ranged from 29 to 40 years. The participants were predominantly female. One study99 reported that participants were predominantly white. All studies reported pain relief or severity as the primary outcome. Timepoints ranged from 20 to 60 minutes. Post-ED followup was 24 hours. Secondary outcomes included headache response, recurrence, use of rescue medication, and adverse effects.

Two studies83,99 had a low risk of bias and two44,72 had an unclear risk of bias (Appendix D).

###### Effectiveness Results

###### Change in Pain Intensity (VAS)

Three studies reported pain intensity using the VAS (mm) (Figure 29).44,83,99 The pooled estimate demonstrated a statistically significant difference in favor of MgSO_4_ (MD = −9.73; 95% CI: −16.75, −2.72; I^2^ = 0%).

Figure 29 Pain intensity (VAS) in trials comparing MgSO_4_ and placebo

VAS = visual analogue scale

Figure 29 displays a forest plot of studies reporting pain intensity using the Visual Analogue Scale, magnesium sulphate vs. placebo. Three studies reported pain intensity. The pooled analysis showed a statistically significant difference favoring magnesium sulphate over placebo (MD = −9.73, 95% CI: −16.75, −2.72; I2 = 0%).

###### Pain Reduction

Two studies reported pain reduction.72,99 The results were inconsistent (Figure 30).

Figure 30 Pain reduction in trials comparing MgSO_4_ and placebo

Figure 30 displays a forest plot of studies reporting pain reduction, magnesium sulphate vs. placebo. Two studies reported pain reduction. One study did show a difference in favor of magnesium sulphate (RR = 10.33; 95% CI: 2.25, 47.53) while the other showed no difference between groups.

###### Headache Recurrence

Two studies44,83 reported headache recurrence. The pooled results showed no significant difference between MgSO_4_ and placebo (RR = 0.68; 95% CI: 0.29, 1.63; I^2^ = 78%).

###### Other Outcomes

One study44 assessed headache response, and use of rescue medications. The results showed significant effect in favor of MgSO_4_ (RR = 2.78; 95% CI: 1.42, 5.44 and RR = 0.65; 95% CI: 0.53, 0.82, respectively).

##### Magnesium Sulfate Versus Active Agents

###### Description of Included Studies

One study compared the effectiveness of MgSO_4_ and prochlorperazine89 and one study compared MgSO_4_ and metoclopramide.83 These studies are described in other sections of the report (metoclopramide; neuroleptics).

In both studies the interventions took place in the ED; outcomes were measured at 30 minutes following the intervention. One study83 also assessed participants at 24 hours post intervention. One study83 reported a mean age of 40 years. See the following tables for details on study and patient characteristics: Table 6 (metoclopramide), Table 9 (neuroleptics).

Both studies had a low risk of bias (Appendix D).

###### Effectiveness Results

Table 25 summarizes results for the studies that compared MgSO_4_ and other active agents. Two studies reported pain intensity (VAS). In one study metoclopramide was more effective than MgSO_4_ and the results were statistically significant. In the other study comparing a neuroleptics agent and MgSO_4_, the results were not statistically significant.

### Antihistamines

#### Key Points

- There was insufficient strength of evidence for improvement in pain intensity as measured by VAS (mm) for patients who received hydroxyzine compared with placebo based on one RCT.

##### Antihistamine Versus Placebo

###### Description of Included Studies

One RCT98 compared the effectiveness of hydroxyzine and placebo in the treatment of acute migraine headache. The study was conducted in the ED. Headache relief measured at 60 minutes was the primary outcome. Post-ED followup occurred at 7 days. No secondary outcomes were reported (Tables 28 and 29). The study had a low risk of bias (Appendix D).

Table 28 Strength of evidence for antihistamine versus placebo

Comparison | Outcome (N Studies; N Patients) | Strength of Evidence Domains | | | | Strength of Evidence
Comparison | Outcome (N Studies; N Patients) | ROB | Consistency | Direct | Precision | Strength of Evidence
Antihistamine vs. placebo | Headache relief–VAS (1; 48) | Low | Unknown | Direct | Imprecise | Insufficient

N = number; ROB = risk of bias; VAS = visual analogue scale

Table 29 Patient and study characteristics of trials comparing antihistamine and placebo

Author, Year, Country Study Design | Timepoints Measured in the ED (Post ED Followup) | Intervention, N Randomized, Dosage, Route of Administration | Mean Age (SD), Females (%), White (%) | Description of Migraine Severity: Mean (SD); Duration of Migraine Prior to Coming Into ED | Primary Outcomes; Secondary Outcomes
Tek, 1987, U.S., RCT98 | 60min, (7d) | G1: HDZ, n=24, 50mg IM P: Placebo, n=24, 2ml IM | G1: NR, NR, NR P: NR, NR, NR | G1: NR, NR P: NR, NR | 1: pain relief (4-pt scale)

ED = emergency department; G1 = group 1; HDZ = hydroxyzine; IM = intramuscular; NR = not reported; P = placebo; pt = point; RCT = randomized controlled trial; SD = standard deviation

###### Effectiveness Results

###### Pain Relief (VAS)

The authors found no statistically significant difference in pain relief comparing hydroxyzine with placebo (MD = 10.40; 95% CI: −7.38, 28.18).98

### Active Combination Therapy Versus Active Therapy

#### Key Points

- For all head to head comparisons single trials compared different combination interventions with other active agents for pain relief (insufficient strength of evidence).
- A post hoc mixed treatment analysis found that combination therapy (metoclopramide plus DHE and prochlorperazine plus DHE) and neuroleptic monotherapy were most effective for pain relief (VAS) (low strength of evidence).

#### Description of Included Studies

Eight RCTs32,86,102,104,107,108,110,113 assessed the effectiveness of two active interventions versus one or more active interventions (Tables 30 and Table 31). None of the trials used the same combination of drugs. The studies were all performed in the ED. The mean age of patient groups ranged from 29 to 43 years. Five trials,32,86,108,110,113 with six separate interventions, reported pain reduction on the VAS (mm) measured between 30 and 120 minutes post-treatment. Two trials104,107 reported headache relief as a dichotomous outcome measured at 30 minutes and 4 hours. Risk of bias was unclear for five trials,86,102,107,108,113 and high for three32,104,110 (Appendix D).

Table 30 Summary of studies reporting active combination therapy versus active therapy for pain reduction (VAS)

Author, Year, Study Design | Intervention | Sample Size | Risk of Bias | Effect Estimate (95% CI) | Strength of Evidence
Belgrade, 1989, RCT110 | MET+DHE vs. BUT | 45 | High | MD = −5.00 (−19.98, 9.98) | Insufficient
Belgrade, 1989, RCT110 | MET+DHE vs. MEP+HDZ | 45 | High | MD = −22.00 (−36.66, −7.34) favors MET+DHE | Insufficient
Callaham,1986, RCT108 | PCZ+DHE vs. PCZ | 34 | Unclear | MD = 5.00 (−18.96, 28.96) | Insufficient
Cicek, 2004, RCT 113 | MET+PET vs. MET | 245 | Unclear | MD = 0.00 (−8.47, 8.47) | Insufficient
Cicek, 2004, RCT113 | MET+PET vs. PET | 98 | Unclear | MD = −10.0 (−19.2, −0.79), favors MET+PET | Insufficient
Corbo, 2001, RCT86 | MET+MgSO_4_ vs MET | 44 | Unclear | MD = 16.00 (−1.58, 33.58) | Insufficient
Edwards, 2001, RCT104 | MET+DHE vs. VAL | 40 | High | RR = 1.10 (0.61,1.99) | Insufficient
Kelly, 1997, RCT32 | MET+CPZ vs MET+SUM | 43 | High | MD = 9.00 (−4.04, 22.04) | Insufficient
Klapper, 1991, RCT102 | MET+DHE vs. KET | 18 | Unclear | MD = −30.0 (−57.72, −2.28); favors MET+DHE] | Insufficient
Klapper, 1989, RCT107 | MET+DHE vs MET+DEX | 20 | Unclear | RR = 0.95 (0.61, 1.49) | Insufficient

BUT = butorphanol; CPZ = chlorpromazine; DEX = dexamethasone; DHE = dihydroergotamine; ED = emergency department; HDZ = hydroxyzine; KET = ketorolac; MD = mean difference; MEP = meperidine; MET = metoclopramide; MgSO_4_ = magnesium sulfate; PET = pethidine; PCZ = prochlorperazine; RCT = randomized controlled trial; RR = risk ratio; SUM = sumatriptan; VAL = valproate; VAS = visual analogue scale

Table 31 Patient and study characteristics of trials comparing active combination therapy and active therapy

Author, Year, Country Study Design | Timepoints Measured in the ED (Post ED Followup) | Intervention, N Randomized, Dosage, Route of Administration | Mean Age (SD), Females (%), White (%) | Description of Migraine Severity: Mean (SD); Duration of Migraine Prior to Coming Into ED | Primary Outcomes; Secondary Outcomes
Cicek, 2004, Turkey, RCT 113 | 45 min, (4 hr) | G1: MET, n=196 (Vascular headache); 140 (tension headache), IM P + MET 10 mg IV G2: MET+PET, n=49, MET 10 mg IV + PET 50 mg IM G3: PET, n=49, IV placebo + PET 50 mg IM P: Placebo, n=48, NR IV/IM | Total: 38.8 (11.1) vascular headache; 42.1 (13.8) for tension headache; mean age of all subjects 40.2 (12.4), 7.1 (female to male ratio for vascular headache), 2.5 (in tension headache group), | G1: NR, NR G2: NR, NR P: NR, NR | 1: pain intensity (VAS) 2: side effects
Corbo, 2001, U.S., RCT 86 | 45 min, (24hr) | G1: MET+MgSO_4_, n=21, 20 mg MET, 2 g MgSO_4_ IV G2: MET + P, n=23, 20 mg IV | G1: 39 (12), 20 (95.2), NR G2: 37 (8), 22 (95.7), NR | G1: VAS: 80 mm (19), NR G2: VAS: 81 mm (23), NR | 1: pain (VAS) 2: % of patients whose pain improved by >/= 50% from BL, percentage of patients with normal functional status at final rating in ED
Callaham, 1986, U.S., RCT108 | 90 min, (24 hr for pain relief and 48 hr for return visits) | G1: DHE+PCZ, n=19, 0.75mg DHE+ 5mg PCZIV P: PCZ+P, n=15, 5mg PCZ + NR IV | G1: NR, NR, NR P: NR, NR, NR | Total: 10-pt scale: 6.3, NR | 1: difference in pain scores (10-pt scale, 10 being the worst) 2: complete pain relief by end of study, optional tx by patient request: additional
Belgrade, 1989, U.S., RCT 110 | 30 min (72 hr) | G1: MEP+HDZ, n=22, 75mg MEP + 50mg HDZIM G2: BUT, n=19, 2mg IM G3: MET, n=23, 1mg DHE + 10mg MET IV | G1: 33 (11), 13 (59.1), NR G2: 29 (9), 11 (57.9), NR G3: 29(8), 13 (61.9), NR | G1: Initial pain score (1–100): 82(18), NR G2: Initial pain score (1–100): 84(11), NR G3: Initial pain score (1–100): 83(19), NR | 1: pain score improvement (scale of 1–100 where 100 is the worst possible pain) 2: blood pressure
Kelly, 1997, Australia and New Zealand, RCT 32 | 120 min, (NA) | G1: CPZ, n=23, 12.5 mg IV G2: SUM, n=20, 6 mg IM | G1: 35 (NR), 17 (73.9), NR G2: 32 (NR), 12 (60.0) NR | G1: VAS: 75.7 (95% CI: 68.8, 82.6), NR G2: VAS: 74.6 (95% CI: 67.3, 81.9), NR | 1: mean pain scores (VAS)
Klapper, 1989, U.S., RCT 107 | 30 min, (24 hr) | G1: MET+ DHE, n=11, 5–10mg MET and 0.75–1.0mg DHE IV G2: MET + DEX, n=9, 5–10mg MET and 6mg DEX IV P: Placebo, n=10, NR IV | G1: NR, NR, NR G2: NR, NR, NR P: NR, NR, NR | G1: NR, NR G2: NR, NR P: NR, NR | 1: improvement by at least one unit (4-pt scale) 2: level of functioning (4-pt scale)
Klapper, 1991, U.S., RCT 102 | 60 min (24 hr) | G1: KET, n=9, 60mg IM G2: DHE + MET, n=9, 1.0 mg DHE + 5mg MET IV | G1: NR, NR, NR G2: NR, NR, NR | G1: NR, NR G2: NR, NR | 1: pain severity (pain severity scale: 0–3 with 3 being severe headache) 2: ability to function
Edwards, 2001, U.S., RCT 104 | 1,2, and 4 hr, 4 hr (24 hr) | G1: MET + DHE, n=20, 10mg MET and 1 mg DHE IV G2: VAL, n=20, 500mg IV | G1: 43 (range 14–71), 18 (90.0), NR G2: 41 (range 14–73), 17 (85.0), NR | G1: Moderate: 8 (40.0), severe: 12 (60.0); 49.2hr (range 24–96), G2: Moderate: 6 (30.0), severe: 14 (70.0); 46.4hr (range 24–75) | 1: headache relief 2: headache-associated nausea, photophobia and phonophobia, recurrence of headache, headache severity

BL = baseline; BUT = Butorphanol; CPZ = Chlorpromazine; DEX = Dexamethasone; DHE = Dihydroergotamine; ED = emergency department; G1 = group 1; G2 = group 2; G3 = group 3; HDZ = hydroxyzine; IM = intramuscular; IV = intravenous; KET = ketorolac; MEP = meperidine; MET = metoclopramide; MgSO_4_ = magnesium sulfate; NR = not reported; P = placebo; PET = pethidine; RCT = randomized controlled trial; SD = standard deviation; SUM = sumatriptan; tx = treatment; VAL = valproate; VAS = visual analogue scale

#### Effectiveness Results

Three interventions102,110,113 showed a statistically significant result that favored metoclopramide plus DHE versus meperidine plus hydroxyzine, metoclopramide plus DHE versus ketorolac monotherapy, and metoclopramide plus pethidine versus pethidine monotherapy (Table 30). The strength of evidence was insufficient for all interventions because results were from single trials.

##### Mixed Treatment Analysis for Pain Relief (VAS)

We conducted a post hoc mixed treatment analysis of 36 studies that reported a pain score (VAS). In addition to neuroleptic agents, metoclopramide, NSAIDs, opioids, DHE, sumatriptan, and orphan agents (i.e., hydroxyzine (Atarax), lidocaine, MgSO_4_, sodium valproate, tramadol, and octreotide), we examined active combination therapy. The combination agents were metoclopramide plus DHE102,110 and prochlorperazine plus DHE.108 The results showed that both combination therapy and neuroleptic agents were most effective in pain relief, with a pain reduction of approximately 40 mm on the VAS (Figure 31). Metoclopramide, NSAIDs, and opioids reduced pain by approximately 24 mm. There were other, albeit less effective agents (e.g., DHE, triptans, and orphan agents) which reduced pain by approximately 12–16 mm. See Appendix F for the network diagram.

Figure 31 Mixed treatment analysis of studies reporting pain score (VAS)

DHE = dihydroergotamine; NSAIDs = nonsteroidal anti-inflammatory drugs; PB = probability; VAS = visual analogue scale

Figure 31 displays a mixed treatment analysis of studies reporting pain score (VAS). The results show that both combination therapy and neuroleptic agents were most effective in pain relief compared to placebo with a pain reduction of approximately 40 mm on the VAS. Metoclopramide, NSAIDs and opioids reduced pain by approximately 24 mm compared to placebo. Less effective agents were DHE, triptans and orphan drugs, which reduced pain by approximately 16-12 mm compared to placebo.

The strength of evidence for the mixed treatment analysis was low. The overall risk of bias for these trials was assessed as moderate and the results were consistent. Since only one or two trials contributed data to some of the network nodes, we downgraded the strength of evidence to low.

## Key Question 2 Effectiveness of Corticosteroids in the Prevention of Migraine Relapse

### Key Points

- Patients receiving dexamethasone plus standard abortive therapy were less likely to report recurrence of pain or headache up to 72 hours after discharge compared with placebo plus standard abortive therapy (moderate strength of evidence).

### Description of Included Studies

Seven studies assessed the effectiveness of corticosteroids compared with placebo in the prevention of migraine relapse.19–21,76,78,103,109 In every study, all patients were given standard abortive therapy after which they were administered either a placebo or intravenous (IV) dexamethasone prior to discharge. In the study by Fiesseler, participants were given either dexamethasone if IV access was obtained or oral prednisone if there was no IV access.103

All trials were conducted in the ED. The mean age of participant groups ranged from 32.6 to 38.0 years. The participants were predominantly female. All studies reported recurrence of headache or persistent pain free status post discharge. Three studies assessed participants at the time of discharge,19,21,78 one assessed patients at 120 minutes after administration of the intervention,20 and two studies did not assess patients in the ED.103,109 One study contacted patients at 3 and 30 days post discharge,76 and another assessed patients at 7 days after discharge.21 The post-ED followup timepoints for the remaining studies ranged from 24 to 72 hours. See Table 32 and Table 33 for strength of evidence grades and study and patient characteristics, respectively.

Table 32 Strength of evidence for corticosteroid versus placebo in prevention of headache recurrence

Comparison | Outcome (N Studies; N Patients) | Strength of Evidence Domains | | | | Strength of Evidence
Comparison | Outcome (N Studies; N Patients) | ROB | Consistency | Direct | Precision | Strength of Evidence
Corticosteroid vs. placebo | Headache recurrence at 24–72 hr (7; 801) | Moderate | Consistent | Direct | Precise | Moderate
Corticosteroid vs. placebo | Headache recurrence at 7 days (1; 126) | Moderate | Unknown | Direct | Imprecise | Insufficient
Corticosteroid vs. placebo | Headache recurrence at 30 days (1; 98) | Moderate | Unknown | Direct | Imprecise | Insufficient

N = number; ROB = risk of bias

Table 33 Patient and study characteristics of trials comparing corticosteroid and placebo

Author, Year, Country Study Design | Timepoints Measured in the ED (Post ED Followup) | Intervention, N Randomized, Dosage, Route of Administration | Mean Age (SD), Females (%), White (%) | Description of Migraine Severity: Mean (SD); Duration of Migraine Prior to Coming Into ED | Primary Outcomes; Secondary Outcomes
Baden, 2006, U.S., RCT78 | before ED discharge, (48–72 hr) | G1: DEX, n=57 (total), 10 mg/ml IV P: Placebo, n=NR, 1 ml IV | G1: 34.5 (12.6), 18 (58.1), NR P: 32.6 (13.0), 17 (70.8), NR | G1: VAS: 75.0 mm (17.5), NR P: VAS: 77.3 mm (19.5), NR | 1: recurrence of headache at 48–72 hr 2: headache severity at 48–72 hr, adverse events
Donaldson, 2008, U.S., RCT76 | 3 d, (30 d) | G1: DEX, n=62, 24 mg IV P: Placebo, n=53, NR IV | G1: 37.48, 54 (87.1), NR P: 35.17, 39 (73.6), NR | G1: 10-pt scale: 8.89, NR P: 10-pt scale: 8.76, NR | 1: recurrence of headache at 3 and 30 d (4-pt ordinal scale: 0=no disability, 1=mild impairment, 2=moderate impairment, 3=severe impairment) 2: headache resolving in ED, satisfaction with ED visit, ED tx (medication received)
Fiesseler, 2009, U.S., RCT103 | None in ED, (24–72 hr) | G1: DEX, n=48, 10mg IV P: Placebo, n=87, 1 ml IV | G1: 37 (10), 82 (87.2); Caucasian: 61 (64.9), Hispanic: 14 (14.9), Black: 8 (8.5), Asian: 4 (4.3), Other: 1 (1.1) P: 38 (10), 74 (85.1); Caucasian: 46 (52.9), Hispanic: 17 (19.5), Black: 9 (10.3), Asian: 2 (2.3), Other: 2 (2.3) | G1: VAS: 8.9, NR P: VAS: 8.9, NR | 1: resolution of headache recurrence of symptoms after discharge 2: use of rescue medication, recurrence of headache (score of at least 2 on the Likert pain scale), resolution of headache (score of 0 on the Likert pain scale)
Friedman, 2007, U.S., RCT20 | 120 min, (24 hr) | G1: DEX, n=106, 10 mg IV P: Placebo, n=99, 10 mg IV | G1: 36 (10), 87 (82.1); Latino: 72 (67.9), Black: 28 (26.4); White: 6 (5.7) P: 37 (11), 87 (87.9); Latino: 68 (68.7) Black: 21 (21.2); White: 2 (2.0) | G1: pain intensity (%): mild- 11, moderate- 25, severe- 64; 48 hr P: pain intensity (%): mild- 4, moderate- 28, severe- 68; 48 hr | 1: persistent pain-free (4-pt scale) 2: no functional impairment after discharge, satisfaction with medication, pain-free at discharge, no functional impairment at discharge, adverse effects
Innes, 1999, Canada, RCT19 | At discharge (results not reported by group), (48 hr) | G1: DEX, n=49, 24mg IV P: Placebo, n=49, NR IV | G1: 34 (9.9), 36 (73.5), NR P: 36 (8.6), 42 (85.7), NR | G1: VAS: 83 mm (IQR: 75–94), median: 12 hr (IQR: 5–28) P: VAS: 84 mm (IQR: 76–93), median: 11 hr (IQR: 6–30) | 1: severe recurrent headache that provoked another physician visit or precluded normal activity (recurrent headaches classified as: class A severe, provoking another physician visit; class B severe, interfering with daily activity but not provoking a physician visit; class C mild requiring self-medication but not limiting activity; class D mild requiring no tx)
Jones, 2003, U.S., RCT109 | None in ED, (48 hr) | G1: DEX, n=34, 20mg/2ml IV/IM P: Placebo, n=36, NR | G1: 35 (8.3), 27 (79.4), White: 30 (88.2) P: 36 (7.9), 28 (77.8), White: 31 (86.1) | G1: VAS score: 90mm, 39 (38) hr, NR P: VAS score: 88 mm, 37 (31) hr, | 1: headache recurrence (4 class scale: A. Severe; provoked a repeat physician visit, B. Severe; precluded normal activity, C. Mild; analgesic necessary but no activity limitation, D. Mild; no treatment necessary, E. none) 2: adverse events
Rowe, 2007, Canada, RCT21 | Prior to discharge from ED, (7 d) | G1: DEX, n=64 (total), 15 mg IV P: Placebo, n=62, NR IV | G1: 35 (11), 51 (80.0), NR P: 34.6 (10), 51 (82.3), NR | G1: VAS (median): 8, duration of headache >1day: 32/64 P: VAS (median): 8, duration of headache >1 day: 32/62 | 1: recurrence of pain at 72 hr (VAS) 2: recurrence of pain at 7 d (VAS)

DEX = dexamethasone; ED = emergency department; G1 = group 1; IM = intramuscular; IV = intravenous; N = number; NR = not reported; P = placebo; RCT = randomized controlled trial; SD = standard deviation; VAS = visual analogue scale

Three studies had an unclear risk of bias,21,76,78,109 and four studies19,20,78,103 had a low risk of bias (Appendix D).

### Effectiveness Results

#### Headache Recurrence (24–72 hours)

We used the authors’ definitions of recurrence. In two studies,19,109 recurrence was classified by severity of headache pain. For these studies, we extracted data for patients who reported severe headache (defined as having provoked a repeat physician visit and precluded return to normal activity). All studies reported on recurrence of pain or headache between 24 and 72 hours after discharge from the ED (Figure 32). The pooled results were statistically significant in favor of the corticosteroids (RR = 0.68; 95% CI: 0.49, 0.96; I^2^ = 63%). Some of the heterogeneity resulted from the study by Baden, et al.,78 which was stopped early for benefit.

Figure 32 Recurrence of pain/headache (24–72 hours) in trials comparing dexamethasone and placebo

Figure 32 displays a forest plot of studies reporting recurrence of pain/headache between 24–72 hours, corticosteroids vs. placebo. The pooled results were statistically significant in favor of the corticosteroids (RR = 0.68, 95% CI: 0.49, 0.96, I2 = 63%).

We conducted a post hoc subgroup analysis to investigate differences in headache recurrence based on dosage of dexamethasone. Studies that used less than 15 mg (n = 4) of dexamethasone reported a similar treatment effect (RR = 0.69; 95% CI: 0.40, 1.18; I^2^ = 65%) to those using 15 mg or more (RR = 0.65; 95% CI: 0.43 to 0.99; I^2^ = 37%). The difference between these two subgroups was not significant (χ2 = 2.01; df=1; p=0.16).

#### Severe Headaches (48–72 hours)

In one study, participants were contacted to determine whether the occurrence of severe headaches differed between those who received dexamethasone and those who received placebo.78 Fewer people in the dexamethasone group had severe headaches; however, the results were not statistically significant (RR = 0.39; 95% CI: 0.13, 1.13).

#### Recurrence of Pain (7 days)

One study looked at recurrence of pain at 7 days.21 While more individuals in the placebo group reported recurrent headache, the results were not statistically significant (RR = 0.70; 95% CI: 0.43, 1.14).

#### Recurrence of Pain (30 days)

One study compared headache recurrence at 30 days and found no statistically significant difference between dexamethasone and placebo (RR = 0.90; 95% CI: 0.58, 1.41).76

## Key Question 3 Short-Term Adverse Effects of Parenteral Pharmacological Interventions

### Key Points

- No two studies reported the same adverse effects for the same pair of interventions. The strength of evidence is insufficient to conclude which active treatment for acute migraine results in more or less adverse effects
- Adverse effects were examined for individual arms of the trials and rates of adverse effects reported. Strength of evidence was not graded for these comparisons.
- All reported adverse effects were considered minor and self-limiting.
- The risk of experiencing sedation following administration of metoclopramide and neuroleptic agents was common.
- Short-term side effects were commonly reported for patients receiving DHE. The most common side effects were skin and local reactions, sedation, digestive problems, nausea or vomiting, and chest symptoms.
- MgSO_4_ was associated with high rates of skin flushing and local reactions.
- Adverse effects for triptans were infrequently reported; the most common adverse effect was local reactions.
- There were few short-term side effects reported for NSAIDs and opioids.

This section addresses the short-term adverse effects of parenteral pharmacological interventions used to treat acute migraine headaches. Reporting of adverse effects was inconsistent across this body of evidence. As a result, no two studies reported the same adverse effects for the same pair of interventions. The strength of evidence is insufficient to conclude which active treatment for acute migraine results in more or less adverse effects.

As a post hoc analysis we analyzed adverse effects for individual arms of the trials. The results are presented by adverse effect categories (e.g., sedation, dizziness, vomiting). When an intervention had more than one study reporting on any adverse effect, the results were pooled using a standard inverse variance random effects meta-analysis. For this reason, the proportion calculated by simply pooling the data may not be identical to the point estimate computed from the meta-analysis.

#### Nausea or Vomiting

There were 26 unique studies that reported on the rates of vomiting, nausea, and emesis (Figure 33, Table 34).21,32,43,53,57,58,60,61,63,65–67,75,76,79,81,91,94,98,100,101,104,106,109,110,113 When participants took the placebo, the risk of vomiting or experiencing nausea and emesis was 11 percent (95% CI: 6 to 14 percent). The risk for active agents ranged from 0 percent (95% CI: 0 to 4 percent) to 57 percent (95% CI: 41 to 72 percent).

Figure 33 Risk of nausea or vomiting reported in acute migraine trials

Figure 33 displays a graph of the risk of nausea/vomiting across interventions. There were 22 different drug combinations, as well as placebo, that were associated with nausea and vomiting. The lowest risks were seen in chlorpromazine and droperidol while the highest risks were seen in prochlorperazine and promethazine.

Table 34 Vomiting, nausea, emesis reported in acute migraine trials

Intervention | Author, Year | n/N | Risk (95% CI)
Placebo | Cicek, 2004^113^ | 5/83 | 0.06 [0.03, 0.13]
Placebo | Tek, 1987^98^ | 2/24 | 0.08, 0.02, 0.26]
Placebo | Krymchantowski, 2003^100^ | 1/12 | 0.08 [0.01, 0.35]
Placebo | Wendt, 2006^57^ | 15/193 | 0.08 [0.05, 0.12]
Placebo | Bigal, 2002^43^ | 10/30 | 0.33 [0.17, 0.51]
Placebo | Mushet, 1996^58^ | 11/79 | 0.14 [0.08, 0.23]
Placebo | Cady, 1991^60^ | 52/370 | 0.14 [0.11, 0.18]
Placebo | Silberstein, 2003^63^ | 3/61 | 0.05 [0.02, 0.14]
Placebo | Subtotal N=8 | 99/852 | 0.11 [0.06, 0.14]
Butorphanol | Belgrade, 1989^110^ | 5/19 | 0.26 [0.12, 0.49]
Butorphanol | Subtotal N=1 | 5/19 | 0.26 [0.12, 0.49]
Chlorpromazine | Cameron, 1995^65^ | 1/47 | 0.02 [0.00, 0.11]
Chlorpromazine | Lane, 1989^67^ | 2/24 | 0.08 [0.02, 0.26]
Chlorpromazine | Bigal, 2002^43^ | 1/30 | 0.03 [0.01, 0.17]
Chlorpromazine | Subtotal N=3 | 4/101 | 0.03 [0.00, 0.07]
Standard abortive therapy plus dexamethasone | Rowe, 2008^21^ | 4/64 | 0.06 [0.02, 0.15]
Standard abortive therapy plus dexamethasone | Donaldson, 2008^76^ | 9/57 | 0.16 [0.09, 0.27]
Standard abortive therapy plus dexamethasone | Jones, 2003^109^ | 2/34 | 0.06 [0.02, 0.19]
Standard abortive therapy plus dexamethasone | Subtotal N=3 | 15/155 | 0.09 [0.03, 0.14]
DHE | Carleton, 1998^53^ | 8/85 | 0.09 [0.05, 0.17]
DHE | Belgrade, 1989^110^ | 7/21 | 0.33 [0.17, 0.55]
DHE | Winner, 1996^61^ | 8/152 | 0.05 [0.03, 0.10]
DHE | Subtotal N=3 | 23/258 | 0.11 [0.02, 0.20]
Diclofenac | Engindeniz, 2005^81^ | 5/24 | 0.21 [0.09, 0.40]
Diclofenac | Subtotal N=1 | 5/24 | 0.21 [0.09, 0.40]
Droperidol | Silberstein, 2003^63^ | 0/61 | 0.00 [0.00, 0.04]
Droperidol | Subtotal N=1 | 0/61 | 0.00 [0.00, 0.04]
Hydroxyzine | Tek, 1987^98^ | 1/23 | 0.04 [0.01, 0.21]
Hydroxyzine | Subtotal N=1 | 1/23 | 0.04 [0.01, 0.21]
Ketorolac | Duarte, 1992^94^ | 3/25 | 0.12 [0.04, 0.30]
Ketorolac | Larkin, 1992^101^ | 1/15 | 0.07 [0.01, 0.30]
Ketorolac | Subtotal N=2 | 4/40 | 0.10 [0.00, 0.19]
Meperidine | Carleton, 1998^53^ | 20/85 | 0.24 [0.16, 0.34]
Meperidine | Larkin, 1992^101^ | 1/16 | 0.06 [0.01, 0.28]
Meperidine | Belgrade, 1989^110^ | 1/22 | 0.05 [0.01, 0.22]
Meperidine | Subtotal N=3 | 22/123 | 0.12 [0.00, 0.25]
Meperidine plus antihistiamine | Duarte, 1992^94^ | 4/25 | 0.16 [0.06, 0.35]
Meperidine plus antihistiamine | Lane, 1989^67^ | 2/22 | 0.09 [0.03, 0.28]
Meperidine plus antihistiamine | Stiell, 1991^66^ | 10/37 | 0.27 [0.15, 0.43]
Meperidine plus antihistiamine | Subtotal N=3 | 16/84 | 0.17 [0.07, 0.28]
Methotrimeprazine | Stiell, 1991^66^ | 8/37 | 0.22 [0.11, 0.37]
Methotrimeprazine | Subtotal N=1 | 8/37 | 0.22 [0.11, 0.37]
Metoclopramide | Cicek, 2004^113^ | 6/85 | 0.07 [0.03, 0.15]
Metoclopramide | Jones, 1996^91^ | 11/29 | 0.38 [0.23, 0.56]
Metoclopramide | Cameron, 1995^65^ | 1/44 | 0.02 [0.00, 0.12]
Metoclopramide | Subtotal N=3 | 18/158 | 0.13 [0.00, 0.25]
Metoclopramide plus pethidine | Cicek, 2004^113^ | 11/84 | 0.13 [0.07, 0.22]
Metoclopramide plus pethidine | Subtotal N=1 | 11/84 | 0.13 [0.07, 0.22]
Metoclopramide plus DHE | Edwards, 2001^104^ | 7/20 | 0.35 [0.18, 0.57]
Metoclopramide plus DHE | Subtotal N=1 | 7/20 | 0.35 [0.18, 0.57]
Nalbuphine | Tek, 1987^98^ | 6/23 | 0.26 [0.13, 0.46]
Nalbuphine | Subtotal N=1 | 6/23 | 0.26 [0.13, 0.46]
Nalbuphine plus hydroxyzine | Tek, 1987^98^ | 5/24 | 0.21 [0.09, 0.40]
Nalbuphine plus hydroxyzine | Subtotal N=1 | 5/24 | 0.21 [0.09, 0.40]
Prochlorperazine | Callan, 2008^75^ | 17/35 | 0.49 [0.33, 0.64]
Prochlorperazine | Jones, 1996^91^ | 14/28 | 0.50 [0.33, 0.67]
Prochlorperazine | Subtotal N=2 | 31/63 | 0.49 [0.38, 0.61]
Promethazine | Callan, 2008^75^ | 20/35 | 0.57 [0.41, 0.72]
Promethazine | Subtotal N=1 | 20/35 | 0.57 [0.41, 0.72]
Sumatriptan | Friedman, 2006^79^ | 6/20 | 0.30 [0.15, 0.52]
Sumatriptan | Kelly, 1997^32^ | 1/20 | 0.05 [0.01, 0.24]
Sumatriptan | Wendt, 2006^57^ | 28/384 | 0.07 [0.05, 0.10]
Sumatriptan | Mushet, 1996^58^ | 10/79 | 0.13 [0.07, 0.22]
Sumatriptan | Akpunonu, 1995^106^ | 8/88 | 0.09 [0.05, 0.17]
Sumatriptan | Cady, 1991^60^ | 68/547 | 0.12 [0.10, 0.15]
Sumatriptan | Winner, 1996^61^ | 6/158 | 0.04 [0.02, 0.08]
Sumatriptan | Subtotal N=7 | 127/1296 | 0.09 [0.05, 0.13]
Tramadol | Engindeniz, 2005^81^ | 7/23 | 0.30 [0.16, 0.51]
Tramadol | Subtotal N=1 | 7/23 | 0.30 [0.16, 0.51]
Trimethobenzamide plus DHE | Friedman, 2006^79^ | 1/20 | 0.05 [0.01, 0.24]
Trimethobenzamide plus DHE | Subtotal N=1 | 1/20 | 0.05 [0.01, 0.24]
Valproate | Edwards, 2001^104^ | 6/20 | 0.30 [0.15, 0.52]
Valproate | Subtotal N=1 | 6/20 | 0.30 [0.15, 0.52]

CI = confidence interval; DHE = dihydroergotamine; N = number

#### Sedation or Somnolence

There were 25 studies that reported the development of sedation or somnolence including drowsiness and decreased levels of consciousness (Figure 34, Table 35).19,20,22,43,53,57,60,65–68,75,79,85–87,91,94,97,98,101,109,110,113 The risk of developing sedation or somnolence as a result of taking placebo was 8 percent (95% CI: 3 to 12 percent). The risk associated with active agents ranged from 3 percent (95% CI: 2 to 4 percent) to 84 percent (95% CI: 69 to 92 percent). The risk of experiencing sedation following administration of metoclopramide and prochlorperazine was common (17 percent each).

Figure 34 Risk of sedation reported in migraine trials

Figure 34 displays a graph of the risk of sedation across interventions. There were 18 different drug combinations, as well as placebo, that were associated with sedation. The lowest risks were seen in sumatriptan and metoclopramide plus magnesium sulphate, while the highest risks were seen in promethazine and methotrimeprazine.

Table 35 Sedation/somnolence reported in acute migraine trials

Intervention | Author, Year | n/N | Risk (95% CI)
Placebo | Cicek, 2004^113^ | 4/83 | 0.05 [0.02, 0.12]
Placebo | McEwen, 1987^97^ | 6/17 | 0.35 [0.17, 0.59]
Placebo | Tek, 1987^98^ | 4/24 | 0.17 [0.07, 0.36]
Placebo | Wendt, 2006^57^ | 4/193 | 0.02 [0.01, 0.05]
Placebo | Cady, 1991^60^ | 8/370 | 0.02 [0.01, 0.04]
Placebo | Jones, 2003^109^ | 4/36 | 0.11 [0.04, 0.25]
Placebo | Silberstein, 2003^63^ | 5/61 | 0.08 [0.04, 0.18]
Placebo | Subtotal N=7 | 35/784 | 0.05 [0.02, 0.09]
Chlorpromazine | Cameron, 1995^65^ | 8/47 | 0.17 [0.09, 0.30]
Chlorpromazine | Lane, 1989^67^ | 5/24 | 0.21 [0.09, 0.40]
Chlorpromazine | McEwen, 1987^97^ | 15/19 | 0.79 [0.57, 0.91]
Chlorpromazine | Subtotal N=3 | 28/90 | 0.38 [0.03, 0.74]
Standard abortive therapy plus Dexamethasone | Friedman, 2007^20^ | 3/106 | 0.03 [0.01, 0.08]
Standard abortive therapy plus Dexamethasone | Innes, 1999^19^ | 12/49 | 0.24 [0.15, 0.38]
Standard abortive therapy plus Dexamethasone | Jones, 2003^109^ | 6/34 | 0.18 [0.08, 0.34]
Standard abortive therapy plus Dexamethasone | Subtotal N=3 | 21/189 | 0.14 [0.00, 0.29]
DHE | Carleton, 1998^53^ | 17/85 | 0.20 [0.13, 0.30]
DHE | Subtotal N=1 | 17/85 | 0.20 [0.13, 0.30]
Droperidol | Silberstein, 2003^63^ | 12/61
Droperidol | Richman, 2002^85^ | 1/15 | 0.07 [0.01, 0.30]
Droperidol | Miner, 2001^87^ | 7/82 | 0.09 [0.04, 0.17]
Droperidol | Subtotal N=3 | 20/158 | 0.12 [0.04, 0.20]
Hydroxyzine | Tek, 1987^98^ | 9/23 | 0.39 [0.22, 0.59]
Hydroxyzine | Subtotal N=1 | 9/23 | 0.39 [0.22, 0.59]
Ketorolac | Duarte, 1992^94^ | 2/25 | 0.08 [0.02, 0.25]
Ketorolac | Larkin, 1992^101^ | 3/15 | 0.20 [0.07, 0.45]
Ketorolac | Subtotal N=2 | 5/40 | 0.11 [0.01, 0.22]
Meperidine | Richman, 2002^85^ | 2/14 | 0.14 [0.04, 0.40]
Meperidine | Carleton, 1998^53^ | 23/85 | 0.27 [0.19, 0.37]
Meperidine | Larkin, 1992^101^ | 2/16 | 0.13 [0.03, 0.36]
Meperidine | Belgrade, 1989^110^ | 4/22 | 0.18 [0.07, 0.39]
Meperidine | Cicek, 2004 (Pethidine)113 | 22/84 | 0.26 [0.18, 0.36]
Meperidine | Subtotal N=5 | 53/221 | 0.23 [0.17, 0.28]
Meperidine plus Antihistiamine | Duarte, 1992^94^ | 7/25 | 0.28 [0.14, 0.48]
Meperidine plus Antihistiamine | Stiell, 1991^66^ | 24/37 | 0.65 [0.49, 0.78]
Meperidine plus Antihistiamine | Lane, 1989^67^ | 4/22 | 0.18 [0.07, 0.39]
Meperidine plus Antihistiamine | Subtotal N=3 | 35/84 | 0.37 [0.08, 0.66]
Methotrimeprazine | Stiell, 1991^66^ | 31/37 | 0.84 [0.69, 0.92]
Methotrimeprazine | Subtotal N=1 | 31/37 | 0.84 [0.69, 0.92]
Metoclopramide | Friedman, 2008^22^ | 5/38 | 0.13 [0.06, 0.27]
Metoclopramide | Cicek, 2004^113^ | 17/85 | 0.20 [0.13, 0.30]
Metoclopramide | Jones, 1996^91^ | 5/29 | 0.17 [0.08, 0.35]
Metoclopramide | Cameron, 1995^65^ | 7/44 | 0.16 [0.08, 0.29]
Metoclopramide | Subtotal N=4 | 34/196 | 0.17 [0.12, 0.22]
Metoclopramide plus Pethidine | Cicek, 2004^113^ | 27/84 | 0.32 [0.23, 0.43]
Metoclopramide plus Pethidine | Subtotal N=1 | 27/84 | 0.32 [0.23, 0.43]
Metoclopramide plus MgSO _ 4 _ | Corbo, 2001^86^ | 1/21 | 0.05 [0.01, 0.23]
Metoclopramide plus MgSO _ 4 _ | Subtotal N=1 | 1/21 | 0.05 [0.01, 0.23]
Nalbuphine | Tek, 1987^98^ | 14/23 | 0.61 [0.41, 0.78]
Nalbuphine | Subtotal N=1 | 14/23 | 0.61 [0.41, 0.78]
Nalbuphine plus Hydroxyzine | Tek, 1987^98^ | 14/24 | 0.58 [0.39, 0.76]
Nalbuphine plus Hydroxyzine | Subtotal N=1 | 14/24 | 0.58 [0.39, 0.76]
Prochlorperazine | Callan, 2008^75^ | 14/35 | 0.40 [0.26, 0.56]
Prochlorperazine | Friedman, 2008^22^ | 6/39 | 0.15 [0.07, 0.30]
Prochlorperazine | Miner, 2001^87^ | 1/86 | 0.01 [0.00, 0.06]
Prochlorperazine | Jones, 1996^91^ | 5/28 | 0.18 [0.08, 0.36]
Prochlorperazine | Jones, 1989^68^ | 7/42 | 0.17 [0.08, 0.31]
Prochlorperazine | Subtotal N=5 | 33/230 | 0.17 [0.04, 0.30]
Promethazine | Callan, 2008^75^ | 25/35 | 0.66 [0.49, 0.79]
Promethazine | Subtotal N=1 | 25/35 | 0.66 [0.49, 0.79]
Sumatriptan | Friedman, 2006^79^ | 2/20 | 0.10 [0.03, 0.30]
Sumatriptan | Wendt, 2006^57^ | 11/384 | 0.03 [0.02, 0.05]
Sumatriptan | Cady, 1991^60^ | 15/547 | 0.03 [0.02, 0.04]
Sumatriptan | Subtotal N=3 | 28/951 | 0.03 [0.02, 0.04]
Trimethobenzamide plus DHE | Friedman, 2006^79^ | 2/20 | 0.10 [0.03, 0.30]
Trimethobenzamide plus DHE | Subtotal N=1 | 2/20 | 0.10 [0.03, 0.30]

CI = confidence interval; DHE = dihydroergotamine; MgSO_4_ = magnesium sulfate; N = number

#### Dizziness

Twenty-three studies reported dizziness as an adverse effect. Included in this category is postural hypertension, syncope, relative hypotension, orthostatic hypotension, fainting, head rushes and dizzy spells (Figure 35, Table 36).19,20,22,43,53,57,58,60,65–68,72,76,86,97,98,100,106,109,110,113 The risk of becoming dizzy in those who received placebo was 5 percent (95% CI: 2 to 8 percent). The risk in those who received an active agent ranged from 2 percent (95% CI: 1 to 8 percent) to 80 percent (95% CI: 63 to 91 percent).

Figure 35 Risk of dizziness reported in acute migraine trials

Figure 35 displays a graph of the risk of dizziness across interventions. There were 17 different drug combinations, as well as placebo, that were associated with dizziness. The lowest risks were seen in DHE and prochlorperazine, while the highest risks were seen in methotrimeprazine and chlorpromazine.

Table 36 Dizziness reported in acute migraine trials

Intervention | Author, Year | n/N | Risk (95% CI)
Placebo | Cicek, 2004^113^ | 1/83 | 0.01 [0.00, 0.07]
Placebo | McEwen, 1987^97^ | 3/17 | 0.18 [0.06, 0.41]
Placebo | Krymchantowski, 2003^100^ | 1/12 | 0.08 [0.01, 0.35]
Placebo | Wendt, 2006^57^ | 10/193 | 0.05 [0.03, 0.09]
Placebo | Bigal, 2002^43^ | 10/30 | 0.33 [0.19, 0.51]
Placebo | Mushet, 1996^58^ | 2/79 | 0.03 [0.01, 0.09]
Placebo | Cady, 1991^60^ | 15/370 | 0.04 [0.02, 0.07]
Placebo | Silberstein, 2003^63^ | 3/61 | 0.05 [0.02, 0.14]
Placebo | Subtotal N=8 | 36/845 | 0.05 [0.02, 0.08]
Butorphanol | Belgrade, 1989^110^ | 4/19 | 0.21 [0.09, 0.43]
Butorphanol | Subtotal N=1 | 4/19 | 0.21 [0.09, 0.43]
Chlorpromazine | Bigal, 2002^43^ | 24/30 | 0.80 [0.63, 0.91]
Chlorpromazine | Subtotal N=1 | 24/30 | 0.80 [0.63, 0.91]
Standard abortive therapy plus dexamethasone | Donaldson, 2008^76^ | 9/57 | 0.16 [0.09, 0.43]
Standard abortive therapy plus dexamethasone | Friedman, 2007^20^ | 3/106 | 0.03 [0.01, 0.08]
Standard abortive therapy plus dexamethasone | Innes, 1999^19^ | 2/49 | 0.04 [0.01, 0.14]
Standard abortive therapy plus dexamethasone | Jones, 2003^109^ | 1/34 | 0.03 [0.01, 0.15]
Standard abortive therapy plus dexamethasone | Subtotal N=4 | 15/246 | 0.05 [0.01, 0.10]
DHE | Carleton, 1998^53^ | 2/85 | 0.02 [0.01, 0.08]
DHE | Subtotal N=1 | 2/85 | 0.02 [0.01, 0.08]
Droperidol | Silberstein, 2003^63^ | 3/61 | 0.05 [0.02, 0.14]
Droperidol | Subtotal N=1 | 3/61 | 0.05 [0.02, 0.14]
Lysine clonixinate | Krymchantowski, 2003^100^ | 1/17 | 0.06 [0.01, 0.27]
Lysine clonixinate | Subtotal N=1 | 1/17 | 0.06 [0.01, 0.27]
Meperidine | Carleton, 1998^53^ | 13/85 | 0.15 [0.09, 0.24]
Meperidine | Belgrade, 1989^110^ | 1/22 | 0.05 [0.01, 0.22]
Meperidine | Subtotal N=2 | 14/107 | 0.11 [0.00, 0.21]
Meperidine plus Antihistamine | Stiell, 1991^66^ | 11/37 | 0.30 [0.17, 0.46]
Meperidine plus Antihistamine | Lane, 1989^67^ | 1/22 | 0.05 [0.01, 0.22]
Meperidine plus Antihistamine | Subtotal N=2 | 12/59 | 0.17 [0.00, 0.41]
Methotrimeprazine | Stiell, 1991^66^ | 12/37 | 0.32 [0.20, 0.49]
Methotrimeprazine | Subtotal N=1 | 12/37 | 0.32 [0.20, 0.49]
Metoclopramide | Friedman, 2008^22^ | 2/38 | 0.05 [0.01, 0.17]
Metoclopramide | Cicek, 2004^113^ | 3/85 | 0.04 [0.01, 0.10]
Metoclopramide | Corbo, 2001^86^ | 1/23 | 0.04 [0.01, 0.21]
Metoclopramide | Cameron, 1995^65^ | 4/44 | 0.09 [0.04, 0.21]
Metoclopramide | Subtotal N=4 | 10/190 | 0.05 [0.01, 0.08]
Metoclopramide plus pethidine | Cicek, 2004^113^ | 17/84 | 0.20 [0.13, 0.30]
Metoclopramide plus pethidine | Subtotal N=1 | 17/84 | 0.20 [0.13, 0.30]
Metoclopramide plus MgSO _ 4 _ | Corbo, 2001^86^ | 2/21 | 0.10 [0.03, 0.29]
Metoclopramide plus MgSO _ 4 _ | Subtotal N=1 | 2/21 | 0.10 [0.03, 0.29]
MgSO _ 4 _ | Demirkaya, 2001^72^ | 3/15 | 0.20 [0.07, 0.45]
MgSO _ 4 _ | Subtotal N=1 | 3/15 | 0.20 [0.07, 0.45]
Nalbuphine | Tek, 1987^98^ | 3/23 | 0.13 [0.05, 0.32]
Nalbuphine | Subtotal N=1 | 3/23 | 0.13 [0.05, 0.32]
Nalbuphine plus hydroxyzine | Tek, 1987^98^ | 1/24 | 0.04 [0.01, 0.20]
Nalbuphine plus hydroxyzine | Subtotal N=1 | 1/24 | 0.04 [0.01, 0.20]
Prochlorperazine | Jones, 1989^68^ | 1/42 | 0.02 [0.00, 0.12]
Prochlorperazine | Subtotal N=1 | 1/42 | 0.02 [0.00, 0.12]
Sumatriptan | Wendt, 2006^57^ | 40/384 | 0.10 [0.08, 0.14]
Sumatriptan | Mushet, 1996^58^ | 3/79 | 0.04 [0.01, 0.11]
Sumatriptan | Akpunonu, 1995^106^ | 8/88 | 0.09 [0.05, 0.17]
Sumatriptan | Cady, 1991^60^ | 65/547 | 0.12 [0.09, 0.15]
Sumatriptan | Subtotal N=4 | 116/1098 | 0.09 [0.06, 0.12]

CI = confidence interval; DHE = dihydroergotamine; MgSO_4_ = magnesium sulfate; N = number

#### Local Reaction

There were 14 studies that measured local reactions including pain or swelling at the injection site and IV site irritation (Figure 36, Table 37).21,53,57,58,60,61,67,76,86,89,98,100,109 The risk in those who received placebo was 19 percent (95% CI: 13 to 24 percent). For those who were administered active agents, the risk ranged from 3 percent (95% CI: 0 to 6 percent) to 43 percent (95% CI: 16 to 75 percent).

Figure 36 Risk of local reaction reported in acute migraine trials

Figure 36 displays a graph of the risk of local reaction across interventions. There were 9 different drug combinations, as well as placebo, that were associated with local reaction. The lowest risks were seen in droperidol and dexamethasone, while the highest risks were seen in sumatriptan and magnesium sulphate.

Table 37 Local reaction reported in acute migraine trials

Intervention | Author, Year | n/N | Risk (95% CI)
Placebo | Tek, 1987^98^ | 4/24 | 0.17 [0.07, 0.36]
Placebo | Wendt, 2006^57^ | 28/193 | 0.15 [0.10, 0.20]
Placebo | Mushet, 1996^58^ | 14/79 | 0.18 [0.11, 0.28]
Placebo | Cady, 1991^60^ | 88/370 | 0.24 [0.20, 0.28]
Placebo | Silberstein, 2003^63^ | 6/61 | 0.10 [0.05, 0.20]
Placebo | Subtotal N=5 | 140/727 | 0.17 [0.11, 0.22]
Chlorpromazine | Lane, 1989^67^ | 3/24 | 0.13 [0.04, 0.31]
Chlorpromazine | Subtotal N=4 | 3/24 | 0.13 [0.04, 0.31]
Standard abortive therapy plus Dexamethasone | Rowe, 2008^21^ | 2/64 | 0.03 [0.01, 0.11]
Standard abortive therapy plus Dexamethasone | Donaldson, 2008^76^ | 2/57 | 0.04 [0.01, 0.12]
Standard abortive therapy plus Dexamethasone | Jones, 2003^109^ | 1/34 | 0.03 [0.01, 0.15]
Standard abortive therapy plus Dexamethasone | Subtotal N=3 | 5/155 | 0.03 [0.00, 0.06]
DHE | Carleton, 1998^53^ | 6/85 | 0.07 [0.03, 0.15]
DHE | Winner, 1996^61^ | 57/152 | 0.38 [0.30, 0.45]
DHE | Subtotal N=2 | 63/237 | 0.22 [0.00, 0.52]
Droperidol | Silberstein, 2003^63^ | 0/61 | 0.00 [0.00, 0.04]
Droperidol | Subtotal N=1 | 0/61 | 0.00 [0.00, 0.04]
Lysine clonixinate | Krymchantowski, 2003^100^ | 3/17 | 0.18 [0.06, 0.41]
Lysine clonixinate | Subtotal N=1 | 3/17 | 0.18 [0.06, 0.41]
Metoclopramide plus MgSO _ 4 _ | Corbo, 2001^86^ | 1/21 | 0.05 [0.01, 0.23]
Metoclopramide plus MgSO _ 4 _ | Subtotal N=1 | 1/21 | 0.05 [0.01, 0.23]
MgSO _ 4 _ | Ginder, 2000^89^ | 3/7 | 0.43 [0.16, 0.75]
MgSO _ 4 _ | Subtotal N=1 | 3/7 | 0.43 [0.16, 0.75]
Nalbuphine | Tek, 1987^98^ | 8/23 | 0.35 [0.19, 0.55]
Nalbuphine | Subtotal N=1 | 8/23 | 0.35 [0.19, 0.55]
Nalbuphine plus Hydroxyzine | Tek, 1987^98^ | 9/24 | 0.38 [0.21, 0.57]
Nalbuphine plus Hydroxyzine | Subtotal N=1 | 9/24 | 0.38 [0.21, 0.57]
Sumatriptan | Wendt, 2006^57^ | 165/384 | 0.43 [0.38, 0.48]
Sumatriptan | Mushet, 1996^58^ | 27/79 | 0.34 [0.25, 0.45]
Sumatriptan | Cady, 1991^60^ | 321/547 | 0.59 [0.55, 0.63]
Sumatriptan | Winner, 1996^61^ | 28/158 | 0.18 [0.13, 0.24]
Sumatriptan | Subtotal N=4 | 541/1168 | 0.39 [0.20, 0.57]

CI = confidence interval; DHE = dihydroergotamine; IV = intravenous; MgSO_4_ = magnesium sulfate; N = number

#### Skin Reactions

Ten studies measured skin reactions to the interventions administered (Figure 37, Table 38).32,57,58,60,72,83,86,110,113 Included in this category was skin flushing or rash. The risk in those who received placebo was 3 percent (95% CI: 1 to 6 percent). For those who were administered active agents, the risk ranged from 2 percent (95% CI: 1 to 8 percent) to 48 percent (95% CI: 28 to 68 percent).

Figure 37 Risk of skin reaction reported in acute migraine trials

Figure 37 displays a graph of the risk of skin flushing across interventions. There were 8 different drug combinations, as well as placebo, that were associated with skin flushing. The lowest risks were seen in droperidol and metoclopramide plus pethidine while the highest risks were seen in DHE and metoclopramide plus magnesium sulphate.

Table 38 Skin reaction reported in acute migraine trials

Intervention | Author, Year | n/N | Risk (95% CI)
Placebo | Wendt, 2006^57^ | 7/193 | 0.04 [0.02, 0.07]
Placebo | Mushet, 1996^58^ | 2/79 | 0.03 [0.01, 0.09]
Placebo | Silberstein, 2003^63^ | 3/61 | 0.05 [0.02, 0.14]
Placebo | Subtotal N=3 | 12/333 | 0.03 [0.01, 0.06]
Butorphanol | Belgrade, 1989^110^ | 1/19 | 0.05 [0.01, 0.25]
Butorphanol | Subtotal N=1 | 1/19 | 0.05 [0.01, 0.25]
DHE | Belgrade, 1989^110^ | 6/21 | 0.29 [0.14, 0.50]
DHE | Subtotal N=1 | 6/21 | 0.29 [0.14, 0.50]
Droperidol | Silberstein, 2003^63^ | 1/61 | 0.02 [0.003, 0.09]
Droperidol | Subtotal N=1 | 1/61 | 0.02 [0.003, 0.09]
Metoclopramide | Corbo, 2001^86^ | 5/23 | 0.22 [0.10, 0.42]
Metoclopramide | Subtotal N=1 | 5/23 | 0.22 [0.10, 0.42]
Metoclopramide plus Pethidine | Cicek, 2004^113^ | 2/84 | 0.02 [0.01, 0.08]
Metoclopramide plus Pethidine | Subtotal N=1 | 2/84 | 0.02 [0.01, 0.08]
Metoclopramide plus MgSO _ 4 _ | Corbo, 2001^86^ | 10/21 | 0.48 [0.28, 0.68]
Metoclopramide plus MgSO _ 4 _ | Subtotal N=1 | 10/21 | 0.48 [0.28, 0.68]
MgSO _ 4 _ | Demirkaya, 2001^72^ | 2/15 | 0.13 [0.04, 0.38]
MgSO _ 4 _ | Cete, 2004^83^ | 3/36 | 0.08 [0.03, 0.22]
MgSO _ 4 _ | Subtotal N=2 | 5/51 | 0.10 [0.01, 0.18]
Pethidine | Cicek, 2004^113^ | 3/84 | 0.04 [0.01, 0.10]
Pethidine | Subtotal N=1 | 3/84 | 0.04 [0.01, 0.10]
Sumatriptan | Kelly, 1997^32^ | 1/20 | 0.05 [0.01, 0.24]
Sumatriptan | Wendt, 2006^57^ | 10/384 | 0.03 [0.01, 0.05]
Sumatriptan | Mushet, 1996^58^ | 4/79 | 0.05 [0.02, 0.12]
Sumatriptan | Cady, 1991^60^ | 36/547 | 0.07 [0.05, 0.09]
Sumatriptan | Subtotal N=4 | 51/1030 | 0.05 [0.02, 0.07]

CI = confidence interval; DHE = dihydroergotamine; MgSO_4_ = magnesium sulfate; N = number

#### Extrapyramidal Symptoms

Six studies reported extrapyramidal symptoms as a result of treatment.58,66,79,82,83,87 Included in this category are dystonic reactions, stiff neck, abnormal movements, and muscle twitching. The symptoms varied across studies and included muscle cramps,58 dystonia,66,87 muscle twitching,66 stiffness or abnormal movements,82 and stiff neck.79 Results for akathsia are presented under KQ 4. See Table 39 for a summary of the results.

Table 39 Extrapyramidal symptoms reported in acute migraine trials

Intervention | Author, Year | n/N | Risk (95% CI)
Placebo | Mushet, 1996^58^ | 1/79 | 0.01 [0.00, 0.07]
Placebo | Silberstein, 2003^63^ | 1/61 | 0.02 [0.003, 0.09]
Placebo | Subtotal N=2 | 2/140 | 0.01 [0.00, 0.04]
Droperidol | Miner, 2001^87^ | 1/82 | 0.01 [0.00, 0.07]
Droperidol | Silberstein, 2003^63^ | 1/61 | 0.02 [0.003, 0.09]
Droperidol | Subtotal N=2 | 2/143 | 0.01 [0.00, 0.04]
Methotrimeprazine | Stiell, 1991^66^ | 3/37 | 0.08 [0.03, 0.21]
Methotrimeprazine | Subtotal N=1 | 3/37 | 0.08 [0.03, 0.21]
Metoclopramide | Friedman, 2005^82^ | 3/40 | 0.08 [0.03, 0.20]
Metoclopramide | Cete, 2004^83^ | 1/37 | 0.03 [0.00, 0.14]
Metoclopramide | Subtotal N=2 | 4/77 | 0.04 [0.00, 0.10]
Sumatriptan | Friedman, 2006^79^ | 3/20 | 0.15 [0.05, 0.36]
Sumatriptan | Friedman, 2005^82^ | 7/38 | 0.18 [0.09, 0.33]
Sumatriptan | Mushet, 1996^58^ | 2/79 | 0.03 [0.01, 0.09]
Sumatriptan | Subtotal N=3 | 12/137 | 0.11 [0.00, 0.22]

CI = confidence interval; N = number

#### Chest Symptoms

Five studies assessed chest symptoms, which included palpitations, arrhythmia, and irregular heartbeat.32,57,58,61,106 See Table 40 for a summary of results.

Table 40 Chest symptoms reported in migraine trials

Intervention | Author, Year | n/N | Risk (95% CI)
Placebo | Wendt, 2006^57^ | 2/193 | 0.01 [0.00, 0.04]
Placebo | Subtotal N=1 | 2/193 | 0.01 [0.00, 0.04]
Chlorpromazine | Kelly, 1997^32^ | 1/23 | 0.04 [0.01, 0.21]
Chlorpromazine | Subtotal N=1 | 1/23 | 0.04 [0.01, 0.21]
DHE | Winner, 1996^61^ | 14/152 | 0.09 [0.06, 0.15]
DHE | Subtotal N=1 | 14/152 | 0.09 [0.06, 0.15]
Sumatriptan | Wendt, 2006^57^ | 20/384 | 0.05 [0.03, 0.08]
Sumatriptan | Mushet, 1996^58^ | 5/79 | 0.06 [0.03, 0.14]
Sumatriptan | Akpunonu, 1995^106^ | 5/88 | 0.06 [0.02, 0.13]
Sumatriptan | Winner, 1996^61^ | 9/158 | 0.06 [0.03, 0.10]
Sumatriptan | Subtotal N=4 | 39/709 | 0.05 [0.04, 0.07]

CI = confidence interval; DHE = dihydroergotamine; N = number

#### Anxiety

Five studies reported anxiety and related adverse effects, including mood change, moodiness, agitation, and insomnia.57,60,75,76,78 See Table 41 for a summary of results.

Table 41 Anxiety reported in acute migraine trials

Intervention | Author, Year | n/N | Risk (95% CI)
Placebo | Cady, 1991^60^ | 16/370 | 0.04 [0.03, 0.07]
Placebo | Silberstein, 2003^63^ | 2/61 | 0.03 [0.01, 0.11]
Placebo | Subtotal N=2 | 18/431 | 0.04 [0.02, 0.06]
Standard abortive therapy plus Dexamethasone | Donaldson, 2008^76^ | 3/57 | 0.05 [0.02, 0.14]
Standard abortive therapy plus Dexamethasone | Baden, 2006^78^ | 1/31 | 0.03 [0.01, 0.16]
Standard abortive therapy plus Dexamethasone | Subtotal N=2 | 4/88 | 0.04 [0.00, 0.09]
Droperidol | Silberstein, 2003^63^ | 10/61 | 0.16 [0.09, 0.28]
Droperidol | Subtotal N=1 | 10/61 | 0.16 [0.09, 0.28]
Prochlorperazine | Callan, 2008^75^ | 13/35 | 0.37 [0.23, 0.54]
Prochlorperazine | Subtotal N=1 | 13/35 | 0.37 [0.23, 0.54]
Promethazine | Callan, 2008^75^ | 8/35 | 0.23 [0.12, 0.39]
Promethazine | Subtotal N=1 | 8/35 | 0.23 [0.12, 0.39]
Sumatriptan | Wendt, 2006^57^ | 4/384 | 0.01 [0.00, 0.03]
Sumatriptan | Cady, 1991^60^ | 6/547 | 0.01 [0.01, 0.02]
Sumatriptan | Subtotal N=2 | 10/931 | 0.01 [0.00, 0.02]

CI = confidence interval; N = number

#### Digestion Issues

Two studies assessed digestion issues that were attributed to the interventions.20,53 Included in this category were any reports on dyspepsia, heartburn, epigastric discomfort, and diarrhea. See Table 42 for a summary of results.

Table 42 Digestion issues reported in acute migraine trials

Intervention | Author, Year | n/N | Risk (95% CI)
Placebo | Friedman, 2007^20^ | 3/99 | 0.03 [0.01, 0.09]
Placebo | Subtotal N=1 | 3/99 | 0.03 [0.01, 0.09]
DHE | Carleton, 1998^53^ | 10/85 | 0.12 [0.07, 0.20]
DHE | Subtotal N=1 | 10/85 | 0.12 [0.07, 0.20]
Meperidine | Carleton, 1998^53^ | 4/85 | 0.05 [0.02, 0.11]
Meperidine | Subtotal N=1 | 4/85 | 0.05 [0.02, 0.11]

CI = confidence interval; DHE = dihydroergotamine; N = number

#### Emergence Reactions

Two studies reported emergence reactions that resulted from the administration of the interventions.32,58 Included in this category were unpleasant dreams and nightmares. See Table 43 for a summary of the results.

Table 43 Emergence reactions reported in acute migraine trials

Intervention | Author, Year | n/N | Risk (95% CI)
Placebo | Mushet, 1996^58^ | 2/79 | 0.03 [0.01, 0.09]
Placebo | Subtotal N=1 | 2/79 | 0.03 [0.01, 0.09]
Sumatriptan | Kelly, 1997^32^ | 1/20 | 0.05 [0.01, 0.24]
Sumatriptan | Mushet, 1996^58^ | 1/79 | 0.01 [0.00, 0.07]
Sumatriptan | Subtotal N=2 | 2/99 | 0.02 [0.00, 0.05]

CI = confidence interval; N = number

## Key Question 4 Development of Akathisia

### Key Points

- No conclusions can be drawn regarding the development of akathisia when an anticholinergic is added to metoclopramide or phenothiazines (insufficient strength of evidence).
- Based on a mixed treatment analysis, there is no statistically significant difference in the development of akathisia between neuroleptics and metoclopramide.

This section addresses the development akathisia following the administration of phenothiazines plus anticholinergic agents compared with metoclopramide plus anticholinergic agents. Different drugs are used to combat akathisia. While most are anticholinergics, some have antihistamine and anticholinergic properties. These agents have been classified as anticholinergics in this report.

One study22 examined the differences in the development of akathisia when metoclopramide or phenothiazines were used with anticholinergic agents (Table 6). In this study, participants were administered either prochlorperazine or metoclopramide, both accompanied by 25 mg of IV diphenhydramine.22 76 70 The difference in rates of akathisia between the two groups was not statistically significant (OR = 1.50; 95% CI: 0.24, 9.52) (Table 44).

Table 44 Strength of evidence for the development of akathisia when anticholinergic agents are added to metoclopramide or phenothiazines

Comparison | Outcome (N Studies; N Patients) | Strength of Evidence Domains | | | | Strength of Evidence
Comparison | Outcome (N Studies; N Patients) | ROB | Consistency | Direct | Precision | Strength of Evidence
Metoclopramide + DPH vs. prochlor-perazine + DPH | Akathisia (1; 77) | Moderate | Unknown | Direct | Imprecise | Insufficient
Prochlorperazine + DPH vs. prochlorperazine | Akathisia (1; 58) | Low | Unknown | Direct | Imprecise | Insufficient

DPH = diphenhydramine; N = number; ROB = risk of bias

In another study, participants were administered prochlorperazine plus diphenhydramine or prochlorperazine alone (Table 9).29 There was no statistically significant difference between groups in the development of akathisia symptoms (OR = 0.46; 95% CI: 0.17, 1.28) (Table 44).

We conducted a post hoc mixed treatment analysis of 15 studies that reported akathisia as an adverse event. In addition to neuroleptics and metoclopramide, other interventions included opioids, sumatriptan, and orphan agents (i.e., hydroxyzine (Atarax), lidocaine, MgSO_4_, sodium valproate, tramadol, and octreotide). The results show that there is no statistically significant increase in akathisia when using agents except neuroleptic agents and metoclopramide. The results also show that there is no statistically significant difference in the risk of akathisia between neuroleptics and metoclopramide. The odds of experiencing akathisia symptoms following administration of these drugs is in the range of 10 times greater than with placebo (Figure 38). See Appendix F for the network diagram.

Figure 38 Mixed treatment analysis of studies that reported akathisia as an adverse effect

PB = probability

Figure 38 displays a mixed treatment analysis of studies that report akathisia as a side effect. There were 15 studies that reported akathisia as a side effect. There was no statistically significant difference in the risk of akathisia between neuroleptics and metoclopramide, although both were significantly greater than placebo. The odds of experiencing akathisia after taking these drugs (i.e. neuroleptics, opioids, sumatriptan etc) was in the range of 2 to 10 times greater than placebo.

## Key Question 5 Effectiveness and Safety of Parenteral Pharmacological Interventions in Different Subgroups

No studies presented results for the subgroups sex, race and duration of headaches. There were some data reported for the subgroup of patients who did not respond to treatment.

The detailed summary of the non-response data are available in Appendix E. Failure to respond was either defined by the authors (often in multiple ways), or described as not reaching a pain free status during the ED visit. The most commonly reported outcome was some measure of non-response; 32 studies (43 percent) reported both non-response and pain free status. There were variable definitions of non-response found in the acute migraine literature. The cut point for the reduction in pain indicating “response” varied widely (e.g., 90 percent, 45 percent). Time to assessment for response varied (e.g., end of treatment, 30–60 minutes, and up to 6 hours). Many studies failed to report the final scores in sufficient detail to determine which patients responded.

Few studies followed their patients after discharge, so it is difficult to determine the relationship between non-response and relapse outcomes. Several studies found that patients who achieved complete relief in the ED were less likely to have recurrence of headache within 48 hours.68,117 Another study specifically reported no difference in response between men and women at 24–48 hours after ED discharge; however, this study was focused on prevention, not the acute treatment.21 After multivariate adjustment, other investigators identified the following independent predictors of poor 24-hour outcomes: severe baseline pain, baseline nausea, screening positive for depression, and longer duration of headache.118

## Key Question 6 Subpopulations in Studies Assessing the Effectiveness of Corticosteroids in Prevention of Migraine Relapse

One study reported no difference in response between men and women in the prevention of relapse at 24–48 hours after ED discharge.21 No studies presented results for by race or ethnicity.

Several studies conducted an a priori subgroup analysis based on duration of headache. In the first,20 the authors compared patients who had an acute migraine lasting longer than 72 hours (n = 45) and patients with headache duration of 72 hours or less (n = 160). The primary outcome was persistent pain free (i.e., pain resolved completely by 2 hours and not recurring through 24 hours followup). For patients with longer headache duration, more patients who received dexamethasone were persistently pain free compared with those receiving placebo (OR = 4.1; 95% CI: 0.9, 18). For patients with shorter headache duration, there was no difference between the groups (OR = 1.0; 95% CI: 0.5, 2.2).

In the second study, relapse was explored using the median headache duration (24 hours) from the study sample as the cut point.21 Among patients whose headache had lasted more than 24 hours prior to ED presentation, the odds of relapse for those treated with dexamethasone was 0.3 (95% CI: 0.1, 0.8); dexamethasone did not reduce relapses among patients whose headache had lasted less than 24 hours (OR=1.7; 95% CI: 0.5, 5.8).

Finally, using a post hoc regression analysis, a third study demonstrated an association between increased headache duration and severe recurrent headache, suggesting that the risk ratio of recurrent severe headache increases by about one percent per hour of headache duration.19 Overall, all authors concluded that a dose of IV dexamethasone administered in the ED may be more effective for patients with prolonged migraine headache.

One trial conducted a subgroup analysis based on residual pain at discharge (VAS >2) compared with patients with better response to therapy (VAS ≤2).21 After adjusting for experimental treatment, only residual pain as measured by the VAS was a significant predictor of relapse. Patients with a VAS score >2 at ED discharge were at a higher risk of relapse compared with those whose pain was assessed with a VAS ≤2 at discharge (adjusted OR=2.4; 95% CI: 1.1, 5.4).