# References

1 Goadsby PJ, Lipton RB, Ferrari MD. Migraine--current understanding and treatment. N Engl J Med. 2002;346(4):257-70. [pmid: 11807151].
2 Headache Classification Committee of the International Headache Society. Part one- The primary headaches. Cephalalgia. 2004;24(Suppl 1):23-136. [pmid: 14687009].
3 Bigal ME, Ferrari M, Silberstein SD, et al. Migraine in the triptan era: lessons from epidemiology, pathophysiology, and clinical science. Headache. 2009;49(Suppl 1):S21-S33. [pmid: 19161562].
4 Cutrer FM. Pathophysiology of migraine. Semin Neurol. 2010;30(2):120-30. [pmid: 20352582].
5 Diamond S, Bigal ME, Silberstein S, et al. Patterns of diagnosis and acute and preventive treatment for migraine in the United States: results from the American Migraine Prevalence and Prevention study. Headache. 2007;47(3):355-63. [pmid: 17371352].
6 Bamford CC, Tepper SJ. Migraine – current understanding and treatment. Techniques Reg Anesth Pain Manage. 2009;13(1):20-7.
7 Hu XH, Markson LE, Lipton RB, et al. Burden of migraine in the United States: disability and economic costs. Arch Intern Med. 1999;159(8):813-8. [pmid: 10219926].
8 Lambert J, Carides GW, Meloche JP, et al. Impact of migraine symptoms on health care use and work loss in Canada in patients randomly assigned in a phase III clinical trial. Can J Clin Pharmacol. 2002;9(3):158-64. [pmid: 12422253].
9 Lipton RB, Hamelsky SW, Kolodner KB, et al. Migraine, quality of life, and depression: a population-based case-control study. Neurology. 2000;55(5):629-35. [pmid: 10980724].
10 Bigal ME, Kurth T, Santanello N, et al. Migraine and cardiovascular disease: a population-based study. Neurology. 2010;74(8):628-35. [pmid: 20147658].
11 Schurks M, Rist PM, Bigal ME, et al. Migraine and cardiovascular disease: systematic review and meta-analysis. BMJ. 2009;339:b3914. [pmid: 19861375].
12 Friedman BW, Serrano D, Reed M, et al. Use of the emergency department for severe headache. A population-based study. Headache. 2009;49(1):21-30. [pmid: 19040677].
13 Goldstein JN, Camargo CA Jr, Pelletier AJ, et al. Headache in United States emergency departments: demographics, work-up and frequency of pathological diagnoses. Cephalalgia. 2006;26(6):684-90. [pmid: 16686907].
14 Friedman BW. Migraine and other primary headache disorders. Rowe BH, editor. Evidence-based emergency medicine. 1st ed. Whiley-Blackwell. 2009:493-502.
15 Vinson DR. Treatment patterns of isolated benign headache in US emergency departments. Ann Emerg Med. 2002;39(3):215-22. [pmid: 11867972].
16 Colman I, Rothney A, Wright SC, et al. Use of narcotic analgesics in the emergency department treatment of migraine headache. Neurology. 2004;62(10):1695-700. [pmid: 15159464].
17 Richer LP, Laycock K, Millar K, et al. Treatment of children with migraine in emergency departments: national practice variation study. Pediatrics. 2010;126(1):e150-e155. [pmid: 20530076].
18 Richer L, Graham L, Klassen T, et al. Emergency department management of acute migraine in children in Canada: a practice variation study. Headache. 2007;47(5):703-10. [pmid: 17501852].
19 Innes GD, Macphail I, Dillon EC, et al. Dexamethasone prevents relapse after emergency department treatment of acute migraine: a randomized clinical trial. CJEM. 1999;1(1):26-33. [pmid: 17659098].
20 Friedman BW, Greenwald P, Bania TC, et al. Randomized trial of IV dexamethasone for acute migraine in the emergency department. Neurology. 2007;69(22):2038-44. [pmid: 17942818].
21 Rowe BH, Colman I, Edmonds ML, et al. Randomized controlled trial of intravenous dexamethasone to prevent relapse in acute migraine headache. Headache. 2008;48(3):333-40. [pmid: 18047499].
22 Friedman BW, Esses D, Solorzano C, et al. A randomized controlled trial of prochlorperazine versus metoclopramide for treatment of acute migraine. Ann Emerg Med. 2008;52(4):399-406. [pmid: 18006188].
23 Kelly AM, Walcynski T, Gunn B. The relative efficacy of phenothiazines for the treatment of acute migraine: a meta-analysis. Headache. 2009;49(9):1324-32. [pmid: 19496829].
24 Burnstein R, Levy D, Jakubowski M. Effects of sensitization of trigeminovascular neurons to triptan therapy during migraine. Rev Neurol. (Paris). 2005;161(6–7):658-60. [pmid: 16141951].
25 Dodick D, Lipton RB, Martin V, et al. Consensus statement: cardiovascular safety profile of triptans (5-HT agonists) in the acute treatment of migraine. Headache. 2004;44(5):414-25. [pmid: 15147249].
26 Akpunonu BE, Mutgi AB, Federman DJ, et al. Subcutaneous sumatriptan for treatment of acute migraine in patients admitted to the emergency department: a multicenter study. [Erratum appears in Ann Emerg Med 1995 Jun;25(6):857]. Ann Emerg Med. 1995;25(4):464-9. [pmid: 7710149].
27 Kelly AM, Kerr D, Clooney M. Impact of oral dexamethasone versus placebo after ED treatment of migraine with phenothiazines on the rate of recurrent headache: a randomised controlled trial. Emerg Med J. 2008;25(1):26-9. [pmid: 18156535].
28 Colman I, Freidman BW, Brown MD, et al. Parenteral dexamethasone for acute severe migraine headache: meta-analysis of randomised controlled trials for preventing recurrence. BMJ. 2008;336(7657):1359-61. [pmid: 18541610].
29 Vinson DR, Drotts DL. Diphenhydramine for the prevention of akathisia induced by prochlorperazine: a randomized, controlled trial. Ann Emerg Med. 2001;37(2):125-31. [pmid: 11174228].
30 Higgins JPT, Higgins JPT, Altman DG. on behalf of the Cochrane Statistical Methods Group and the Cochrane Bias Methods Group. Chapter 8: Assessing risk of bias in included studies. Cochrane handbook for systematic reviews of interventions Version 5.1.0. [updated March 2011]. 2011. http://www.cochrane-handbook.org.
31 Follmann D, Elliot P, Suh I. Variance imputation for overviews of clinical trials with continous response. J Clin Epidemiol. 1992;45(7):769-73. [pmid: 1619456].
32 Kelly AM, Ardagh M, Curry C, et al. Intravenous chlorpromazine versus intramuscular sumatriptan for acute migraine. Journal of Accident &; Emergency Medicine. 1997;14(4):209-11. [pmid: 9248904].
33 Egger M, Davey SG, Schneider M, et al. Bias in meta-analysis detected by a simple, graphical test. BMJ. 1997;315(7109):629-34. [pmid: 9310563].
34 Caldwell DM, Ades AE, Higgins JP. Simultaneous comparison of multiple treatments: combining direct and indirect evidence. BMJ. 2005;331(7521):897-900. [pmid: 16223826].
35 Lu G, Ades AE. Combination of direct and indirect evidence in mixed treatment comparisons. Stat Med. 2004;23(20):3105-24. [pmid: 15449338].
36 Higgins JP, Whitehead A. Borrowing strength from external trials in a meta-analysis. Stat Med. 1996;15(24):2733-49. [pmid: 8981683].
37 Smith TC, Spiegelhalter DJ, Thomas A. Bayesian approaches to random-effects meta-analysis: a comparative study. Stat Med. 1995;14(24):2685-99. [pmid: 8619108].
38 Dias S, Welton NJ, Caldwell DM, et al. Checking consistency in mixed treatment comparison meta-analysis. Stat Med. 2010;29(7–8):932-44. [pmid: 20213715].
39 Gartlehner G, Hansen R, Nissman D. A simple and valid tool distinguished efficacy from effectiveness studies. J Clin Epidemiol. 2006;59(10):1040-8. [pmid: 16980143].
40 Owens D, Lohr K, Atkins D. Grading the strength of a body of evidence when comparing medical interventions: Agency for Healthcare Research and Quality and the Effective Health Care Program; AHRQ series paper 5. J Clin Epidemiol. 2010;63(5):513-23. [pmid: 19595577].
41 Bigal ME, Bordini CA, Sheftell FD, et al. Migraine with aura versus migraine without aura: pain intensity and associated symptom intensities after placebo. Headache. 2002;42(9):872-7. [pmid: 12390612].
42 Bigal ME, Bordini CA, Speciali JG. Intramuscular diclofenac in the acute treatment of migraine: A double-blind placebo controlled study. [Portuguese]. Arq Neuropsiquiatr. 2002;60(2B):410-5. [pmid: 12131942].
43 Bigal ME, Bordini CA, Speciali JG. Intravenous Chlorpromazine in the Emergency Department treatment of migraines: A randomized controlled trial. J Emerg Med. 2002;23(2):141-8. [pmid: 12359281].
44 Bigal ME, Bordini CA, Tepper SJ, et al. Intravenous magnesium sulphate in the acute treatment of migraine without aura and migraine with aura. A randomized, double-blind, placebo-controlled study. Cephalalgia. 2002;22(5):345-53. [pmid: 12110110].
45 Lee JS, Hobden E, Stiell IG, et al. Clinically important change in the visual analog scale after adequate pain control. Acad Emerg Med. 2003;10(10):1128-30. [pmid: 14525749].
46 Todd KH, Funk JP. The minimum clinically important difference in physician-assigned visual analog pain scores. Acad Emerg Med. 1996;3(2):142-6. [pmid: 8808375].
47 Kelly AM. Does the clinically significant difference in visual analog scale pain scores vary with gender, age, or cause of pain?. Acad Emerg Med. 1998;5(11):1086-90. [pmid: 9835471].
48 Gallagher EJ, Liebman M, Bijur PE. Prospective validation of clinically important changes in pain severity measured on a visual analog scale. Ann Emerg Med. 2001;38(6):633-8. [pmid: 11719741].
49 Gallagher EJ, Bijur PE, Latimer C, et al. Reliability and validity of a visual analog scale for acute abdominal pain in the ED. Am J Emerg Med. 2002;20(4):287-90. [pmid: 12098173].
50 Bijur PE, Latimer CT, Gallagher EJ. Validation of a verbally administered numerical rating scale of acute pain for use in the emergency department. Acad Emerg Med. 2003;10(4):390-2. [pmid: 12670856].
51 Marinsek M, Kovacic D, Versnik D, et al. Analgesic treatment and predictors of satisfaction with analgesia in patients with acute undifferentiated abdominal pain. Eur J Pain. 2007;11(7):773-8. [pmid: 17251043].
52 Leinisch E, Evers S, Kaempfe N, et al. Evaluation of the efficacy of intravenous acetaminophen in the treatment of acute migraine attacks: a double-blind, placebo-controlled parallel group multicenter study. Pain. 2005;117(3):396-400. [pmid: 16153780].
53 Carleton SC, Shesser RF, Pietrzak MP, et al. Double-blind, multicenter trial to compare the efficacy of intramuscular dihydroergotamine plus hydroxyzine versus intramuscular meperidine plus hydroxyzine for the emergency department treatment of acute migraine headache. Ann Emerg Med. 1998;32(2):129-38. [pmid: 9701293].
54 Shrestha M, Singh R, Moreden J, et al. Ketorolac vs chlorpromazine in the treatment of acute migraine without aura. A prospective, randomized, double-blind trial. Arch Intern Med. 1996;156(15):1725-8. [pmid: 8694672].
55 Davis CP, Torre PR, Williams C, et al. Ketorolac versus meperidine-plus-promethazine treatment of migraine headache: evaluations by patients. Am J Emerg Med. 1995;13(2):146-50. [pmid: 7893296].
56 Limmroth V, May A, Diener HC. Lysine-acetylsalicylic acid in acute migraine attacks. European Neurology. 1999;41(2):88-93. [pmid: 10023111].
57 Wendt J, Cady R, Singer R, et al. A randomized, double-blind, placebo-controlled trial of the efficacy and tolerability of a 4-mg dose of subcutaneous sumatriptan for the treatment of acute migraine attacks in adults. Clin Ther. 2006;28(4):517-26. [pmid: 16750463].
58 Mushet GR, Cady RK, Baker CC, et al. Efficacy and tolerability of subcutaneous sumatriptan administered using the IMITREX^R^ STATdose^TM^ system. Clin Ther. 1996;18(4):687-99. [pmid: 8879897].
59 Thomson AN, Arthur GP, Bergin PS, et al. Subcutaneous sumatriptan in acute treatment of migraine - a multicenter New-Zealand trial. N Z Med J. 1993;106(955):171-3. [pmid: 8389026].
60 Cady RK, Wendt JK, Kirchner JR, et al. Treatment of acute migraine with subcutaneous sumatriptan. JAMA. 1991;265(21):2831-5. [pmid: 1851894].
61 Winner P, Ricalde O, Le FB, et al. A double-blind study of subcutaneous dihydroergotamine vs subcutaneous sumatriptan in the treatment of acute migraine. Arch Neurol. 1996;53(2):180-4. [pmid: 8639069].
62 Cabarrocas X. Efficacy and tolerability of subcutaneous almotriptan for the treatment of acute migraine: a randomized, double-blind, parallel-group, dose-finding study. Clin Ther. 2001;23(11):1867-75. [pmid: 11768838].
63 Silberstein SD, Young WB, Mendizabal JE, et al. Acute migraine treatment with droperidol: A randomized, double-blind, placebo-controlled trial. Neurology. 2003;60(2):315-21. [pmid: 12552051].
64 Kostic MA, Gutierrez FJ, Rieg TS, et al. A prospective, randomized trial of intravenous prochlorperazine versus subcutaneous sumatriptan in acute migraine therapy in the emergency department. Ann Emerg Med. 2010;56(1):1-6. [pmid: 20045576].
65 Cameron JD, Lane PL, Speechley M. Intravenous chlorpromazine vs intravenous metoclopramide in acute migraine headache. Acad Emerg Med. 1995;2(7):597-602. [pmid: 8521205].
66 Stiell IG, Dufour DG, Moher D, et al. Methotrimeprazine versus meperidine and dimenhydrinate in the treatment of severe migraine: a randomized, controlled trial. Ann Emerg Med. 1991;20(11):1201-5. [pmid: 1952306].
67 Lane PL, McLellan BA, Baggoley CJ. Comparative efficacy of chlorpromazine and meperidine with dimenhydrinate in migraine headache. Ann Emerg Med. 1989;18(4):360-5. [pmid: 2705667].
68 Jones J, Sklar D, Dougherty J, et al. Randomized double-blind trial of intravenous prochlorperazine for the treatment of acute headache. JAMA. 1989;261(8):1174-6. [pmid: 2915441].
69 Tanen DA, Miller S, French T, et al. Intravenous sodium valproate versus prochlorperazine for the emergency department treatment of acute migraine headaches: a prospective, randomized, double-blind trial. Ann Emerg Med. 2003;41(6):847-53. [pmid: 12764341].
70 Weaver CS, Jones JB, Chisholm CD, et al. Droperidol vs prochlorperazine for the treatment of acute headache. J Emerg Med. 2004;26(2):145-50. [pmid: 14980334].
71 Seim MB, March JA, Dunn KA. Intravenous ketorolac vs intravenous prochlorperazine for the treatment of migraine headaches. Acad Emerg Med. 1998;5(6):573-6. [pmid: 9660282].
72 Demirkaya S, Vural O, Dora B, et al. Efficacy of intravenous magnesium sulfate in the treatment of acute migraine attacks. Headache. 2001;41(2):171-7. [pmid: 11251702].
73 Miller MA, Levsky ME, Enslow W, et al. Randomized evaluation of octreotide vs prochlorperazine for ED treatment of migraine headache. Am J Emerg Med. 2009;27(2):160-4. [pmid: 19371522].
74 Hill CH, Miner JR, Martel ML. Olanzapine versus droperidol for the treatment of primary headache in the emergency department. Acad Emerg Med. 2008;15(9):806-11. [pmid: 19244630].
75 Callan JE, Kostic MA, Bachrach EA, et al. Prochlorperazine vs. promethazine for headache treatment in the emergency department: a randomized controlled trial. J Emerg Med. 2008;35(3):247-53. [pmid: 18534808].
76 Donaldson D, Sundermann R, Jackson R, et al. Intravenous dexamethasone vs placebo as adjunctive therapy to reduce the recurrence rate of acute migraine headaches: a multicenter, double-blinded, placebo-controlled randomized clinical trial. Am J Emerg Med. 2008;26(2):124-30. [pmid: 18272089].
77 Alemdar M, Pekdemir M, Selekler HM. Single-dose intravenous tramadol for acute migraine pain in adults: a single-blind, prospective, randomized, placebo-controlled clinical trial. Clin Ther. 2007;29(7):1441-7. [pmid: 17825695].
78 Baden EY, Hunter CJ. Intravenous dexamethasone to prevent the recurrence of benign headache after discharge from the emergency department: a randomized, double-blind, placebo-controlled clinical trial. CJEM. 2006;8(6):393-400. [pmid: 17209488].
79 Friedman BW, Hochberg M, Esses D, et al. A clinical trial of trimethobenzamide/diphenhydramine versus sumatriptan for acute migraines. Headache. 2006;46(6):934-41. [pmid: 16732839].
80 Honkaniemi J, Liimatainen S, Rainesalo S, et al. Haloperidol in the acute treatment of migraine: a randomized, double-blind, placebo-controlled study. Headache. 2006;46(5):781-7. [pmid: 16643581].
81 Engindeniz Z, Demircan C, Karli N, et al. Intramuscular tramadol vs. diclofenac sodium for the treatment of acute migraine attacks in emergency department: a prospective, randomised, double-blind study. Journal of Headache and Pain. 2005;6(3):143-8. [pmid: 16355295].
82 Friedman BW, Corbo J, Lipton RB, et al. A trial of metoclopramide vs sumatriptan for the emergency department treatment of migraines. Neurology. 2005;64(3):463-8. [pmid: 15699376].
83 Cete Y, Dora B, Ertan C, et al. A randomized prospective placebo-controlled study of intravenous magnesium sulphate vs. metoclopramide in the management of acute migraine attacks in the Emergency Department. Cephalalgia. 2004;25(3):199-204. [pmid: 15689195].
84 Meredith JT, Wait S, Brewer KL. A prospective double-blind study of nasal sumatriptan versus IV ketorolac in migraine. Am J Emerg Med. 2003;21(3):173-5. [pmid: 12811706].
85 Richman PB, Allegra J, Eskin B, et al. A randomized clinical trial to assess the efficacy of intramuscular droperidol for the treatment of acute migraine headache. Am J Emerg Med. 2002;20(1):39-42. [pmid: 11781912].
86 Corbo J, Esses D, Bijur PE, et al. Randomized clinical trial of intravenous magnesium sulfate as an adjunctive medication for emergency department treatment of migraine headache. Ann Emerg Med. 2001;38(6):621-7. [pmid: 11719739].
87 Miner JR, Fish SJ, Smith SW, et al. Droperidol vs. prochlorperazine for benign headaches in the emergency department. Acad Emerg Med. 2001;8(9):873-9. [pmid: 11535479].
88 Blanda M, Rench T, Gerson LW, et al. Intranasal lidocaine for the treatment of migraine headache: a randomized, controlled trial. Acad Emerg Med. 2001;8(4):337-42. [pmid: 11282668].
89 Ginder S, Oatman B, Pollack M. A prospective study of IV magnesium and IV prochlorperazine in the treatment of headaches. J Emerg Med. 2000;18(3):311-5. [pmid: 10729668].
90 Drotts DL, Vinson DR. Prochlorperazine induces akathisia in emergency patients. Ann Emerg Med. 1999;34(4:Pt 1):t-75. [pmid: 10499947].
91 Jones J, Pack S, Chun E. Intramuscular prochlorperazine versus metoclopramide as single-agent therapy for the treatment of acute migraine headache. Am J Emerg Med. 1996;14(3):262-4. [pmid: 8639197].
92 Coppola M, Yealy DM, Leibold RA. Randomized, placebo-controlled evaluation of prochlorperazine versus metoclopramide for emergency department treatment of migraine headache. Ann Emerg Med. 1995;26(5):541-6. [pmid: 7486359].
93 Jovicic A, Maric D, Ilic T. Treatment of acute migraine attacks [Serbian]. Vojnosanitetski Pregled. 1995;52(1):44-8. [pmid: 7638950].
94 Duarte C, Dunaway F, Turner L, et al. Ketorolac versus meperidine and hydroxyzine in the treatment of acute migraine headache: a randomized, prospective, double-blind trial. Ann Emerg Med. 1992;21(9):1116-21. [pmid: 1514724].
95 Tek DS, McClellan DS, Olshaker JS, et al. A prospective, double-blind study of metoclopramide hydrochloride for the control of migraine in the emergency department. Ann Emerg Med. 1990;19(10):1083-7. [pmid: 2221512].
96 Bell R, Montoya D, Shuaib A, et al. A comparative trial of three agents in the treatment of acute migraine headache. Ann Emerg Med. 1990;19(10):1079-82. [pmid: 2221511].
97 McEwen JI, O’Connor HM, Dinsdale HB. Treatment of migraine with intramuscular chlorpromazine. Ann Emerg Med. 1987;16(7):758-63. [pmid: 3592329].
98 Tek D, Mellon M. The effectiveness of nalbuphine and hydroxyzine for the emergency treatment of severe headache. Ann Emerg Med. 1987;16(3):308-13. [pmid: 3544982].
99 Frank LR, Olson CM, Shuler KB, et al. Intravenous magnesium for acute benign headache in the emergency department: A randomized double-blind placebo-controlled trial. CJEM. 2004;6(5):327-32. [pmid: 17381989].
100 Krymchantowski AV, Silva MTT. Intravenous lysine clonixinate for the acute treatment of severe migraine attacks: a double-blind, randomized, placebo-controlled study. Current Therapeutic Research - Clinical and Experimental. 2003;64(8):505-13.
101 Larkin GL, Prescott JE. A randomized, double-blind, comparative study of the efficacy of ketorolac tromethamine versus meperidine in the treatment of severe migraine. Ann Emerg Med. 1992;21(8):919-24. [pmid: 1497157].
102 Klapper JA, Stanton JS. Ketorolac versus DHE and metoclopramide in the treatment of migraine headaches. Headache. 1991;31(8):523-4. [pmid: 1960056].
103 Fiesseler FW, Shih R, Szucs P, et al. Steroids for migraine headaches: a randomized double-blind, two-armed, placebo-controlled trial. J Emerg Med. 2011;40(4):463-8. [pmid: 19846269].
104 Edwards KR, Norton J, Behnke M. Comparison of intravenous valproate versus intramuscular dihydroergotamine and metoclopramide for acute treatment of migraine headache. Headache. 2001;41(10):976-80. [pmid: 11903525].
105 Aktas C, Giray S, Sarikaya S, et al. Ondansetron: an agent to be included in the emergency treatment of migraine headache?. Healthmed. 2011;5(1):187-93.
106 Akpunonu BE, Mutgi AB, Federman DJ, et al. Subcutaneous sumatriptan for treatment of acute migraine in patients admitted to the emergency department: a multicenter study. [Erratum appears in Ann Emerg Med 1995 Jun;25(6):857]. Ann Emerg Med. 1995;25(4):464-9. [pmid: 7710149].
107 Klapper J, Stanton J. The emergency treatment of acute migraine headache - a comparison of intravenous dihydroergotamine, dexamethasone, and placebo. Cephalalgia. 1989;11:159-60.
108 Callaham M, Raskin N. A controlled study of dihydroergotamine in the treatment of acute migraine headache. Headache. 1986;26(4):168-71. [pmid: 3519528].
109 Jones J, Brown MD, Bermingham M, Anderson I, Perrin J. 2003: SAEM Annual Meeting Abstracts. Efficacy of parenteral dexamethasone to prevent relapse after emergency department treatment of acute migraine. Academic Emergency Medicine. 2003;10(5):423-576.
110 Belgrade MJ, Ling LJ, Schleevogt MB, et al. Comparison of single-dose meperidine, butorphanol, and dihydroergotamine in the treatment of vascular headache. Neurology. 1989;39(4):590-2. [pmid: 2648190].
111 Karachalios GN, Fotiadou A, Chrisikos N, et al. Treatment of acute migraine attack with diclofenac sodium: a double-blind study. Headache. 1992;32(2):98-100. [pmid: 1551795].
112 Hoag R, Mortimer L. Methotrimeprazine compared to meperidine and dimenhydrinate in the treatment of migraine headache. CAEP Review. May. 1986:29-31.
113 Cicek M, Karcioglu O, Parlak I, et al. Prospective, randomised, double blind, controlled comparison of metoclopramide and pethidine in the emergency treatment of acute primary vascular and tension type headache episodes. Emerg Med J. 2004;21(3):323-6. [pmid: 15107371].
114 Monzillo PH, Nemoto PH, Costa AR, et al. Acute treatment of migraine in emergency room: comparative study between dexametasone and haloperidol. Preliminary results. [Portuguese]. Arq Neuropsiquiatr. 2004;62(2B):513-8. [pmid: 15273854].
115 Taheraghdam AA, Amiri H, Shojaan H, et al. Intravenous dexamethasone versus morphine in relieving of acute migraine headache. Pak J Biol Sci. 2011;14(12):682-7. [pmid: 22303641].
116 The Subcutaneous Sumatriptan International Study Group. Treatment of migraine attacks with sumatriptan. The Subcutaneous Sumatriptan International Study Group. N Engl J Med. 1991;325(5):316-21. [pmid: 1647495].
117 Ducharme J, Beveridge RC, Lee JS, et al. Emergency management of migraine: is the headache really over?. Acad Emerg Med. 1998;5(9):899-905. [pmid: 9754503].
118 Friedman BW, Hochberg ML, Esses D, et al. Recurrence of primary headache disorders after emergency department discharge: frequency and predictors of poor pain and functional outcomes. Ann Emerg Med. 2008;52(6):696-704. [pmid: 18387702].
119 Vinson DR, Hurtado TR, Vandenberg JT, et al. Variations among emergency departments in the treatment of benign headache. Ann Emerg Med. 2003;41(1):90-7. [pmid: 12514688].
120 Friedman BW, Kapoor A, Friedman MS, et al. The relative efficacy of meperidine for the treatment of acute migraine: a meta-analysis of randomized controlled trials. Ann Emerg Med. 2008;52(6):705-13. [pmid: 18632186].
121 Colman I, Brown MD, Innes GD, et al. Parenteral dihydroergotamine for acute migraine headache: A systematic review of the literature. Ann Emerg Med. 2005;45(4):393-401. [pmid: 15795718].
122 Colman I, Brown MD, Innes GD, et al. Parenteral metoclopramide for acute migraine: meta-analysis of randomised controlled trials. BMJ. 2004;329(7479):1369-73. [pmid: 15550401].
123 Moher D, Hopewell S, Schulz KF, et al. CONSORT 2010 Explanation and Elaboration: Updated guidelines for reporting parallel group randomised trials. J Clin Epidemiol. 2010;63(8):e1-37. [pmid: 20346624].