# Peer Reviewers

Sam Campbell, M.B., B.Ch.

Departments of Emergency Medicine

Dalhousie University and Queen Elizabeth II Health Science Centre

Halifax, Nova Scotia, Canada

Christopher Carpenter, M.D., M.Sc.

Division of Emergency Medicine

Washington University School of Medicine in St. Louis

St. Louis, MO

Andrew Chang, M.D.

Montefiore Medical Center

Bronx, NY

Charles Flippen, II, M.D.

David Geffen School of Medicine at UCLA

Neurology Department

Los Angeles, CA

Alan Jones, M.D.

Department of Emergency Medicine

University of Mississippi Medical Center

Jackson, MS

Carrie Robertson, M.D.

Department of Neurology

Mayo Clinic

Rochester, MN