# Key Informants and Technical Expert Panel^*^ * One member’s name was removed by request

Michael Brown, M.D., M.Sc.

Michigan State University College of Human Medicine

Grand Rapids, MI

James Ducharme, M.D.

McMaster University

Hamilton, Ontario, Canada

Kenneth Mack, M.D., Ph.D.

Mayo Clinic Pediatric Center

Rochester, MN

Marco Sivilotti, B.Sc., M.Sc., M.D.

Departments of Emergency Medicine and Pharmacology & Toxicology

Queens University

Kingston, Ontario, Canada

Andrew Worster, B.Sc., M.Sc., M.D., M.Sc.

McMaster Clinic-Hamilton General Hospital

Hamilton, Ontario, Canada