# Network Diagrams for the Mixed Treatment Analyses

F.1 Pain (Visual analog scale)

This figure illustrates the comparisons and number of randomized controlled trials for each that were examined in the network meta-analysis for pain (VAS).

AN = anti-nauseants; DHE = dihydroergotamine; NSAIDS = nonsteroidal anti-inflammatory drugs

Appendix F.1 shows the 10 interventions used in the pain network meta-analysis and how many studies there were directly comparing each pair of intervetions. The number of studies for each pair ranged from 0 to 5.

F.2 Akathisia

This figure illustrates the comparisons and number of randomized controlled trials for each that were examined in the network meta-analysis for akathesia.

Appendix F.2 shows the 6 interventions used in the pain network meta-analysis and how many studies there were directly comparing each pair of intervetions. The number of studies for each pair ranged from 0 to 4.