# Nonresponders Table

Author, year | Non-response definition | Nonresponse data | | Not pain-free data | | Relevance/Conclusions
Author, year | Non-response definition | Treatment | Comparison | Treatment | Comparison | Relevance/Conclusions
Akpunonu, 1995 | Failure of patient to achieve “meaningful relief” as defined by patient | SUM 22/88 = 25% | Placebo 31/48 = 65% | SUM 61/88 = 69% | Placebo 42/48 = 88% | NR
Aktas, 2011 | Requirement of rescue medication (60 minutes after initial treatment) | OND 4/30 = 13.3% | MET 1/30 = 3% | NR | NR | NR
Alemdar, 2007 | Failure to achieve decrease in VAS pain score by >50% of baseline value and a decrease of 4-point verbal scale score (60 minutes after initial treatment) | Tramadol 5/17 = 30% | Placebo 11/17 = 65% | Tramadol 12/17 = 71% | Placebo 15/17 = 88% | Headache recurrence within 24 hr of administration reported by 2 (16.7%) of 12 patients with pain response in the tramadol group, and 1 (16.7%) of 6 patients with pain response in the placebo group.
Baden, 2006 | Failure to relieve all pain by ED discharge. | NR | NR | NR | NR | NR
Belgrade, 1989 | Failure to achieve near-complete pain resolution (90% or greater) | MEP 22/22 = 100% BUT 16/19 = 84% | DHE 13/21 = 62% | NR | NR | NR
Bell, 1990 | Patient requires addition medication (outside treatment protocol). | CPZ 5/24 = 21% | LID 11/26 = 42% DHE 13/26 = 50% | CPZ 16/24 = 67% | LID 24/26 = 92% DHE 6/26 = 77% | NR
Bigal, 2002 | Failure to achieve pain reduction of <2 points on scale of 0 to 3 before discharge (60 minutes after initial treatment) | CPZ 12/68 = 18% | Placebo 51/60 = 85% | CPZ 24/68 = 35% | Placebo 55/60 = 92% | NR
Bigal, 2002 | | NR | NR | Diclofenac 28/30=93% | Placebo 19/30=63% | NR Foreign language (Portugese)
Blanda, 2001 | < 50% improvement in pain score or an absolute pain score >2.5cm (VAS) 5 min after treatment | LID 25/27 = 93% | Placebo 19/22 = 86% | LID 9/27 = 33% | Placebo 6/22 = 27% | It may be that patients who had more severe pain were less likely to respond (at 5 min).
Cabarrocas, 2001 | Failure to achieve a reduction in migraine pain from moderate or severe at baseline to mild or no pain (120 min after initial treatment) | Almotriptan 2mg: ~60% 6mg: 97% 10mg: 90% | Placebo 50% | Almotriptan 2mg: 74% 6mg: 41% 10mg: 61% | Placebo 75% | NR
Cady, 1991 | Requirement of rescue medication | SUM 20% | Placebo 59% | SUM 223/734 = 30% | Placebo 290/370 = 78% | NR
Callaham, 1986 | Requirement of rescue narcotics | DHE 0/19 = 0% | Placebo 4/15 = 27% | NR | NR | No factors correlated with treatment success.
Callan, 2008 | Requirement of rescue medication 60 min after initial treatment (Failure to achieve improvement of 25mm on VAS scale) | PMZ 12/35 = 34% | PC 12/35 = 34% | NR | NR | NR
Cameron, 1995 | Failure of patient to achieve >70% relief (Requirement of rescue medication) | CPZ 10/47 = 26% | MET 15/44 = 33% | CPZ 35/47 = 74% | MET 33/44 = 75% | NR
Carleton, 1998 | Need for second treatment | DHE 30/85 = 39% | MEP 31/85 = 41% | NR | NR | NR
Carleton, 1998 | Requirement of rescue medication | DHE 16/85 = 19% | MEP 14/85 = 16% | NR | NR | NR
Cete, 2004 | Requirement of rescue medication (30 min after initial treatment) | MEP 14/37=38% MgSO_4_ 16/36 =44% | Placebo 26/40 = 65% | NR | NR | NR
Cicek, 2004 | Required rescue medication (60 min after initial treatment) | MET 12/85 = 14% PET 35/84 = 42% | MET+PET 23/84 = 27% Placebo 52/83 =63% | NR | NR | NR
Coppola, 1995 | Failure to achieve patient satisfaction and either a decrease of >50% in the 30-min pain score (compared with the initial score) or an absolute pain score of 2.5 cm or less. | MET 52% PC 18% | Placebo 71% | MET 6/24 = 25% PC 2/22 = 9% | Placebo 15/24 = 63% | NR
Corbo, 2001 | Failure to obtain a 50% pain reduction (45 minutes after initial treatment) | MET+MgSO_4_ 6/21 = 29% | MET+placebo 1/23 = 4% | NR | NR | NR
Davis, 1995 | < 4 unit change in pain score (on 10-point Borg scale) | MEPT/PMZ 7/22 = 32% | Ketorolac 9/20 = 45% | NR | NR | Quotation: if the patient’s headache pain is reduced within 30 to 60 min, the patient can be given relatively good assurance that the migraine headache will continue to be suppressed for hours.
Demirkaya, 2001 | Failure to reduce headache pain from medium or severe to none or mild (30 min after initial treatment) | MgSO_4_ 0/15 = 0% | Placebo 14/15 = 93% | MgSO_4_ 2/15 =13.4% | Placebo 15/15 = 100% | NR
Donaldson, 2008 | Failure to resolve headache in ED | NR | NR | DEX 30/57 = 53% | Placebo 27/42 = 64 % | NR
Drotts, 1999 | NR | NR | NR | NR | NR | NR
Duarte, 1992 | Patient fails to achieve “complete” or “great deal” of relief | KET 10/25 = 40% | MEP/HYD 11/25 = 44% | KET 24/25 = 96% | MEP/HYD 25/25 = 100% | NR
Edwards, 2001 | Failure to achieve headache relief (from moderate to severe to mild or no headache) within 4 hr | VAL 40% | MET+DHE 40% | NR | NR | NR
Engindeniz, 2005 | Failure to achieve headache relief (from pain score of 2 or 3 to 0 or 1) within 2 hr | Diclofenac sodium 4/20 = 20% | Tramadol 4/20 = 20% | Diclofenac sodium 11/20 = 55% | Tramadol 13/20 = 65% | NR
Fiesseler, 2011 | Failure to resolve headache at 24 hr FU | DEX 15/46 = 33% Prednisone 18/48 = 38% | Placebo 36/82 = 44% | DEX (At D/C) 81/94 = 86% | Placebo (At D/C) 77/87 = 89% | NR
Frank, 2004a | <50% reduction in VAS pain score | MgSO_4_ 17/21 = 81% | Placebo 16/21 = 76% | NR | NR | NR
Frank, 2004b | Patients requiring rescue therapy. | MgSO_4_ 17/21 = 81% | Placebo 18/21 = 86% | NR | NR | NR
Friedman, 2005 | Required rescue medication | MET/DPH 2/40 = 5% | SUM 10/38 = 26% | MET/DPH 16/40= 41% | SUM 24/38 = 65% | NR
Friedman, 2006 | Failure to achieve mild or no headache pain at 2 hr post-treatment (required rescue medication) | TMB+DPH 4/20 = 20% | SUM 3/20 = 15% | TMB/DPH 14/20 = 70% | SUM 11/20 = 55% | NR
Friedman, 2007 | Requirement of rescue medication | MET+DEX 14/106 = 13% | MET+Placebo 13/99 = 13% | MET+DEX 48/106 = 45% | MET+Placebo 52/99 = 53% | In the H/A > 72 hr subgroup, 38% of those receiving dexamethasone were persistently pain free vs 13% of placebo (p = 0.06).
Friedman, 2008 | Required rescue medication (60 min after initial treatment) | PCZ 3/34 = 9% | MET 6/36 = 17% | PCZ 16/37 = 43% | MET 22/37 = 59% | Logistic regression analysis showed that duration of headache did not influence the 1-hr outcome (R2 = 0.00; P= 0.73).
Ginder, 2000 | Partial (<45%) or no pain relief and requirement of additional pain medication | PCZ 10/20 = 50% | MgSO_4_ 8/16 = 50% | PCZ 12/20 = 60% | MgSO_4_ 14/16 = 88% | NR
Hill, 2008a | Failure to reduce pain from moderate or severe to mild or none (60 min after initial treatment) | Olanzapine 6/44 = 13.6% | DRO 5/40 = 12.5% | Olanzapine 28/45 =62% | DRO 31/45 =69% | NR
Hill, 2008b | Required rescue medication | Olanzapine 4/45 = 9% | DRO 6/42 =14% | (See above) | (see above) | NR
Hoag, 1986 | Failure to achieve improvement above the median relief score of 2.2 | MTP 30% | MEP+DHE 72% | NR | NR | NR
Honkaniemi, 2006 | Failure to achieve “significant relief” within 3 hr of treatment | Haloperidol 4/20 = 20% | Placebo 17/20 = 85% | NR | NR | NR
Innes, 1999 | Patients requiring > 1 abortive treatment. | DEX 25/49 = 51% | Placebo 26/49 = 53% | NR | NR | Post-hoc regression analysis showed an association between increased headache duration and severe recurrent headache, suggesting that the relative risk of recurrent severe headache increases by about 1%/hr of headache duration.
Jones, 1989 | Any patient without relief (60 minutes after initial treatment) | PCZ 5/42 = 12% | Placebo 22/40 = 55% | PCZ 31/42 = 74% | Placebo 5/40 = 13% | Patients (treatment, and placebo) who achieved complete relief in the ED had no recurrence of headache within 48 hrs.
Jones, 1996 | Required rescue analgesic (60 minutes after initial treatment) | PCZ 16/28 = 57% MET 23/29 = 79% | Placebo 25/29 = 86% | PCZ 19/28 = 68% MET 25/29 = 86% | Placebo 27/29 = 93%
Jones, 2003 | | NR | NR | | | Abstract
Jovicic, 1995 | | NR | NR | NR | NR | Foreign language
Karachallios, 1992 | Failure to achieve complete pain relief | Diclofenac sodium 5/45 = 12% | Paracetamol 33/40 = 82.5% | Diclofenac sodium Same result | NR | NR
Kelly, 1997 | Failure to relieve pain to patient satisfaction | SUM 1/20 = 5% | CPZ 1/23 = 4% | SUM 58% | CPZ 59% | NR
Klapper, 1986 | Pain improvement of <1 pain unit, and patient felt unable to return to normal functioning | DEX+MET 5/11 = 46% DHE+MET 4/9 = 44% | Placebo 0/10 = 0% | NR | NR | NR
Klapper, 1991 | Moderate pain and requirement of rescue medication (60 min after initial treatment) | KET 6/9 = 67% | DHE+MET 0/8 = 0% | | | NR
Kostic, 2010 | | NR | NR | NR | NR | NR
Krymchantowski, 2003 | Requirement of rescue medication (120 min after initial treatment) | LC 1/17 = 6% | Placebo 6/12 = 50% | LC 3/17 = 18% | Placebo 7/12 = 58% | NR
Lane, 1989 | Requirement of rescue medication after 3 treatments (45 min after initial treatment) | CPZ 2/24 = 8% | MEP+DHE 11/22 = 50% | NR | NR | NR
Larkin, 1992 | Requirement of rescue medication | KET 11/15 = 73% | MEP 6/16 = 36% | KET 14/15 = 95% (Figure 2) | MEP 11/16 = 70% (Figure 2) | NR
Limroth, 1999 | Pain relief of less than 50% (60 min after initial treatment) | L-ASA 31/56 = 55% | Ergot 43/56 = 77% | NR | NR | NR
McEwen, 1987 | Requirement of rescue medication | CPZ 8/19 = 42% | Placebo 14/17 = 82% | CPZ 18/19 = 95% | Placebo 17/17 = 100% | NR
Meredith, 2003 | Requirement of rescue medication at end of study period | SUM 4/16 = 25% | KET 2/13 = 15% | NR | NR | NR
Miller, 2009 | Failure to achieve patient satisfaction with treatment and either a decrease of 50% or more in the pain score when compared with the initial score or an absolute pain score of 2.5 cm or less (Required rescue medication) | PCZ 2/20 = 10% | OC 11/23 = 48% | NR | NR | NR
Miner, 2001 | Failure to obtain least a 50% reduction from their baseline VAS scores (60 min after initial treatment) | DRO 8/82 = 98% | PCZ 27/86 = 31% | NR | NR | NR
Monzillo, 2004 | | NR | NR | Haloperidol 0/14=0% | DEX 13/15 = 53.4% | NR Foreign language
Mushet, 1996 | Pain reduction of <2 points on scale of 0 to 3 (60 min after initial treatment) | SUM Study 1: 30% Study 2: 23% | Placebo Study 1: 75% Study 2: 68% | SUM -120 mins Study 1: ~40% Study 2: ~44% (Figure) | Placebo -120 mins Study 1: ~91% Study 2: ~90% (Figure) | NR
Richman, 2002 | Patient not well enough to go home after 30 min and thus requiring rescue medication | DRO 33% | MEP 43% | NR | NR | NR
Rowe, 2007 | score of > 2 on the VAS scale at the end of treatment (which varied) | DEX 24/64 = 38% | Placebo 23/62 = 37% | NR | NR | VAS >2 at end of treatment had more relapse than responders (~38% vs ~20%)
Seim, 1998 | Requirement of rescue treatment (60 min after initial treatment) | PCZ 6/35 = 17% | KET 4/29 = 14% | NR | NR | NR
Shresta, 1997 | Requirement of rescue medication (120 min after initial treatment) | KET 1/15 = 7% | CPZ 2/15 = 13% | KET 6/15 = 40% | CPZ 6/15 = 40% | NR
Stiell, 1991 | Failure of patient to achieve >70% relief, requiring rescue medication | MEP/DHE 27.0% | MTZ 29.7% | NR | NR | NR
Tanen, 2003 | Requirement of rescue medication (60 min after initial treatment) | VAL 15/19 = 79% | PCZ 5/20 = 25% | NR | NR | NR
Tek, 1990 | “No relief of pain” | MET 8/24 = 33% | Placebo 21/26 = 81% | NR | NR | NR
Tek, 1987 | Requirement of rescue medication | NR | NR | NR | NR | NR
Thomson, 1993a | Failure to achieve significant improvement in pain (i.e. grade 2 or 3 to grade 0 or 1) within 30 min | SUM 10/28 = 36% | Placebo 16/22 = 73% | SUM 23/28 = 82% (30 minutes) | Placebo 21/22 = 95% (30 minutes) | NR
Thomson, 1993b | Patients requiring rescue therapy | SUM 9/28 = 32% | Placebo 17/22 = 75% | (See above) | (See above) | NR
Vinson, 2001 | | NR | NR | NR | NR | NR
Weaver, 2004 | Failure to achieve 50% pain relief (30 min after initial treatment) | DRO 8/48 = 17% | PCZ 34/47 = 28% | DRO 22/48 = 46% | PCZ 29/47 = 62% | NR
Wendt, 2006 | Failure to reduce moderate or severe pain to mild or no pain (120 min after initial treatment) | SUM 30% | Placebo 78% | SUM 50% | Placebo 89% | NR
Winner, 1996a | Failure to achieve relief by 3 hr (i.e. required rescue mediation) | DHE 20/145 = 14% | SUM 15/150 = 10% | DHE 27/145 = 19% | SUM 46/150 = 30% | NR
Winner, 1996b | Patients requiring rescue therapy | DHE 43/145 = 30% | SUM 23/150 = 15% | (See above) | (See above) | NR

BUT: Butorphanol; CPZ: chlorpromazine; DHE: Dihydroergotamine; DEX: Dexamethasone; DPH Diphenhydramine; DRO: Droperidol; DiNa: diclofenac sodium; Ergot: Ergotamine; HDZ: Hydroxyzine; KET: Ketorolac; L-ASA: Lysine-Acetylsalicylic Acid; LC: Lysine Clonixinate; LID: Lidocaine; MEP: Meperidine; MgSO4: Magnesium sulphate; MTP: Metroclopamide; MTZ: Methotrimeprazine; NR = not reported; OC: Octreotide; OND: Ondansetron; PCZ: Prochlorperazine; PMZ: Promethazine; SUM: Sumatripan; TMB: Trimethobenzamide; VAL: Valporate.