# Risk of Bias Table

Reference list with complete citation appears at the end in alphabetical order.

Author Year | Sequence generation | Allocation concealment | Blinding: Subjective outcomes | Incomplete outcome data | Selective outcome reporting | Other sources | Overall risk of bias
Akpunonu 1995 | Unclear | Unclear | Unclear | Low | Low | Low | Unclear
Aktas 2011 | Unclear | Unclear | Unclear | Unclear | Unclear | Low | Unclear
Alemdar 2007 | Unclear | High | Unclear | Low | Low | Low | High
Baden 2006 | Low | Low | Low | Low | Low | Low | Low
Belgrade 1989 | Unclear | Unclear | High | Low | Low | Low | High
Bell 1990 | Unclear | Unclear | Unclear | High | Low | Low | High
Bigal 2002 | Low | Unclear | Unclear | Low | Unclear | Unclear | Unclear
Blanda 2001 | Low | Low | Low | Low | Low | Low | Low
Cabarrocas 2001 | Unclear | Unclear | Unclear | Low | Low | Low | Unclear
Cady 1991 | Unclear | Unclear | Unclear | Low | Low | Low | Unclear
Callaham 1986 | Unclear | Unclear | Low | Low | Low | Low | Unclear
Callan 2008 | Low | Low | Low | Unclear | Low | Low | Unclear
Cameron 1995 | Low | Low | Low | Low | Low | Low | Low
Carleton 1998 | Low | Low | Low | Low | Low | Low | Low
Cete 2005 | Low | Low | Low | Low | Low | Low | Low
Cicek 2004 | Low | Unclear | Low | Low | Low | Low | Unclear
Coppola 1995 | Low | Unclear | Unclear | Low | Low | Low | Unclear
Corbo 2001 | Low | Low | Low | Low | Unclear | Low | Unclear
Davis 1995 | Unclear | Low | Low | Low | Low | Low | Unclear
Demirkaya 2001 | Unclear | Unclear | Unclear | Low | Low | Unclear | Unclear
Donaldson 2008 | Unclear | Unclear | Low | Low | Low | Low | Unclear
Drotts 1999 | High | Unclear | Unclear | Low | Low | Unclear | High
Duarte 1992 | Unclear | Low | Low | Low | Low | Low | Unclear
Edwards 2001 | Unclear | High | High | Low | Low | Low | High
Engindeniz 2005 | Low | Low | Low | Low | Low | Low | Low
Fiesseler 2011 | Low | Low | Low | Low | Low | Low | Low
Frank 2004 | Low | Low | Low | Low | Low | Low | Low
Friedman 2006 | Low | Low | Low | Low | Low | Low | Low
Friedman 2008 | Low | Low | Low | Low | Low | Unclear | Unclear
Friedman 2005 | Low | Low | Low | Low | Low | Unclear | Unclear
Friedman 2007 | Low | Low | Low | Low | Low | Low | Low
Ginder 2000 | Low | Low | Low | Low | Low | Low | Low
Hill 2008 | Low | Low | Low | Unclear | Low | Low | Unclear
Hoag 1986 | Low | Unclear | High | Low | Low | Unclear | High
Honkaniemi 2006 | Unclear | Unclear | Unclear | Low | Low | Low | Unclear
Innes 1999 | Unclear | Low | Low | Low | Low | Low | Low
Jones 2003 | Unclear | Unclear | Unclear | Low | Low | Low | Unclear
Jones 1996 | Low | Low | Low | Low | Low | Low | Low
Jones 1989 | Low | Low | Low | Low | Low | Low | Low
Jovicic 1995 | Unclear | Unclear | Unclear | Low | Low | Unclear | Unclear
Karachalios 1992 | Unclear | Unclear | Unclear | Low | Low | Low | Unclear
Kelly 1997 | Unclear | Unclear | High | Low | Low | Low | High
Klapper 1991 | Unclear | Unclear | Unclear | Low | Low | Low | Unclear
Klapper 1991 | Unclear | Unclear | Low | Low | Low | Unclear | Unclear
Kostic 2010 | Low | Low | Low | Low | Low | Low | Low
Krymchantowski 2003 | Unclear | Unclear | High | Low | Low | Low | High
Lane 1989 | Unclear | Unclear | Unclear | Low | Low | Low | Unclear
Larkin 1992 | Low | Unclear | Low | Low | Low | Low | Unclear
Limmroth 1999 | High | Unclear | Unclear | Low | Low | Low | Unclear
McEwen 1987 | Unclear | Low | Low | Low | Low | Low | Unclear
Meredith 2003 | Low | Unclear | Low | Low | Low | Low | Unclear
Miller 2009 | Low | Unclear | Low | Low | Low | Low | Unclear
Miner 2001 | Low | Unclear | Low | Low | Unclear | Unclear | Unclear
Monzillo 2004 | Unclear | Unclear | Unclear | Low | Low | Unclear | Unclear
Mushet 1996 | Unclear | Unclear | Low | Low | Low | Low | Unclear
Richman 2002 | Unclear | Unclear | Low | Low | Unclear | Unclear | Unclear
Rowe 2008 | Low | Unclear | Low | Low | Low | Low | Unclear
Seim 1998 | Low | Unclear | Low | Low | Low | Low | Unclear
Shrestha 1996 | Low | Low | Low | Low | Low | Low | Low
Silberstein 2003 | Unclear | Unclear | Unclear | Low | Low | Low | Unclear
Stiell 1991 | Low | Low | Low | Low | Low | Low | Low
The Subcutaneous Sumatriptan International Study Group 1991 | Low | Unclear | Unclear | Low | Low | Low | Unclear
Tanen 2003 | Low | Low | Low | Low | Low | Low | Low
Teaheraghdam 2011 | Unclear | Unclear | Unclear | Low | Low | Low | Unclear
Tek 1987 | Low | Low | Low | Low | Low | Low | Low
Tek 1990 | Low | Low | Low | Unclear | Low | Low | Unclear
Thomson 1993 | Unclear | Unclear | Unclear | Low | Low | Low | Unclear
Vinson 2001 | Low | Low | Low | Low | Low | Low | Low
Weaver 2004 | Low | Low | Low | Low | Low | Unclear | Unclear
Wendt 2006 | Unclear | Unclear | Low | Low | Unclear | Low | Unclear
Winner 1996 | Unclear | Unclear | Unclear | Low | Low | Unclear | Unclear