# Excluded Studies

157 studies were excluded from the review. Reasons for exclusion include: publication type (n=15), study design (n=44), population (n=18), intervention (n=53), comparator (n=21), outcomes (n=4), and duplicate (n=2). In addition, we were unable to obtain copies of 5 studies.

## Publication type (n = 15)

1 IM Dihydroergotamine Comparable to Meperidine for Acute Migraine. Modern Medicine. 1998;66(10):19.
2 Migraine treatments: Acute. Headache: The Journal of Head &; Face Pain. 2005;45(4):401-2.
3 Bermejo PE, Pereda AF. Neuroleptics in the treatment of migraine. Med Clin (Barc). 2008;130(18):704-9. [pmid: 18501143].
4 Colman I, Brown MD, Innes GD, et al. Parenteral dihydroergotamine for acute migraine headache: A systematic review of the literature. Ann Emerg Med. 2005;45(4):393-401. [pmid: 15795718].
5 Colman I, Brown MD, Innes GD, et al. Parenteral metoclopramide for acute migraine: meta-analysis of randomised controlled trials. BMJ. 2004;329(7479):1369-73. [pmid: 15550401].
6 Colman I, Innes GD, Brown MD, et al. Parenteral corticosteroids for acute migraine. [Protocol]. Cochrane Database of Systematic Reviews. 2010;(4). 2011;(4).
7 Colman I, Innes GD, Brown MD, et al. Parenteral dihydroergotamine (DHE) for acute migraine. [Protocol]. Cochrane Database of Systematic Reviews. 2010;(4). 2011;(4).
8 Colman I, Innes GD, Brown MD, et al. Parenteral metoclopramide for acute migraine. [Protocol]. Cochrane Database of Systematic Reviews. 2010;(4). 2011;(4).
9 Dahlof C, Ekbom K, Persson L. Clinical experiences from Sweden on the use of subcutaneously administered sumatriptan in migraine and cluster headache. Arch Neurol. 1994;51(12):1256-61. [pmid: 7986182].
10 Friedman BW. Treatment of primary headache in the emergency department. Headache: The Journal of Head &; Face Pain. 2004;44(7):728-30.
11 Hay E. Treatment of migraine with sumatriptan in the ED [8]. Am J Emerg Med. 1994;12(3):388-389. [pmid: 8179764].
12 Kostic M, Gutierrez F, Rieg T, Moore T, Gendron R. A prospective, randomized trial of intravenous prochlorperazine versus subcutaneous sumatriptan in acute migraine therapy in the emergency department. Headache. 2010;50(5):892.
13 Suthisisang CC, Poolsup N, Suksomboon N, et al. Meta-Analysis of the Efficacy and Safety of Naproxen Sodium in the Acute Treatment of Migraine. Headache: The Journal of Head &; Face Pain. 2010;50(5):808-18.
14 Tepper SJ. Migraine treatment. Headache: The Journal of Head &; Face Pain. 2005;45(3):264-5.
15 Vinson DR. Emergency department treatment of migraine headaches. Arch Intern Med. 2002;162(7):845. [pmid: 11926869].

## Study design (n = 44)

1 Becker W, Riess C, Hoag J. Effectiveness of subcutaneous dihydroergotamine by home injection for migraine. Headache: The Journal of Head &; Face Pain. 1996;36(3):144-8.
2 Carpenter CR. Review: Adding dexamethasone to standard therapy reduces short-term relapse for acute migraine in the emergency department. Evidence Based Medicine. 2009;14(4):121. [pmid: 19648437].
3 Carpenter CR. Review: Adding dexamethasone to standard therapy reduces short-term relapse for acute migraine in the emergency department : What kind of randomized trials do patients and clinicians need. Ann Intern Med. 2009;2009(10).
4 Centre for Reviews and Dissemination. Does the addition of dexamethasone to standard therapy for acute migraine headache decrease the incidence of recurrent headache for patients treated in the emergency department: a meta-analysis and systematic review of the literature (Structured abstract). Database of Abstracts of Reviews of Effects. 2011;(2). 2011;(2).
5 Centre for Reviews and Dissemination. Parenteral dexamethasone for acute severe migraine headache: meta-analysis of randomised controlled trials for preventing recurrence (Structured abstract). Database of Abstracts of Reviews of Effects. 2011;(2). 2011;(2).
6 Centre for Reviews and Dissemination. The relative efficacy of phenothiazines for the treatment of acute migraine: a meta-analysis (Structured abstract). Database of Abstracts of Reviews of Effects. 2011;(2). 2011;(2).
7 Centre for Reviews and Dissemination. The relative efficacy of meperidine for the treatment of acute migraine: a meta-analysis of randomized controlled trials (Structured abstract). Database of Abstracts of Reviews of Effects. 2011;(2). 2011;(2).
8 Colman I, Friedman BW, Brown MD, et al. Parenteral dexamethasone for acute severe migraine headache: meta-analysis of randomised controlled trials for preventing recurrence. BMJ. 2008;336(7657):1359-61. [pmid: 18541610].
9 Derry S, Moore AR. Diclofenac with or without an antiemetic for acute migraine headaches in adults. [Protocol]. Cochrane Database of Systematic Reviews. 2010;(10). 2011;(10).
10 Derry S, Moore AR, McQuay HJ. Eletriptan for acute migraine headaches in adults. [Protocol]. Cochrane Database of Systematic Reviews. 2010;(4). 2010;(4).
11 Derry S, Moore AR, McQuay HJ. Naratriptan for acute migraine headaches in adults. [Protocol]. Cochrane Database of Systematic Reviews. 2010;(4). 2010;(4).
12 Derry S, Moore AR, McQuay HJ. Paracetamol (acetaminophen) with or without an antiemetic for acute migraine headaches in adults. [Systematic Review]. Cochrane Database of Systematic Reviews. 2011;(1). 2010;(1).
13 Derry S, Moore AR, McQuay HJ. Zolmitriptan for acute migraine headaches in adults. [Protocol]. Cochrane Database of Systematic Reviews. 2010;(4). 2010;(4).
14 Elstner M, Linn J, Muller-Schunk S, et al. Reversible cerebral vasoconstriction syndrome: A complicated clinical course treated with intra-arterial application of nimodipine. Cephalalgia. 2009;29(6):677-82. [pmid: 19239677].
15 Ferrari MD, Goadsby PJ, Roon KI, et al. Triptans (serotonin, 5-HT1B/1D agonists) in migraine: detailed results and methods of a meta-analysis of 53 trials. Cephalalgia. 2002;22(8):633-58. [pmid: 12383060].
16 Freitag FG, Diamond S, Diamond M, et al. Subcutaneous sumatriptan in patients treated with monoamine oxidase inhibitors and other prophylactic agents. Headache Quarterly. 1998;9(2):165-71.
17 Friedman BW, Kapoor A, Friedman MS, et al. The Relative Efficacy of Meperidine for the Treatment of Acute Migraine: A Meta-analysis of Randomized Controlled Trials. Ann Emerg Med. 2008;52(6):705-13. [pmid: 18632186].
18 Friedman D, Feldon S, Holloway R, et al. Utilization, Diagnosis, Treatment and Cost of Migraine Treatment in the Emergency Department. Headache: The Journal of Head &; Face Pain. 2009;49(8):1163-73.
19 Fullerton T, Gengo FM. Sumatriptan - A Selective 5-Hydroxytryptamine Receptor Agonist for the Acute Treatment of Migraine. Ann Pharmacother. 1992;26(6):800-8. [pmid: 1319244].
20 Gallagher RM. Emergency Treatment of Intractable Migraine. Headache: The Journal of Head &; Face Pain. 1985;25(3).
21 Gallagher RM. Emergency treatment of intractable migraine. Headache: The Journal of Head &; Face Pain. 1986;26(2):74-5.
22 Griffith JD, Mycyk MB, Kyriacou DN. Metoclopramide versus hydromorphone for the emergency department treatment of migraine headache. J Pain. 2008;9(1):88-94. [pmid: 17981511].
23 Hernansanz MAC, Roy RS, Orgaz AC, et al. Migraine treatment patterns and patient satisfaction with prior therapy: a substudy of a multicenter trial of rizatriptan effectiveness. Clin Ther. 2003;25(7):2053-69. [pmid: 12946550].
24 Kelly AM, Walcynski T, Gunn B. The Relative Efficacy of Phenothiazines for the Treatment of Acute Migraine: A Meta-Analysis. Headache: The Journal of Head &; Face Pain. 2009;49(9):1324-32.
25 Kirthi V, Derry S, Moore AR, et al. Aspirin with or without an antiemetic for acute migraine headaches in adults. [Systematic Review]. Cochrane Database of Systematic Reviews. 2010;(11). 2010;(11).
26 Lake AE III, Saper JR, Hamel RL. Comprehensive inpatient treatment of refractory chronic daily headache. Headache: The Journal of Head &; Face Pain. 2009;49(4):555-62.
27 Law S, Derry S, Moore AR. Triptans for acute cluster headache. [Systematic Review]. Cochrane Database of Systematic Reviews. 2011;(1). 2010;(1).
28 Ling R, Derry S, Moore AR, et al. Rizatriptan for acute migraine headaches in adults. [Protocol]. Cochrane Database of Systematic Reviews. 2010;(4). 2010;(4).
29 Lipton RB, Bigal ME, Goadsby PJ. Double-blind clinical trials of oral triptans vs other classes of acute migraine medication - a review. Cephalalgia. 2004;24(5):321-32. [pmid: 15096220].
30 Loder EW. Review: intravenous metoclopramide is better than placebo for reducing pain in acute migraine in the emergency department. ACP Journal Club. 2004;142(3):77. Jun. [pmid: 15862076].
31 Lofland JH, Johnson NE, Batenhorst AS, et al. Changes in resource use and outcomes for patients with migraine treated with sumatriptan: A managed care perspective. Arch Intern Med. 1999;159(8):857-63. [pmid: 10219932].
32 McCrory DC, Gray RN. Oral sumatriptan for acute migraine [Systematic Review]. Cochrane Database of Systematic Reviews. 2009;(1).
33 Oldman A, Smith LA, McQuay HJ, et al. Rizatriptan for acute migraine. [Systematic Review]. Cochrane Database of Systematic Reviews. 2011;(1). 2010;(1).
34 Richman PB, Reischel U, Ostrow A, et al. Droperidol for acute migraine headache. Am J Emerg Med. 1999;17(4):398-400. [pmid: 10452443].
35 Sahai-Srivastava S, Desai P, Zheng L. Analysis of headache management in a busy emergency room in the United States. Headache: The Journal of Head &; Face Pain. 2008;48(6):931-8.
36 Silberstein SD, Schulman EA, McFadden HM. Repetitive intravenous DHE in the treatment of refractory headache. Headache. 1990;30(6):334-39. [pmid: 2370132].
37 Singh A, Alter HJ, Zaia B. Does the addition of dexamethasone to standard therapy for acute migraine headache decrease the incidence of recurrent headache for patients treated in the emergency department? A meta-analysis and systematic review of the literature. Acad Emerg Med. 2008;15(12):1223-33. [pmid: 18976336].
38 Smith LA, Oldman A, McQuay HJ, et al. Eletriptan for acute migraine. [Systematic Review]. Cochrane Database of Systematic Reviews. 2011;(1). 2010;(1).
39 Takiya L, Piccininni LC, Kamath V. Safety and efficacy of eletriptan in the treatment of acute migraine. Pharmacotherapy. 2006;26(1):115-28. [pmid: 16506353].
40 Tfelthansen P. Sumatriptan for the Treatment of Migraine Attacks - A Review of Controlled Clinical-Trials. Cephalalgia. 1993;13(4):238-44. [pmid: 8397070].
41 Tornabene SV, Deutsch R, Davis DP, et al. Evaluating the Use and Timing of Opioids for the Treatment of Migraine Headaches in the Emergency Department. J Emerg Med. 2009;36(4):333-37. [pmid: 18280084].
42 Vinson DR. Treatment patterns of isolated benign headache in US emergency departments. Ann Emerg Med. 2002;39(3):215-22. [pmid: 11867972].
43 Vinson DR, Hurtado TR, Vandenberg JT, et al. Variations among emergency departments in the treatment of benign headache. Ann Emerg Med. 2003;41(1):90-7. [pmid: 12514688].
44 Visser WH, de Vriend RH, Jaspers MW, et al. Sumatriptan in clinical practice: a 2-year review of 453 migraine patients. Neurology. 1996;47(1):46-51. [pmid: 8710123].

## Population (n = 18)

1 Aurora SK, Rozen TD, Kori SH, et al. A randomized, double blind, placebo-controlled study of MAP0004 in adult patients with migraine. Headache: The Journal of Head &; Face Pain. 2009;49(6):826-37.
2 Barrajon E, de las PR. Randomised double blind crossover study comparing ondansetron, granisetron and tropisetron. A cost-benefit analysis. Support Care Cancer. 2000;8(4):323-33. [pmid: 10923774].
3 Bell CF, Foley KA, Barlas S, et al. Time to pain freedom and onset of pain relief with rizatriptan 10 mg and prescription usual-care oral medications in the acute treatment of migraine headaches: A multicenter, prospective, open-label, two-attack, crossover study. Clin Ther. 2006;28(6):872-80. [pmid: 16860170].
4 Bigal ME, Bordini CA, Speciali JG. Intravenous chlorpromazine in the acute treatment of episodic tension-type headache: a randomized, placebo controlled, double-blind study. Arq Neuropsiquiatr. 2002;60(3-A):537-41. [pmid: 12244386].
5 Bouchard J, Cortelli P, Dahlof C, et al. A multinational investigation of the impact of subcutaneous sumatriptan. 4. Patient satisfaction. Pharmacoeconomics. 1997;11:43-50. [pmid: 10168042].
6 Carpay H, Matthijsse P, Steinbuch M, et al. Oral and subcutaneous sumatriptan in the acute treatment of migraine: An open randomized cross-over study. Cephalalgia. 1997;17(5):591-5. [pmid: 9251875].
7 Carpenter CR. ACP Journal Club. Review: Adding dexamethasone to standard therapy reduces short-term relapse for acute migraine in the emergency department. Ann Intern Med. 2009;150(10):JC5-11. [pmid: 19451567].
8 Cohen JA, Beall D, Beck A, et al. Sumatriptan treatment for migraine in a health maintenance organization: economic, humanistic, and clinical outcomes. Clin Ther. 1999;21(1):190-204. [pmid: 10090435].
9 Dahlof C, Bouchard J, Cortelli P, et al. A multinational investigation of the impact of subcutaneous sumatriptan. Pharmacoeconomics. 1997;11:24-34. [pmid: 10168040].
10 Del BE, Poggioni M, Garagiola U, et al. Intramuscular treatment of migraine attacks using diclofenac sodium: a crossover clinical trial. J Int Med Res. 1987;15(1):44-8. [pmid: 3545942].
11 Ekbom K. Treatment of Acute Cluster Headache with Sumatriptan. N Engl J Med. 1991;325(5):322-6. [pmid: 1647496].
12 Friedman BW, Greenwald P, Bania TC, et al. A randomized placebo-controlled trial of intravenous corticosteroids for the treatment of migraine in the emergency department. Headache: The Journal of Head &; Face Pain. 2007;47(5):749-50.
13 Hakkarainen H, Allonen H. Ergotamine vs. metoclopramide vs. their combination in acute migraine attacks. Headache: The Journal of Head &; Face Pain. 1982;22(1):10-2.
14 Landy SH, McGinnis JE, McDonald SA. Pilot study evaluating preference for 3-mg versus 6-mg subcutaneous sumatriptan. Headache: The Journal of Head &; Face Pain. 2005;45(4):346-9.
15 McCarthy BG, Peroutka SJ. Comparative neuropharmacology of dihydroergotamine and sumatriptan. Headache: The Journal of Head &; Face Pain. 1989;29(7):420-2.
16 Raskin NH. Repetitive intravenous dihydroergotamine as therapy for intractable migraine. Neurology. 1986;36(7):995-7. [pmid: 3520384].
17 Saadah HA. Abortive migraine therapy in the office with dexamethasone and prochlorperazine. Headache: The Journal of Head &; Face Pain. 1994;34(6):366-70.
18 Sumatriptan Cluster Headache Study Group. Treatment of Acute Cluster Headache with Sumatriptan. N Engl J Med. 1991;325(5):322-6. [pmid: 1647496].

## Intervention (n = 53)

1 Bigal M, Rapoport A, Aurora S, et al. Satisfaction with current migraine therapy: Experience from 3 centers in US and Sweden. Headache: The Journal of Head &; Face Pain. 2007;47(4):475-9.
2 Bigal ME, Bordini CA, Speciali JG. Headache treatment in an emergency unit of the city of Ribeirao Preto, Brazil. [Portuguese]. Arq Neuropsiquiatr. 1999;57(3B):813-9. [pmid: 10751917].
3 Blumenfeld A. botulinum toxin type A as an effective prophylactic treatment in primary headache disorders. Headache: The Journal of Head &; Face Pain. 2003;43(8):853-60.
4 Burke-Ramirez P, Asgharnejad M, Webster C, et al. Efficacy and tolerability of subcutaneous sumatriptan for acute migraine: A comparison between ethnic groups. Headache: The Journal of Head &; Face Pain. 2001;41(9):873-82.
5 Cady RK, Rubino J, Crummett D, et al. Oral sumatriptan in the treatment of recurrent headache. Arch Fam Med. 1994;3(9):766-72. [pmid: 7987510].
6 Cady RK, Gutterman D, Saiers JA, et al. Responsiveness of non-IHS migraine and tension-type headache to sumatriptan. Cephalalgia. 1997;17(5):588-90. [pmid: 9251874].
7 Cagle J, Krusz JC, Krusz JC, et al. IV lidocaine for treatment of refractory migraines and headaches in the outpatient clinic. Cephalalgia. 2007;27(6):750.
8 Cohen JA, Beall DG, Miller DW, et al. Subcutaneous sumatriptan for the treatment of migraine: humanistic, economic, and clinical consequences. Family Medicine. 1996;28(3):171-7. [pmid: 8900548].
9 Da Costa AR, Monzillo PH, Sanvito WL. Use of chlorpromazine in the treatment of headache at an emergency service. [Portuguese]. Arq Neuropsiquiatr. 1998;56(3B):565-8. [pmid: 9850751].
10 Da Costa AR, Monzillo PH, Sanvito WL. Intravenous chlorpromazine for the treatment of acute headache. [Portuguese]. Arquivos de Neuro-Psiquiatria. 1998;56(3 B):565-68. [pmid: 9850751].
11 Davis CP, Torre PR, Schafer NC, et al. Ketorolac as a rapid and effective treatment of migraine headache: evaluations by patients. Am J Emerg Med. 1993;11(6):573-5. [pmid: 8240554].
12 Dexter SL, Graham AN, Johnston ES, et al. Double-blind controlled study of paramax in the acute treatment of common and classical migraine. Br J Clin Pract. 1985;39(10):388-92. [pmid: 3907680].
13 Diamond S. Treatment of migraine with isometheptene, acetaminophen, and dichloralphenazone combination: a double-blind, crossover trial. Headache: The Journal of Head &; Face Pain. 1976;15(4):282-7.
14 Dodick DW, Mauskop A, Elkind AH, et al. Botulinum toxin type A for the prophylaxis of chronic daily headache: Subgroup analysis of patients not receiving other prophylactic medications: A randomized double-blind, placebo-controlled study. Headache: The Journal of Head &; Face Pain. 2005;45(4):315-24.
15 Dodick DW. Botulinum neurotoxin for the treatment of migraine and other primary headache disorders: From bench to bedside. Headache: The Journal of Head &; Face Pain. 2003;43(Supplement 1):S25-S33.
16 Elstner M, Linn J, Muller-Schunk S, et al. Reversible cerebral vasoconstriction syndrome: A complicated clinical course treated with intra-arterial application of nimodipine. Cephalalgia. 2009;29(6):677-82. [pmid: 19239677].
17 Eross EJ, Gladstone JP, Lewis S, et al. Duration of migraine is a predictor for response to botulinum toxin type A. Headache: The Journal of Head &; Face Pain. 2005;45(4):308-14.
18 Ferrari A, Pinetti D, Bertolini A, et al. Interindividual variability of oral sumatriptan pharmacokinetics and of clinical response in migraine patients. Eur J Clin Pharmacol. 2008;64(5):489-95. [pmid: 18180912].
19 Friedman BW, Hochberg ML, Esses D, et al. Recurrence of Primary Headache Disorders After Emergency Department Discharge: Frequency and Predictors of Poor Pain and Functional Outcomes. Ann Emerg Med. 2008;52(6):696-704. [pmid: 18387702].
20 Friedman BW, Solorzano C, Esses D, et al. Treating headache recurrence after emergency department discharge: a randomized controlled trial of naproxen versus sumatriptan. Ann Emerg Med. 2010;56(1):7-17. [pmid: 20303198].
21 Gruffydd-Jones K, Hood CA, Price DB. A within-patient comparison of subcutaneous and oral sumatriptan in the acute treatment of migraine in general practice. Cephalalgia. 1997;17(1):31-6. [pmid: 9051333].
22 Henry P, D’Allens H, Migraine F. Subcutaneous sumatriptan in the acute treatment of migraine in patients using dihydroergotamine as prophylaxis. Headache: The Journal of Head &; Face Pain. 1993;33(8):432-5.
23 Hirata K, Tatsumoto M, Araki N, et al. Multi-center randomized control trial of etizolam plus NSAID combination for tension-type headache. Intern Med. 2007;46(8):467-72. [pmid: 17443036].
24 Jakubowski M, Levy D, Goor-Aryeh I, et al. Terminating migraine with allodynia and ongoing central sensitization using parenteral administration of COX1/COX2 inhibitors. Headache: The Journal of Head &; Face Pain. 2005;45(7):850-61.
25 Jensen R, Brinck T, Olesen J. Sodium valproate has a prophylactic effect in migraine without aura: a triple-blind, placebo-controlled crossover study. Neurology. 1994;44(4):647-51. [pmid: 8164818].
26 Jhingran P, Cady RK, Rubino J, et al. Improvements in health-related quality of life with sumatriptan treatment for migraine. J Fam Pract. 1996;42(1):36-42. [pmid: 8537803].
27 Krusz JC, Cagle J, Scott VB. IV ketamine treatment for refractory migraines and pain in the outpatient clinic. Ann Neurol. 2008;64(Suppl 12):S27.
28 Krymchantowski AV, Barbosa J. Rizatriptan combined with rofecoxib vs. rizatriptan for the acute treatment of migraine: An open label pilot study. Cephalalgia. 2002;22(4):309-12. [pmid: 12100094].
29 Krymchantowski AV, Barbosa JS. Dexamethasone decreases migraine recurrence observed after treatment with a triptan combined with a nonsteroidal anti-inflammatory drug. Arq Neuropsiquiatr. 2001;59(3B):708-11. [pmid: 11593269].
30 Krymchantowski AV, Barbosa J. Intravenous lysine clonixinate for the acute treatment of migraine: an open pilot study. Arq Neuropsiquiatr. 1999;57(3A):606-9. [pmid: 10667284].
31 Leinisch E, Evers S, Kaempfe N, et al. Evaluation of the efficacy of intravenous acetaminophen in the treatment of acute migraine attacks: a double-blind, placebo-controlled parallel group multicenter study. Pain. 2005;117(3):396-400. [pmid: 16153780].
32 Linde M, Mellberg A, Dahlof C. Subcutaneous sumatriptan provides symptomatic relief at any pain intensity or time during the migraine attack. Cephalalgia. 2006;26(2):113-21. [pmid: 16426264].
33 Mathew NT, Jaffri SFA. A Double-Blind Comparison of OnabotulinumtoxinA (Botox R) and Topiramate (Topamax R) for the Prophylactic Treatment of Chronic Migraine: A Pilot Study. Headache: The Journal of Head &; Face Pain. 2009;49(10):1466-78.
34 Mathew NT, Kailasam J. Repetitive intravenous administration of valproate sodium in intractable migraine: comparison with intravenous dihydroergotamine (DHE). Cephalalgia. 2000;20(4):351.
35 Mauskop A, Altura BT, Cracco RQ, et al. Intravenous magnesium sulfate rapidly alleviates headaches of various types. Headache: The Journal of Head &; Face Pain. 1996;36(3):154-60.
36 Mendizabal JE, Watts JM, Riaz S, et al. Open-label intramuscular droperidol for the treatment of refractory headache: A pilot study. Headache Quarterly-Current Treatment and Research. 1999;10(1):55-7.
37 Millan-Guerrero R, Isais-Millan R, Barreto-Vizcaino S, et al. Subcutaneous histamine versus sodium valproate in migraine prophylaxis: a randomized, controlled, double-blind study. Eur J Neurol. 2007;14(10):1079-84. [pmid: 17880560].
38 Moghadam AH, Zarei H, Seifaddini R, et al. Outpatient treatment of migraine headache, can we use a dexamethasone containing regimen?. Journal of Research in Medical Sciences. 2008;13(5):264-67.
39 Morey V, Rothrock JF. Examining the utility of in-clinic “rescue” therapy for acute migraine. Headache: The Journal of Head &; Face Pain. 2008;48(6):939-43.
40 Nino-Maldonado AI, Caballero-Garcia G, Mercado-Bochero W, et al. Efficacy and tolerability of intravenous methylergonovine in migraine female patients attending the emergency department: a pilot open-label study. Head &; Face Medicine. 2009;5:21.
41 O’Quinn S, Davis RL, Gutterman DL, et al. Prospective large-scale study of the tolerability of subcutaneous sumatriptan injection for acute treatment of migraine. Cephalalgia. 1999;19(4):223-31. [pmid: 10376167].
42 Peroutka SJ, Lyon JA, Swarbrick J, et al. Research submissions efficacy of diclofenac sodium softgel 100 mg with or without caffeine 100 mg in migraine without aura: a randomized, double-blind, crossover study. Headache: The Journal of Head &; Face Pain. 2004;44(2):136-41.
43 Pietrini U, De Luca M, Del Bene E, et al. Prophylactic activity of increasing doses of intravenous histamine in refractory migraine: Retrospective observations of a series of patients with migraine without aura. Current Therapeutic Research-Clinical and Experimental. 2004;65(1):70-8.
44 Pradalier A, Guerard des LA, Scheck F, et al. Calcium carbasalate-metoclopramide combination versus dihydroergotamine in the treatment of migraine attacks. Pathol Biol (Paris). 1995;43(9):806-13. [pmid: 8746103].
45 Ryan R, Elkind A, Baker CC, et al. Sumatriptan nasal spray for the acute treatment of migraine - Results of two clinical studies. Neurology. 1997;49(5):1225-30. [pmid: 9371898].
46 Sargent JD, Baumel B, Peters K, et al. Aborting a migraine attack: naproxen sodium v ergotamine plus caffeine. Headache: The Journal of Head &; Face Pain. 1988;28(4):263-6.
47 Smuts J, Barnard P. Botulinum toxin type A in the treatment of headache syndromes: A clinical report on 79 patients. Cephalalgia. 2000;20(4):332.
48 Sostak P, Krause P, Forderreuther S, et al. Botulinum toxin type-A therapy in cluster headache: an open study. Journal of Headache and Pain. 2007;8(4):236-41. [pmid: 17901920].
49 Straube A, Empl M, Ceballos-Baumann A, et al. Pericranial injection of botulinum toxin type A (Dysport (R) for tension-type headache - A multicentre, double-blind, randomized, placebo-controlled study. Eur J Neurol. 2008;15(3):205-13. [pmid: 18290842].
50 The Multinational Oral Sumatriptan and Cafergot Comparative Study Group. A randomized, double-blind comparison of sumatriptan and Cafergot in the acute treatment of migraine. Eur Neurol. 1991;31(5):314-22. [pmid: 1653139].
51 Thomas SH, Stone CK, Ray VG, et al. Intravenous versus rectal prochlorperazine in the treatment of benign vascular or tension headache: a randomized, prospective, double-blind trial. Ann Emerg Med. 1994;24(5):923-7. [pmid: 7978566].
52 Wang SJ, Silberstein SD, Young WB. Droperidol treatment of status migrainosus and refractory migraine. Headache: The Journal of Head &; Face Pain. 1997;37(6):377-82.
53 Weidmann E, Unger J, Blair S, et al. An open-label study to assess changes in efficacy and satisfaction with migraine care when patients have access to multiple sumatriptan succinate formulations. Clinical Therapeutics. 2003;25(1):235-246. [pmid: 12637123].

## Comparator (n = 21)

1 Ametrano P, Ansaloni MC, Bolognesi AG. Essential headache in the emergency department. [Italian]. Confinia Cephalalgica. 1995;4(3):79-82.
2 Cady RK, Dexter J, Sargent JD, et al. Efficacy of Subcutaneous Sumatriptan in Repeated Episodes of Migraine. Neurology. 1993;43(7):1363-8. [pmid: 8392150].
3 Cagle J, Krusz JC. IV tramadol for treatment of refractory headache in the clinic. Cephalalgia. 2007;27(6):750.
4 Cagle J, Scott-Krusz V, Cammarata D, et al. IV tramadol for treating refractory migraines and migraines in the outpatient clinic. Headache: The Journal of Head &; Face Pain. 2007;47(5):754.
5 Friedman BW, Mulvey L, Esses D, et al. Metoclopramide for acute migraine: a dose-finding randomized clinical trial. Ann Emerg Med. 2011;57(5):475-82. [pmid: 21227540].
6 Harden RN, Carter TD, Gilman CS, et al. Ketorolac in acute headache management. Headache: The Journal of Head &; Face Pain. 1991;31(7):463-4.
7 Hernandez NL, Guitart JM, Martinez VM, et al. Prevention of migraine: A pharamacoepidemiological study. [Spanish]. Neurologia. 2009;24(2):98-101. [pmid: 19322687].
8 Iserson KV. Parenteral chlorpromazine treatment of migraine. Ann Emerg Med. 1983;12(12):756-8. [pmid: 6359974].
9 Krusz JC. Intravenous valproate sodium in the treatment of migraine headaches in the headache clinic. Headache Quarterly-Current Treatment and Research. 2001;12(1):39-41.
10 Krusz JC, Cagle J, Scott V. Intravenous valproate for treatment of status migrainosus in the headache clinic: A retrospective look. Headache and Pain: Diagnostic Challenges, Current Therapy. 2006;17(3):121-23.
11 Krusz JC, Scott-Krusz V, Hall SK, et al. Intravenous (IV) ketamine for mixed migraine and pain disorders in the clinic. Headache: The Journal of Head &; Face Pain. 2008;48:S51.
12 Parlak I, Erdur B, Parlak M, et al. Intravenous administration of metoclopramide by 2 min bolus vs 15 min infusion: does it affect the improvement of headache while reducing the side effects?. Postgrad Med J. 2007;83(984):664-8. [pmid: 17916877].
13 Popeney C. Depacon and P.O Depakote ER for treatment of status migrainosis and prevention of episodic migraine. Cephalalgia. 2003;23(7):625-6.
14 Popeney CA. I.V Depacon and P.O. Depakote ER for treatment of status migrainosis and prevention of episodic migraine. Cephalalgia. 2003;23(7):739.
15 Rowat BM, Merrill CF, Davis A, et al. A double-blind comparison of granisetron and placebo for the treatment of acute migraine in the emergency department. Cephalalgia. 1991;11(5):207-13. [pmid: 1663423].
16 Saadah HA. Abortive headache therapy in the office with intravenous dihydroergotamine plus prochlorperazine. Headache: The Journal of Head &; Face Pain. 1992;32(3):143-6.
17 Saadah HA. Abortive headache therapy with intramuscular dihydroergotamine. Headache: The Journal of Head &; Face Pain. 1992;32(1):18-20.
18 Salazar-Tortolero G, Huertas-Campistol A, Vergez-Pinto L, et al. Metoclopramide as a painkiller for intense migraine headache in emergency departments. [Spanish]. Rev Neurol. 2008;47(10):506-8. [pmid: 19012253].
19 Seviour C, Harrison D. Incidence of Akathisia from Intravenous Metoclopramide for Migraine. Academic Emergency Medicine. 2000;7:536b.
20 Valade D, Lucas C, Calvel L, et al. Migraine diagnosis and management in general emergency departments in France. Cephalalgia. 2011;31(4):471-80. [pmid: 20670996].
21 Vinson DR, Migala AF, Quesenberry CP Jr. Slow infusion for the prevention of akathisia induced by prochlorperazine: a randomized controlled trial. J Emerg Med. 2001;20(2):113-9. [pmid: 11207403].

## Outcomes (n = 4)

1 Gobel H, Krapat S, Ensink FBM, et al. Comparison of Contingent Negative-Variation Between Migraine Interval and Migraine Attack Before and After Treatment with Sumatriptan. Headache: The Journal of Head &; Face Pain. 1993;33(10):570-2.
2 Harden RN, Gracely RH, Carter T, et al. The placebo effect in acute headache management: ketorolac, meperidine, and saline in the emergency department. Headache: The Journal of Head &; Face Pain. 1996;36(6):352-6.
3 Klapper JA, Stanton J. Current Emergency Treatment of Severe Migraine Headaches. Headache: The Journal of Head &; Face Pain. 1993;33(10):560-2.
4 Parlak I, Atilla R, Cicek M, et al. Rate of metoclopramide infusion affects the severity and incidence of akathisia. Emerg Med J. 2005;22(9):621-4. [pmid: 16113179].

## Duplicate (n = 2)

1 Akpunonu BE, Mutgi AB, Federman DJ, et al. Subcutaneous sumatriptan for treatment of acute migraine in patients admitted to the emergency department: a multicenter study. [Erratum appears in Ann Emerg Med 1995 Jun;25(6):857]. Ann Emerg Med. 1995;25(4):464-9. [pmid: 7710149].
2 Bigal M, Bordini CA, Speciali JG. Intravenous chlorpromazine in the Emergency Department treatment of migraines: A randomized controlled trial. Journal of Emergency Medicine. 2002;23(2):141-48. [pmid: 12359281].