# Sample Forms

B.1 Inclusion Criteria Worksheet: Acute migraine review

B.2 Data extraction form: Acute migraine review

B.3 Risk of Bias: Acute migraine review