# Search Strategies

Table A1 Acute migraine review - Ovid MEDLINE(R)

Version: OvidSP_UI03.04.00.105, SourceID 54178 Years/issue searched: 1948 to June Week 1 2011 Search date: June 13, 2011 Limits: “all adult (19 plus years)”; human Results: 209 Deduped: 196
1. Migraine Disorders/; 2. migraine with aura/; 3. migraine without aura/; 4. Headache/; 5. exp Headache Disorders/; 6. migrain$.mp.; 7. (headach$ or head-ach$).tw.; 8. (cephalgi$ or cephalalgi$).tw.; 9. or/1–8; 10. exp serotonin 5-HT1 receptor agonists/; 11. sumatript$.mp.; 12. zolmitript$.mp.; 13. rizatrip$.mp.; 14. eletript$.mp.; 15. naratript$.mp.; 16. almotript$.mp.; 17. frovatript$.mp.; 18. exp ergot alkaloids/; 19. dihydroergotami$.mp.; 20. DHE.tw.; 21. ergotami$.mp.; 22. exp analgesics, non-narcotic/; 23. acetaminophen.mp.; 24. (acetaminofeno or acetominophen or apap or asetaminofen or paracetamol or paracetamolis or paracetamolum or parasetamol or parasetamoli).tw.; 25. exp anti-inflammatory agents, non-steroidal/; 26. (NSAIA? or NSAID?).tw.; 27. ((nonsteroidal or non-steroidal) adj anti-inflammator$).tw.; 28. aspirin.mp.; 29. (acetylsalicylic acid or ASA).tw.; 30. (acetilsalicilico or acetilszalicilsav or acetylsalicyl$ or asetilsalisilik or asetyylisalisyylihappo or acetylosalicylowy).tw.; 31. diclofen$.mp.; 32. (diklofen$ or diclophen$).tw.; 33. ibuprofen$.mp.; 34. ibuprofeeni.tw.; 35. (ketoprof$ or dexketoprofeno).mp.; 36. ketorola$.mp.; 37. naprox$.mp.; 38. naprok$.tw.; 39. exp analgesics, opioid/; 40. exp narcotics/; 41. morphine/; 42. (morphin* or morfiini* or morfin*).mp.; 43. buprenorphin*.mp.; 44. butorphanol$.mp.; 45. butorfanol$.tw.; 46. codein$.mp.; 47. (kodeiini or kodein or kodeina or kodeinas or methylmorphine or metilmorfina or morphine methyl ether).tw.; 48. fentanyl.mp.; 49. hydromorphon*.mp.; 50. meperidin$.mp.; 51. (pethidin$ or petidiinihydrokloridi or petidin$ or petidinhydroklorid or petydyny).tw.; 52. nalbuphin$.mp.; 53. nalbufin$.tw.; 54. tramadol$.mp.; 55. propofol$.mp.; 56. disoprofol.tw.; 57. ketamin$.mp.; 58. valproic acid/; 59. (acide valproique or acido dipropilacetico or acido valproico or acidum valproicum or dipropylacetic acid or DPA or kyselina valproova or natrii valproas or natrio valproatas or natriumvalproaatti or natriumvalproat or natrium-valproat or valproat$ or valproic acid or valproiinihappo or valproik asit or valproine rugutis or valproinsav or valproinsyra).tw.; 60. exp antiemetics/; 61. (antiemetic$ or anti-emetic$).tw.; 62. haloperidol/; 63. (haloperidol* or aloperidolo).mp.; 64. Trimethobenzamide.mp.; 65. exp Phenothiazines/; 66. chlorpromazin$.mp.; 67. (klooripromatsiini$ or klorpromazin$ or aminazine or chlor#promaz$).tw.; 68. promethazin$.mp.; 69. (prometatsiini or prometazin or prometazina or promethazinum).tw.; 70. methotrimeprazin$.mp.; 71. (levomeproma$ or lewomepromazyny).tw.; 72. prochlorperazin$.mp.; 73. (chlormeprazine or prochlorpemazine or proklooriperatsiini or proklorperazin).tw.; 74. ondansetron$.mp.; 75. droperidol$.mp.; 76. metoclopramid$.mp.; 77. metoklopramid$.tw.; 78. domperidon$.mp.; 79. exp histamine h1 antagonists/; 80. diphenhydramin$.mp.; 81. (benzhydramin$ or difenhidramin$ or difenhydramiinihydrokloridi or difenhydramin$ or dimedrolum).tw.; 82. dimenhydrinat$.mp.; 83. (chloranautine or dimenhidrinat$ or dimenhydramina or dimenhydrina$ or diphenhydramin$).tw.; 84. butalbital$.mp.; 85. (alisobumalum or allylbarbit$ or butalbitaali or butalbitalum or itobarbital or tetrallobarbital).tw.; 86. Botulinum Toxins, Type A/; 87. (Botuliinitoksiini tyyppi A or Botulinum Toxin Type A or Botulinum A Toksini or Toxin typ A mot botulism or Toxina botulinica A or Toxine botulinique type A or Toxinum Botulinicum Typum A).tw.; 88. lidocain$.mp.; 89. (lidokaiini or lidokain$ or lignocain$).tw.; 90. xylocain$.tw.; 91. oxygen.mp.; 92. nitric oxide/ or nitrous oxide/; 93. ((nitric or nitrous) adj oxide).tw.; 94. magnesium sulfate/; 95. (magnesium adj (sulfat$ or sulphat$)).tw.; 96. drug therapy, combination/; 97. drug combinations/; 98. combined modality therapy/; 99. placebo$.mp.; 100. (pharmacologic adj manag$).tw.; 101. (abortive adj therap$).tw.; 102. or/10–101; 103. cortisone/; 104. (coritson* or kortison* or kortizon* or kortyzon*).mp.; 105. exp glucocorticoids/; 106. glucocorticoid?.tw.; 107. (corticosteroid? or steroid$).tw.; 108. betamethason$.mp.; 109. (beetametasoni or betadexamethasone or betametason$ or betametazon$ or flubenisolon$).tw.; 110. (budesonid* or budezonid*).mp.; 111. dexamethason$.mp.; 112. (deksametason$ or desamethason$ or dexametason$ or dexametazon$ or hexadecadrol).tw.; 113. hydrocortison$.mp.; 114. (cortisol or hidrocortisona or hidrokortizon$ or hydrocortisonum or hydrokortison$ or hydrokortyzon).tw.; 115. methylprednisolon$.mp.; 116. (meilprednizolon or methyl-prednisolon$ or metilprednisolon$ metilprednizolonas or metylprednisolon or metyyliprednisoloni).tw.; 117. prednisolon$.mp.; 118. (deltahydrocortisone or metacortandralone or prednizolon$).tw.; 119. prednison$.mp.; 120. (deltacortisone or deltadehydrocortisone or metacortandracin or prednizon$).tw.; 121. triamcinolon$.mp.; 122. (fluoxiprednisolonum or triamcynolon or triamsinoloni).tw.; 123. or/103–122; 124. or/10–122; 125. Injections, Intramuscular/; 126. Injections, Intravenous/; 127. Injections, Subcutaneous/; 128. Infusions, Intravenous/; 129. Infusions, Parenteral/; 130. (IM or intramuscular$ or intra-muscular$).tw.; 131. (IV or intravenous$ or intra-venous$).tw.; 132. (SC or subcutan$ or sub-cutan$ or sub-cu?).tw.; 133. (parenteral$ adj2 (inject$ or administ$ or therap$ or treatment?)).tw.; 134. or/125–133; 135. Emergency Treatment/; 136. Emergency Service, Hospital/; 137. Emergency Medical Services/; 138. Emergencies/; 139. Ambulatory Care Facilities/; 140. Community Health Centers/; 141. exp Outpatient Clinics, Hospital/; 142. Community Health Services/; 143. exp General Practice/; 144. Primary Health Care/; 145. ((emerg or emergenc$) adj3 (department? or ward? or service? or unit? or room? or hospital? or care or medicin$ or treatment? or admission?)).tw.; 146. ED?.tw.; 147. ER?.tw.; 148. (ambulatory adj2 (clinic? or care or centre? or center? or service?)).tw.; 149. ((out-patient or outpatient) adj2 (clinic? or care or centre? or center? or service?)).tw.; 150. (community adj2 (service? or care)).tw.; 151. (primary adj2 care).tw.; 152. (urgent adj2 care).tw.; 153. ((pain or headache or head-ache or walkin or walk-in) adj2 (clinic? or centre? or center? or service? or unit?)).tw.; 154. or/135–153; 155. and/9,124,134,154; 156. limit 155 to “all adult (19 plus years)”; 157. exp animals/ not humans.sh.; 158. 156 not 157; 159. (comment or editorial or letter).pt.; 160. 158 not 159; 161. remove duplicates from 160; 162. and/102,134; 163. or/123,162; 164. and/9,154,163; 165. limit 164 to “all adult (19 plus years)”; 166. 165 not 161

Table A2 Acute migraine review - EMBASE

Version: OvidSP_UI03.04.00.105, SourceID 54178 Years/issue searched: 1980 to 2011 Week 23 Search date: June 13, 2011 Limits: (adult <18 to 64 years> or aged <65+ years>) Results: 480 Deduped: 329
1. exp migraine/; 2. headache/; 3. migrain$.mp.; 4. (headach$ or head-ach$).tw.; 5. (cephalgi$ or cephalalgi$).tw.; 6. or/1–5; 7. exp antimigraine agent/; 8. exp serotonin agonist/; 9. sumatript$.mp.; 10. zolmitript$.mp.; 11. rizatrip$.mp.; 12. eletript$.mp.; 13. naratript$.mp.; 14. almotript$.mp.; 15. frovatript$.mp.; 16. ergot alkaloid/; 17. dihydroergotami$.mp.; 18. DHE.tw.; 19. ergotami$.mp.; 20. exp analgesic agent/; 21. acetaminophen.mp.; 22. (acetaminofeno or acetominophen or apap or asetaminofen or paracetamol or paracetamolis or paracetamolum or parasetamol or parasetamoli).tw.; 23. exp nonsteroid antiinflammatory agent/; 24. (NSAIA? or NSAID?).tw.; 25. ((nonsteroidal or non-steroidal) adj anti-inflammator$).tw.; 26. aspirin.mp.; 27. (acetylsalicylic acid or ASA).tw.; 28. (acetilsalicilico or acetilszalicilsav or acetylsalicyl$ or asetilsalisilik or asetyylisalisyylihappo or acetylosalicylowy).tw.; 29. diclofen$.mp.; 30. (diklofen$ or diclophen$).tw.; 31. ibuprofen$.mp.; 32. ibuprofeeni.tw.; 33. (ketoprof$ or dexketoprofeno).mp.; 34. ketorola$.mp.; 35. naprox$.mp.; 36. naprok$.tw.; 37. exp narcotic agent/; 38. exp opioid agonist/; 39. butorphanol/; 40. buprenorphin$.mp.; 41. butorphanol$.mp.; 42. butorfanol$.tw.; 43. codein$.mp.; 44. fentanyl.mp.; 45. hydromorphon*.mp.; 46. (kodeiini or kodein or kodeina or kodeinas or methylmorphine or metilmorfina or morphine methyl ether).tw.; 47. meperidin$.mp.; 48. morphin*.mp.; 49. (pethidin$ or petidiinihydrokloridi or petidin$ or petidinhydroklorid or petydyny).tw.; 50. nalbuphin$.mp.; 51. nalbufin$.tw.; 52. tramadol$.mp.; 53. propofol$.mp.; 54. disoprofol.tw.; 55. ketamin$.mp.; 56. valproic acid/; 57. (acide valproique or acido dipropilacetico or acido valproico or acidum valproicum or dipropylacetic acid or DPA or kyselina valproova or natrii valproas or natrio valproatas or natriumvalproaatti or natriumvalproat or natrium-valproat or valproat$ or valproic acid or valproiinihappo or valproik asit or valproine rugutis or valproinsav or valproinsyra).tw.; 58. exp antiemetics/; 59. exp antiemetic agent/; 60. (antiemetic$ or anti-emetic$).tw.; 61. exp trimethobenzamide/; 62. trimethobenzamid*.mp.; 63. haloperidol/; 64. (haloperidol* or aloperidol*).mp.; 65. exp phenothiazine derivative/; 66. chlorpromazin$.mp.; 67. (klooripromatsiini$ or klorpromazin$ or aminazine or chlor#promaz$).tw.; 68. promethazin$.mp.; 69. (prometatsiini or prometazin or prometazina or promethazinum).tw.; 70. methotrimeprazin$.mp.; 71. (levomeproma$ or lewomepromazyny).tw.; 72. prochlorperazin$.mp.; 73. (chlormeprazine or prochlorpemazine or proklooriperatsiini or proklorperazin).tw.; 74. ondansetron$.mp.; 75. droperidol$.mp.; 76. metoclopramid$.mp.; 77. metoklopramid$.tw.; 78. domperidon$.mp.; 79. exp histamine H1 receptor antagonist/; 80. diphenhydramin$.mp.; 81. (benzhydramin$ or difenhidramin$ or difenhydramiinihydrokloridi or difenhydramin$ or dimedrolum).tw.; 82. dimenhydrinat$.mp.; 83. (chloranautine or dimenhidrinat$ or dimenhydramina or dimenhydrina$ or diphenhydramin$).tw.; 84. butalbital$.mp.; 85. (alisobumalum or allylbarbit$ or butalbitaali or butalbitalum or itobarbital or tetrallobarbital).tw.; 86. botulinum toxin A/; 87. (Botuliinitoksiini tyyppi A or Botulinum Toxin Type A or Botulinum A Toksini or Toxin typ A mot botulism or Toxina botulinica A or Toxine botulinique type A or Toxinum Botulinicum Typum A).tw.; 88. lidocain$.mp.; 89. (lidokaiini or lidokain$ or lignocain$).tw.; 90. xylocain$.tw.; 91. oxygen.mp.; 92. nitric oxide/ or nitrous oxide/; 93. ((nitric or nitrous) adj oxide).tw.; 94. magnesium sulfate/; 95. (magnesium adj (sulfat$ or sulphat$)).tw.; 96. adjuvant therapy/; 97. “add on therapy”/; 98. drug combination/; 99. placebo/; 100. placebo effect/; 101. placebo$.mp.; 102. (pharmacologic adj manag$).tw.; 103. (abortive adj therap$).tw.; 104. or/7–103; 105. exp glucocorticoid/; 106. glucocorticoid?.tw.; 107. (corticosteroid? or steroid$).tw.; 108. betamethason$.mp.; 109. (beetametasoni or betadexamethasone or betametason$ or betametazon$ or flubenisolon$).tw.; 110. (budesonid* or budezonid*).mp.; 111. (cortison* or kortison* or kortizon* or kortyzon*).mp.; 112. dexamethason$.mp.; 113. (deksametason$ or desamethason$ or dexametason$ or dexametazon$ or hexadecadrol).tw.; 114. hydrocortison$.mp.; 115. (cortisol or hidrocortisona or hidrokortizon$ or hydrocortisonum or hydrokortison$ or hydrokortyzon).tw.; 116. methylprednisolon$.mp.; 117. (meilprednizolon or methyl-prednisolon$ or metilprednisolon$ metilprednizolonas or metylprednisolon or metyyliprednisoloni).tw.; 118. prednisolon$.mp.; 119. (deltahydrocortisone or metacortandralone or prednizolon$).tw.; 120. prednison$.mp.; 121. (deltacortisone or deltadehydrocortisone or metacortandracin or prednizon$).tw.; 122. triamcinolon$.mp.; 123. (fluoxiprednisolonum or triamcynolon or triamsinoloni).tw.; 124. or/105–123; 125. or/7–123; 126. intramuscular drug administration/; 127. intravenous drug administration/; 128. subcutaneous drug administration/; 129. parenteral drug administration/; 130. (IM or intramuscular$ or intra-muscular$).tw.; 131. (IV or intravenous$ or intra-venous$).tw.; 132. (SC or subcutan$ or sub-cutan$ or sub-cu?).tw.; 133. (parenteral$ adj2 (inject$ or administ$ or therap$ or treatment?)).tw.; 134. or/126–133; 135. emergency treatment/; 136. emergency care/; 137. emergency health service/; 138. emergency/; 139. health care facility/; 140. health center/; 141. health care delivery/; 142. aftercare/; 143. ambulatory care/; 144. community care/; 145. primary health care/; 146. pain clinic/; 147. general practice/; 148. ((emerg or emergenc$) adj3 (department? or ward? or service? or unit? or room? or hospital? or care or medicin$ or treatment? or admission?)).tw.; 149. ED?.tw.; 150. ER?.tw.; 151. (ambulatory adj2 (clinic? or care or centre? or center? or service?)).tw.; 152. ((out-patient or outpatient) adj2 (clinic? or care or centre? or center? or service?)).tw.; 153. (community adj2 (service? or care)).tw.; 154. (primary adj2 care).tw.; 155. (urgent adj2 care).tw.; 156. ((pain or headache or head-ache or walkin or walk-in) adj2 (clinic? or centre? or center? or service? or unit?)).tw.; 157. or/135–156; 158. and/6,125,134,157; 159. limit 158 to adult <18 to 64 years>; 160. limit 158 to aged <65+ years>; 161. or/159–160; 162. (animal not (animal and human)).sh.; 163. 161 not 162; 164. (editorial or letter or note).pt.; 165. 163 not 164; 166. remove duplicates from 165; 167. and/104,134; 168. or/124,167; 169. and/6,157,168; 170. limit 169 to adult <18 to 64 years>; 171. limit 169 to aged <65+ years>; 172. or/170–171; 173. remove duplicates from 172; 174. 173 not 166

Table A3 Acute migraine review - EBM Reviews - Cochrane Central Register of Controlled Trials

Version: OvidSP_UI03.04.00.105, SourceID 54178 Years/issue searched: 1st Quarter 2011 Search date: June 13, 2011 Limits: MEDLINE or EMBASE records Results: 4 De-duped: 2
1. Migraine Disorders/; 2. migraine with aura/; 3. migraine without aura/; 4. Headache/; 5. exp Headache Disorders/; 6. migrain$.mp.; 7. (headach$ or head-ach$).tw.; 8. (cephalgi$ or cephalalgi$).tw.; 9. or/1–8; 10. exp Serotonin Agonists/; 11. sumatript$.mp.; 12. zolmitript$.mp.; 13. rizatrip$.mp.; 14. eletript$.mp.; 15. naratript$.mp.; 16. almotript$.mp.; 17. frovatript$.mp.; 18. exp ergot alkaloids/; 19. dihydroergotami$.mp.; 20. DHE.tw.; 21. ergotami$.mp.; 22. exp analgesics, non-narcotic/; 23. acetaminophen.mp.; 24. (acetaminofeno or acetominophen or apap or asetaminofen or paracetamol or paracetamolis or paracetamolum or parasetamol or parasetamoli).tw.; 25. exp anti-inflammatory agents, non-steroidal/; 26. (NSAIA? or NSAID?).tw.; 27. ((nonsteroidal or non-steroidal) adj anti-inflammator$).tw.; 28. aspirin.mp.; 29. (acetylsalicylic acid or ASA).tw.; 30. (acetilsalicilico or acetilszalicilsav or acetylsalicyl$ or asetilsalisilik or asetyylisalisyylihappo or acetylosalicylowy).tw.; 31. diclofen$.mp.; 32. (diklofen$ or diclophen$).tw.; 33. ibuprofen$.mp.; 34. ibuprofeeni.tw.; 35. (ketoprof$ or dexketoprofeno).mp.; 36. ketorola$.mp.; 37. naprox$.mp.; 38. naprok$.tw.; 39. exp analgesics, opioid/; 40. exp narcotics/; 41. morphine/; 42. (morphin* or morfiini* or morfin*).mp.; 43. buprenorphin*.mp.; 44. butorphanol$.mp.; 45. butorfanol$.tw.; 46. codein$.mp.; 47. (kodeiini or kodein or kodeina or kodeinas or methylmorphine or metilmorfina or morphine methyl ether).tw.; 48. fentanyl.mp.; 49. hydromorphon*.mp.; 50. meperidin$.mp.; 51. (pethidin$ or petidiinihydrokloridi or petidin$ or petidinhydroklorid or petydyny).tw.; 52. nalbuphin$.mp.; 53. nalbufin$.tw.; 54. tramadol$.mp.; 55. propofol$.mp.; 56. disoprofol.tw.; 57. ketamin$.mp.; 58. valproic acid/; 59. (acide valproique or acido dipropilacetico or acido valproico or acidum valproicum or dipropylacetic acid or DPA or kyselina valproova or natrii valproas or natrio valproatas or natriumvalproaatti or natriumvalproat or natrium-valproat or valproat$ or valproic acid or valproiinihappo or valproik asit or valproine rugutis or valproinsav or valproinsyra).tw.; 60. exp antiemetics/; 61. (antiemetic$ or anti-emetic$).mp.; 62. haloperidol/; 63. (haloperidol* or aloperidolo).mp.; 64. Trimethobenzamide.mp.; 65. exp Phenothiazines/; 66. chlorpromazin$.mp.; 67. (klooripromatsiini$ or klorpromazin$ or aminazine or chlor#promaz$).tw.; 68. promethazin$.mp.; 69. (prometatsiini or prometazin or prometazina or promethazinum).tw.; 70. methotrimeprazin$.mp.; 71. (levomeproma$ or lewomepromazyny).tw.; 72. prochlorperazin$.mp.; 73. (chlormeprazine or prochlorpemazine or proklooriperatsiini or proklorperazin).tw.; 74. ondansetron$.mp.; 75. droperidol$.mp.; 76. metoclopramid$.mp.; 77. metoklopramid$.tw.; 78. domperidon$.mp.; 79. exp histamine h1 antagonists/; 80. diphenhydramin$.mp.; 81. (benzhydramin$ or difenhidramin$ or difenhydramiinihydrokloridi or difenhydramin$ or dimedrolum).tw.; 82. dimenhydrinat$.mp.; 83. (chloranautine or dimenhidrinat$ or dimenhydramina or dimenhydrina$ or diphenhydramin$).tw.; 84. butalbital$.mp.; 85. (alisobumalum or allylbarbit$ or butalbitaali or butalbitalum or itobarbital or tetrallobarbital).tw.; 86. Botulinum Toxin Type A/; 87. (Botuliinitoksiini tyyppi A or Botulinum Toxin Type A or Botulinum A Toksini or Toxin typ A mot botulism or Toxina botulinica A or Toxine botulinique type A or Toxinum Botulinicum Typum A).tw.; 88. lidocain$.mp.; 89. (lidokaiini or lidokain$ or lignocain$).tw.; 90. xylocain$.tw.; 91. oxygen.mp.; 92. nitric oxide/ or nitrous oxide/; 93. ((nitric or nitrous) adj oxide).tw.; 94. magnesium sulfate/; 95. (magnesium adj (sulfat$ or sulphat$)).tw.; 96. drug therapy, combination/; 97. drug combinations/; 98. combined modality therapy/; 99. placebo$.mp.; 100. (pharmacologic adj manag$).tw.; 101. (abortive adj therap$).tw.; 102. or/10–101; 103. cortisone/; 104. (coritson* or kortison* or kortizon* or kortyzon*).mp.; 105. exp glucocorticoids/; 106. glucocorticoid?.tw.; 107. (corticosteroid? or steroid$).tw.; 108. betamethason$.mp.; 109. (beetametasoni or betadexamethasone or betametason$ or betametazon$ or flubenisolon$).tw.; 110. (budesonid* or budezonid*).mp.; 111. dexamethason$.mp.; 112. (deksametason$ or desamethason$ or dexametason$ or dexametazon$ or hexadecadrol).tw.; 113. hydrocortison$.mp.; 114. (cortisol or hidrocortisona or hidrokortizon$ or hydrocortisonum or hydrokortison$ or hydrokortyzon).tw.; 115. methylprednisolon$.mp.; 116. (meilprednizolon or methyl-prednisolon$ or metilprednisolon$ metilprednizolonas or metylprednisolon or metyyliprednisoloni).tw.; 117. prednisolon$.mp.; 118. (deltahydrocortisone or metacortandralone or prednizolon$).tw.; 119. prednison$.mp.; 120. (deltacortisone or deltadehydrocortisone or metacortandracin or prednizon$).tw.; 121. triamcinolon$.mp.; 122. (fluoxiprednisolonum or triamcynolon or triamsinoloni).tw.; 123. or/103–122; 124. or/10–122; 125. Injections, Intramuscular/; 126. Injections, Intravenous/; 127. Injections, Subcutaneous/; 128. Infusions, Intravenous/; 129. Infusions, Parenteral/; 130. (IM or intramuscular$ or intra-muscular$).tw.; 131. (IV or intravenous$ or intra-venous$).tw.; 132. (SC or subcutan$ or sub-cutan$ or sub-cu?).tw.; 133. (parenteral$ adj2 (inject$ or administ$ or therap$ or treatment?)).tw.; 134. or/125–133; 135. Emergency Treatment/; 136. Emergency Service, Hospital/; 137. Emergency Medical Services/; 138. Emergencies/; 139. Ambulatory Care Facilities/; 140. Community Health Centers/; 141. exp Outpatient Clinics, Hospital/; 142. Community Health Services/; 143. Family Practice/; 144. Primary Health Care/; 145. ((emerg or emergenc$) adj3 (department? or ward? or service? or unit? or room? or hospital? or care or medicin$ or treatment? or admission?)).tw.; 146. ED?.tw.; 147. ER?.tw.; 148. (ambulatory adj2 (clinic? or care or centre? or center? or service?)).tw.; 149. ((out-patient or outpatient) adj2 (clinic? or care or centre? or center? or service?)).tw.; 150. (community adj2 (service? or care)).tw.; 151. (primary adj2 care).tw.; 152. (urgent adj2 care).tw.; 153. ((pain or headache or head-ache or walkin or walk-in) adj2 (clinic? or centre? or center? or service? or unit?)).tw.; 154. or/135–153; 155. and/9,124,134,154; 156. limit 155 to (medline records or embase records); 157. 155 not 156; 158. and/102,134; 159. or/123,158; 160. and/9,154,159; 161. limit 160 to medline records; 162. limit 160 to embase records; 163. or/161–162; 164. 160 not 163; 165. 157 or 164

Table A4 Acute migraine review - EBM Reviews - Cochrane Database of Systematic Reviews 2005 to March 2011 (CDSR)

EBM Reviews - Database of Abstracts of Reviews of Effects 2nd Quarter 2011 (DARE) Ovid MEDLINE(R) In-Process &; Other Non-Indexed Citations April 29, 2011 PASCAL 1984 to 2011 Week 26 International Pharmaceutical Abstracts 1970 to March 2011 (IPA) Version: OvidSP_UI03.04.00.105, SourceID 54178 Search date: 30.06.2011 Number of results:

Database | Results | De-duped
CDSR | 262 | 260
DARE | 15 | 15
In-Process | 20 | 13
Pascal | 122 | 20
IPA | 41 | 25

Table A5 Acute Migraine review - 4 CDSR, DARE, MEDLINE In-Process, PASCAL, IPA

1. migrain$.mp.; 2. (headach$ or head-ach$).mp.; 3. (cephalgi$ or cephalalgi$).mp.; 4. or/1–3; 5. (serotonin adj2 agonist?).mp.; 6. sumatript$.mp.; 7. zolmitript$.mp.; 8. rizatrip$.mp.; 9. eletript$.mp.; 10. naratript$.mp.; 11. almotript$.mp.; 12. frovatript$.mp.; 13. ergot alkaloid?.mp.; 14. dihydroergotami$.mp.; 15. DHE.mp.; 16. ergotami$.mp.; 17. analgesic?.mp.; 18. acetaminophen.mp.; 19. (acetaminofeno or acetominophen or apap or asetaminofen or paracetamol or paracetamolis or paracetamolum or parasetamol or parasetamoli).mp.; 20. (NSAIA? or NSAID?).mp.; 21. ((nonsteroidal or non-steroidal) adj anti-inflammator$).mp.; 22. aspirin.mp.; 23. (acetylsalicylic acid or ASA).mp.; 24. (acetilsalicilico or acetilszalicilsav or acetylsalicyl$ or asetilsalisilik or asetyylisalisyylihappo or acetylosalicylowy).mp.; 25. diclofen$.mp.; 26. (diklofen$ or diclophen$).mp.; 27. ibuprofen$.mp.; 28. ibuprofeeni.mp.; 29. (ketoprof$ or dexketoprofeno).mp.; 30. ketorola$.mp.; 31. naprox$.mp.; 32. naprok$.mp.; 33. narcotic?.mp.; 34. (morphin* or morfiini* or morfin*).mp.; 35. buprenorphin*.mp.; 36. butorphanol$.mp.; 37. butorfanol$.mp.; 38. codein$.mp.; 39. (kodeiini or kodein or kodeina or kodeinas or methylmorphine or metilmorfina or morphine methyl ether).mp.; 40. fentanyl.mp.; 41. hydromorphon*.mp.; 42. meperidin$.mp.; 43. (pethidin$ or petidiinihydrokloridi or petidin$ or petidinhydroklorid or petydyny).mp.; 44. nalbuphin$.mp.; 45. nalbufin$.mp.; 46. tramadol$.mp.; 47. propofol$.mp.; 48. disoprofol.mp.; 49. ketamin$.mp.; 50. (acide valproique or acido dipropilacetico or acido valproico or acidum valproicum or dipropylacetic acid or DPA or kyselina valproova or natrii valproas or natrio valproatas or natriumvalproaatti or natriumvalproat or natrium-valproat or valproat$ or valproic acid or valproiinihappo or valproik asit or valproine rugutis or valproinsav or valproinsyra).mp.; 51. (antiemetic$ or anti-emetic$).mp.; 52. (haloperidol* or aloperidolo).mp.; 53. Trimethobenzamide.mp.; 54. phenothiazin$.mp.; 55. chlorpromazin$.mp.; 56. (klooripromatsiini$ or klorpromazin$ or aminazine or chlor#promaz$).mp.; 57. promethazin$.mp.; 58. (prometatsiini or prometazin$).mp.; 59. methotrimeprazin$.mp.; 60. (levomeproma$ or lewomepromazyny).mp.; 61. prochlorperazin$.mp.; 62. (chlormeprazine or prochlorpemazine or proklooriperatsiini or proklorperazin).mp.; 63. ondansetron$.mp.; 64. droperidol$.mp.; 65. metoclopramid$.mp.; 66. metoklopramid$.mp.; 67. domperidon$.mp.; 68. (antihistamin$ or anti-histamin$).mp.; 69. diphenhydramin$.mp.; 70. (benzhydramin$ or difenhidramin$ or difenhydramiinihydrokloridi or difenhydramin$ or dimedrolum).mp.; 71. dimenhydrinat$.mp.; 72. (chloranautine or dimenhidrinat$ or dimenhydramina or dimenhydrina$ or diphenhydramin$).mp.; 73. butalbital$.mp.; 74. (alisobumalum or allylbarbit$ or butalbitaali or butalbitalum or itobarbital or tetrallobarbital).mp.; 75. (Botuliinitoksiini tyyppi A or Botulinum Toxin Type A or Botulinum A Toksini or Toxin typ A mot botulism or Toxina botulinica A or Toxine botulinique type A or Toxinum Botulinicum Typum A).mp.; 76. lidocain$.mp.; 77. (lidokaiini or lidokain$ or lignocain$).mp.; 78. xylocain$.mp.; 79. oxygen.mp.; 80. ((nitric or nitrous) adj oxide).mp.; 81. (magnesium adj (sulfat$ or sulphat$)).mp.; 82. (drug adj2 combination?).mp.; 83. (combin? adj2 (therap$ or treatment?)).mp.; 84. placebo$.mp.; 85. (pharmacologic adj manag$).mp.; 86. (abortive adj therap$).mp.; 87. or/5–86; 88. (coritson* or kortison* or kortizon* or kortyzon*).mp.; 89. glucocorticoid?.mp.; 90. (corticosteroid? or steroid$).mp.; 91. betamethason$.mp.; 92. (beetametasoni or betadexamethasone or betametason$ or betametazon$ or flubenisolon$).mp.; 93. (budesonid* or budezonid*).mp.; 94. dexamethason$.mp.; 95. (deksametason$ or desamethason$ or dexametason$ or dexametazon$ or hexadecadrol).mp.; 96. hydrocortison$.mp.; 97. (cortisol or hidrocortisona or hidrokortizon$ or hydrocortisonum or hydrokortison$ or hydrokortyzon).mp.; 98. methylprednisolon$.mp.; 99. (meilprednizolon or methyl-prednisolon$ or metilprednisolon$ metilprednizolonas or metylprednisolon or metyyliprednisoloni).mp.; 100. prednisolon$.mp.; 101. (deltahydrocortisone or metacortandralone or prednizolon$).mp.; 102. prednison$.mp.; 103. (deltacortisone or deltadehydrocortisone or metacortandracin or prednizon$).mp.; 104. triamcinolon$.mp.; 105. (fluoxiprednisolonum or triamcynolon or triamsinoloni).mp.; 106. or/88–105; 107. or/5–105; 108. (IM or intramuscular$ or intra-muscular$).mp.; 109. (IV or intravenous$ or intra-venous$).mp.; 110. (SC or subcutan$ or sub-cutan$ or sub-cu?).mp.; 111. (parenteral$ adj2 (inject$ or administ$ or therap$ or treatment?)).mp.; 112. or/108–111; 113. ((family or general) adj2 practice?).mp.; 114. ((emerg or emergenc$) adj3 (department? or ward? or service? or unit? or room? or hospital? or care or medicin$ or treatment? or admission?)).mp.; 115. ED?.mp.; 116. ER?.mp.; 117. (ambulatory adj2 (clinic? or care or centre? or center? or service?)).mp.; 118. ((out-patient or outpatient) adj2 (clinic? or care or centre? or center? or service?)).mp.; 119. (community adj2 (service? or care)).mp.; 120. (primary adj2 care).mp.; 121. (urgent adj2 care).mp.; 122. ((pain or headache or head-ache or walkin or walk-in) adj2 (clinic? or centre? or center? or service? or unit?)).mp.; 123. or/113–122; 124. and/4,107,112,123; 125. and/87,112; 126. or/106,125; 127. and/4,123,126; 128. 127 not 124

Table A6 Acute migraine review - CINAHL Plus with Full Text EBSCOhost

Years/issue searched: 1937 to the present Search date: June 14, 2011 Number of results: 131 Limiters/Expanders: Search modes - Find all my search terms Last Run Via: Interface - EBSCOhost Search Screen - Advanced Search Limiters and Last Run Via apply to all lines of search strategy

ID | Search | Hits
S144 | S7 and S107 and S120 and S143 | 134
S143 | S121 or S122 or S123 or S124 or S125 or S126 or S127 or S128 or S129 or S130 or S131 or S132 or S133 or S134 or S135 or S136 or S137 or S138 or S139 or S140 or S141 or S142 | 493262
S142 | AB urgent N2 care | 370
S141 | AB primary N2 care | 22446
S140 | AB community N2 service* or AB community N2 care | 7769
S139 | AB walk-in N2 clinic* or AB walk-in N2 care or AB walk-in N2 centre* or AB walk-in N2 center* or AB walk-in N2 service* or AB walk-in N2 unit* | 149
S138 | AB walkin N2 clinic* or AB walkin N2 care or AB walkin N2 centre* or AB walkin N2 center* or AB walkin N2 service* or AB walkin N2 unit* | 1
S137 | AB pain N2 clinic* or AB pain N2 care or AB pain N2 centre* or AB pain N2 center* or AB pain N2 service* or AB pain N2 unit* | 3528
S136 | AB outpatient N2 clinic* or AB outpatient N2 care or AB outpatient N2 centre* or AB outpatient N2 center* or AB outpatient N2 service* | 5883
S135 | AB out-patient N2 clinic* or AB out-patient N2 care or AB out-patient N2 centre* or AB out-patient N2 center* or AB out-patient N2 service* | 385
S134 | AB ambulatory N2 clinic* or AB ambulatory N2 care or AB ambulatory N2 centre* or AB ambulatory N2 center* or AB ambulatory N2 service* | 2236
S133 | AB ED* or AB ER* | 165428
S132 | AB emergenc* N3 department* or AB emergenc* N3 ward* or AB emergenc* N3 service* or AB emergenc* N3 unit* or AB emergenc* N3 room* or AB emergenc* N3 hospital* or AB emergenc* N3 care or AB emergenc* N3 medicin* or AB emergenc* N3 treatment* or AB emergenc* N3 admission* | 19812
S131 | AB emerg N3 department* or AB emerg N3 ward* or AB emerg N3 service* or AB emerg N3 unit* or AB emerg N3 room* or AB emerg N3 hospital* or AB emerg N3 care or AB emerg N3 medicin* or AB emerg N3 treatment* or AB emerg N3 admission* | 3
S130 | (MH “Primary Health Care”) | 28246
S129 | (MH “Family Practice”) | 13482
S128 | (MH “Community Health Services+”) | 233566
S127 | (MH “Outpatient Service”) | 4335
S126 | (MH “Community Health Centers”) | 2384
S125 | (MH “Ambulatory Care Facilities+”) | 8334
S124 | (MH “Emergencies+”) | 6168
S123 | (MH “Emergency Medical Services+”) | 48860
S122 | (MH “Emergency Service+”) | 24429
S121 | (MH “Emergency Care+”) | 22162
S120 | S108 or S109 or S110 or S111 or S112 or S114 or S115 or S116 or S118 or S119 | 40259
S119 | AB parenteral* N2 inject* or AB parenteral* N2 administ* or AB parenteral* N2 therap* or AB parenteral* N2 treatment* | 619
S118 | AB subcutan* or sub-cutan* or sub-cu* | 4863
S117 | AB SC | 0
S116 | AB intravenous* or AB intra-venous* | 12662
S115 | AB IV | 11881
S114 | AB intramuscular* or AB intra-muscular* | 1796
S113 | AB IM | 0
S112 | (MH “Infusions, Parenteral+”) | 7435
S111 | (MH “Infusions, Intravenous”) | 5081
S110 | (MH “Injections, Subcutaneous+”) | 2038
S109 | (MH “Injections, Intravenous”) | 2943
S108 | (MH “Injections, Intramuscular+”) | 2165
S107 | S8 or S9 or S10 or S11 or S12 or S13 or S14 or S15 or S16 or S17 or S18 or S19 or S20 or S21 or S22 or S23 or S24 or S25 or S26 or S27 or S28 or S29 or S30 or S31 or S32 or S33 or S34 or S35 or S36 or S37 or S38 or S39 or S40 or S41 or S42 or S43 or S44 or S45 or S46 or S47 or S48 or S49 or S50 or S51 or S52 or S53 or S54 or S55 or S56 or S57 or S58 or S59 or S60 or S61 or S62 or S63 or S64 or S65 or S66 or S67 or S68 or S69 or S70 or S71 or S72 or S73 or S74 or S75 or S76 or S77 or S78 or S79 or S80 or S81 or S82 or S83 or S84 or S85 or S86 or S87 or S88 or S89 or S90 or S91 or S92 or S93 or S94 or S95 or S96 or S97 or S98 or S99 or S100 or S101 or S102 or S103 or S104 or S105 or S106 | 154362
S106 | S89 or S90 or S91 or S92 or S93 or S94 or S95 or S96 or S97 or S98 or S99 or S100 or S101 or S102 or S103 or S104 or S105 | 31569
S105 | AB fluoxiprednisolonum or triamcynolon or triamsinoloni | 0
S104 | AB Triamcinolon* | 242
S103 | AB deltacortisone or deltadehydrocortisone or metacortandracin or prednizon* | 0
S102 | AB prednison* | 969
S101 | AB deltahydrocortisone or metacortandralone or prednizolon* | 1
S100 | AB prednisolon* | 570
S99 | AB meilprednizolon or methyl-prednisolon* or metilprednisolon* metilprednizolonas or metylprednisolon or metyyliprednisoloni | 24
S98 | AB methylprednisolon* | 487
S97 | AB cortisol or hidrocortisona or hidrokortizon* or hydrocortisonum or hydrokortison* or hydrokortyzon | 1988
S96 | AB hydrocortison* | 266
S95 | AB deksametason* or desamethason* or dexametason* or dexametazon or dexamethason* or hexadecadrol | 2598
S94 | AB dexamethason* | 1126
S93 | AB beetametasoni or betadexamethasone or betametason* or betametazon* or flubenisolon* | 0
S92 | AB betamethason* | 160
S91 | AB corticosteroid* or steroid* | 22376
S90 | AB Glucocorticoid* | 1114
S89 | (MH “Glucocorticoids+”) | 6500
S88 | S8 or S9 or S10 or S11 or S12 or S13 or S14 or S15 or S16 or S17 or S18 or S19 or S20 or S21 or S22 or S23 or S24 or S25 or S26 or S27 or S28 or S29 or S30 or S31 or S32 or S33 or S34 or S35 or S36 or S37 or S38 or S39 or S40 or S41 or S42 or S43 or S44 or S45 or S46 or S47 or S48 or S49 or S50 or S51 or S52 or S53 or S54 or S55 or S56 or S57 or S58 or S59 or S60 or S61 or S62 or S63 or S64 or S65 or S66 or S67 or S68 or S69 or S70 or S71 or S72 or S73 or S74 or S75 or S76 or S77 or S78 or S79 or S80 or S81 or S82 or S83 or S84 or S85 or S86 or S87 | 136950
S87 | AB abortive N1 therap* | 37
S86 | AB pharmacologic N1 manag* | 274
S85 | AB Placebo* | 18141
S84 | (MH “Combined Modality Therapy+”) | 19321
S83 | (MH “Drug Combinations+”) | 13149
S82 | (MH “Drug Therapy, Combination+”) | 18454
S81 | AB magnesium N1 sulfat* or AB magnesium N1 sulphat* | 268
S80 | (MH “Magnesium Sulfate”) | 742
S79 | AB nitric N1 oxide or AB nitrous N1 oxide | 3953
S78 | (MH “Nitric Oxide”) OR (MH “Nitrous Oxide”) | 5587
S77 | AB oxygen | 12572
S76 | AB xylocain* | 35
S75 | AB lidokaiini or lidokain* or lignocain* | 360
S74 | AB lidocain* | 974
S73 | AB Botuliinitoksiini tyyppi A or Botulinum Toxin Type A or Botulinum A Toksini or Toxin typ A mot botulism or Toxina botulinica A or Toxine botulinique type A or Toxinum Botulinicum Typum A | 570
S72 | (MH “Botulinum Toxins”) | 2471
S71 | AB alisobumalum or allylbarbit* or butalbitaali or butalbitalum or itobarbital or tetrallobarbital | 0
S70 | AB butalbital* | 15
S69 | AB chloranautine or dimenhidrinat* or dimenhydramina or dimenhydrina* or diphenhydramin* | 432
S68 | AB dimenhydrinat* | 16
S67 | AB benzhydramin* or difenhidramin* or difenhydramiinihydrokloridi; difenhydramin* or dimedrolum | 0
S66 | AB diphenhydramin* | 152
S65 | (MH “Histamine H1 Antagonists+”) | 2181
S64 | AB domperidon* | 30
S63 | AB metoklopramid* | 0
S62 | AB metoclopramid* | 237
S61 | AB droperidol* or haloperidol* or aloperidol* | 963
S60 | AB ondansetron* | 226
S59 | AB chlormeprazine or prochlorpemazine or prochlorperazin* or proklooriperatsiini or proklorperazin | 148
S58 | AB prochlorperazin* | 65
S57 | AB levomeproma* or lewomepromazyny | 15
S56 | AB methotrimeprazin* | 11
S55 | AB prometatsiini or prometazin or prometazina or promethazinum | 0
S54 | AB promethazin* | 60
S53 | AB klooripromatsiini* or klorpromazin* or aminazine or chlor#promaz* | 345
S52 | AB chlorpromazin* | 151
S51 | (MH “Antipsychotic Agents, Phenothiazine+”) | 639
S50 | AB antiemetic* or AB anti-emetic* | 672
S49 | (MH “Antiemetics+”) | 8039
S48 | AB acide valproique or acido dipropilacetico or acido valproico or acidum valproicum or dipropylacetic acid or DPA or kyselina valproova or natrii valproas or natrio valproatas or natriumvalproaatti or natriumvalproat or natrium-valproat or valproat* or valproic acid or valproiinihappo or valproik asit or valproine rugutis or valproinsav or valproinsyra | 1490
S47 | (MH “Valproic Acid”) | 1100
S46 | AB ketamin* | 519
S45 | AB disoprofol* | 0
S44 | AB propofol* | 897
S43 | AB tramadol* | 283
S42 | AB morphin* or hydromorphon* | 2042
S41 | AB nalbuphin* or nalbufin* | 29
S40 | AB pethidin* or petidiinihydrokloridi or petidin* or petidinhydroklorid or petydyny | 83
S39 | AB meperidin* | 182
S38 | AB kodeiini or kodein or kodeina or kodeinas or methylmorphine or metilmorfina or morphine methyl ether | 1
S37 | AB codein* | 219
S36 | AB buprenorphin* or fentanyl | 3260
S35 | AB butorphanol* or butorfanol* | 33
S34 | (MH “Narcotics+”) | 18946
S33 | (MH “Analgesics, Opioid+”) | 16017
S32 | AB naprok* | 0
S31 | AB naprox* | 277
S30 | AB ketorola* | 175
S29 | AB ketoprof* or dexketoprofeno | 64
S28 | AB ibuprofeeni | 0
S27 | AB ibuprofen* | 573
S26 | AB diklofen* or diclophen* | 1
S25 | AB diclofen* | 391
S24 | AB acetaminofeno or acetominophen or apap or asetaminofen or paracetamol or paracetamolis or paracetamolum or parasetamol or parasetamoli | 896
S23 | AB Acetaminophen | 885
S22 | (MH “Analgesics, Nonnarcotic+”) | 21107
S21 | (MH “Analgesics+”) | 24881
S20 | AB ergotami* | 97
S19 | AB DHE | 34
S18 | AB dihydroergotami* | 90
S17 | (MH “Ergot Alkaloids+”) | 602
S16 | AB frovatript* | 47
S15 | AB almotript* | 75
S14 | AB naratript* | 74
S13 | AB eletript* | 57
S12 | AB Rizatript* | 104
S11 | AB zolmitript* | 99
S10 | AB imitrex or AB sumavel or AB treximet | 8
S9 | AB Sumatript* | 366
S8 | (MH “Serotonin Agonists+”) | 1519
S7 | S1 or S2 or S3 or S4 or S5 or S6 | 17206
S6 | AB cephalgi* or AB cephalalgi* | 137
S5 | AB head-ach* | 21
S4 | AB headach* | 7028
S3 | AB migrain* | 3551
S2 | (MH “Headache+”) | 13608
S1 | (MH “Migraine”) | 6959

Table A7 Acute migraine review - Academic Search Complete EBSCOhost

Years/issue searched: 1887 - present Search date: June 14, 2011 Number of results: 201 Limiters/Expanders: Search modes - Find all my search terms Last Run Via: Interface - EBSCOhost Search Screen - Advanced Search Limiters and Last Run Via apply to all lines of search strategy

ID | Search | Hits
S144 | S7 and S107 and S120 and S143 | 135
S143 | S121 or S122 or S123 or S124 or S125 or S126 or S127 or S128 or S129 or S130 or S131 or S132 or S133 or S134 or S135 or S136 or S137 or S138 or S139 or S140 or S141 or S142 | 2714291
S142 | AB urgent N2 care | 521
S141 | AB primary N2 care | 35500
S140 | AB community N2 service* or AB community N2 care | 20615
S139 | AB walk-in N2 clinic* or AB walk-in N2 care or AB walk-in N2 centre* or AB walk-in N2 center* or AB walk-in N2 service* or AB walk-in N2 unit* | 680
S138 | AB walkin N2 clinic* or AB walkin N2 care or AB walkin N2 centre* or AB walkin N2 center* or AB walkin N2 service* or AB walkin N2 unit* | 2
S137 | AB pain N2 clinic* or AB pain N2 care or AB pain N2 centre* or AB pain N2 center* or AB pain N2 service* or AB pain N2 unit* | 4131
S136 | AB outpatient N2 clinic* or AB outpatient N2 care or AB outpatient N2 centre* or AB outpatient N2 center* or AB outpatient N2 service* | 9904
S135 | AB out-patient N2 clinic* or AB out-patient N2 care or AB out-patient N2 centre* or AB out-patient N2 center* or AB out-patient N2 service* | 745
S134 | AB ambulatory N2 clinic* or AB ambulatory N2 care or AB ambulatory N2 centre* or AB ambulatory N2 center* or AB ambulatory N2 service* | 3072
S133 | AB ED* or AB ER* | 2624521
S132 | AB emergenc* N3 department* or AB emergenc* N3 ward* or AB emergenc* N3 service* or AB emergenc* N3 unit* or AB emergenc* N3 room* or AB emergenc* N3 hospital* or AB emergenc* N3 care or AB emergenc* N3 medicin* or AB emergenc* N3 treatment* or AB emergenc* N3 admission* | 33467
S131 | AB emerg N3 department* or AB emerg N3 ward* or AB emerg N3 service* or AB emerg N3 unit* or AB emerg N3 room* or AB emerg N3 hospital* or AB emerg N3 care or AB emerg N3 medicin* or AB emerg N3 treatment* or AB emerg N3 admission* | 1
S130 | (MH “Primary Health Care”) | 4133
S129 | (MH “Family Practice”) | 641
S128 | (MH “Community Health Services+”) | 6005
S127 | (MH “Outpatient Service”) | 3
S126 | (MH “Community Health Centers”) | 35
S125 | (MH “Ambulatory Care Facilities+”) | 5
S124 | (MH “Emergencies+”) | 8184
S123 | (MH “Emergency Medical Services+”) | 7795
S122 | (MH “Emergency Service+”) | 83
S121 | (MH “Emergency Care+”) | 135
S120 | S108 or S109 or S110 or S111 or S112 or S114 or S115 or S116 or S118 or S119 | 165984
S119 | AB parenteral* N2 inject* or AB parenteral* N2 administ* or AB parenteral* N2 therap* or AB parenteral* N2 treatment* | 1520
S118 | AB subcutan* or sub-cutan* or sub-cu* | 39358
S117 | AB SC | 20657
S116 | AB intravenous* or AB intra-venous* | 45020
S115 | AB IV | 79308
S114 | AB intramuscular* or AB intra-muscular* | 8714
S113 | AB IM | 21615
S112 | (MH “Infusions, Parenteral+”) | 2
S111 | (MH “Infusions, Intravenous”) | 14
S110 | (MH “Injections, Subcutaneous+”) | 1
S109 | (MH “Injections, Intravenous”) | 971
S108 | (MH “Injections, Intramuscular+”) | 989
S107 | S8 or S9 or S10 or S11 or S12 or S13 or S14 or S15 or S16 or S17 or S18 or S19 or S20 or S21 or S22 or S23 or S24 or S25 or S26 or S27 or S28 or S29 or S30 or S31 or S32 or S33 or S34 or S35 or S36 or S37 or S38 or S39 or S40 or S41 or S42 or S43 or S44 or S45 or S46 or S47 or S48 or S49 or S50 or S51 or S52 or S53 or S54 or S55 or S56 or S57 or S58 or S59 or S60 or S61 or S62 or S63 or S64 or S65 or S66 or S67 or S68 or S69 or S70 or S71 or S72 or S73 or S74 or S75 or S76 or S77 or S78 or S79 or S80 or S81 or S82 or S83 or S84 or S85 or S86 or S87 or S88 or S89 or S90 or S91 or S92 or S93 or S94 or S95 or S96 or S97 or S98 or S99 or S100 or S101 or S102 or S103 or S104 or S105 or S106 | 398992
S106 | S89 or S90 or S91 or S92 or S93 or S94 or S95 or S96 or S97 or S98 or S99 or S100 or S101 or S102 or S103 or S104 or S105 | 100757
S105 | AB fluoxiprednisolonum or triamcynolon or triamsinoloni | 0
S104 | AB Triamcinolon* | 1650
S103 | AB deltacortisone or deltadehydrocortisone or metacortandracin or prednizon* | 13
S102 | AB prednison* | 4590
S101 | AB deltahydrocortisone or metacortandralone or prednizolon* | 31
S100 | AB prednisolon* | 4629
S99 | AB meilprednizolon or methyl-prednisolon* or metilprednisolon* metilprednizolonas or metylprednisolon or metyyliprednisoloni | 166
S98 | AB methylprednisolon* | 2956
S97 | AB cortisol or hidrocortisona or hidrokortizon* or hydrocortisonum or hydrokortison* or hydrokortyzon | 11184
S96 | AB hydrocortison* | 1904
S95 | AB deksametason* or desamethason* or dexametason* or dexametazon or dexamethason* or hexadecadrol | 9212
S94 | AB dexamethason* | 8664
S93 | AB beetametasoni or betadexamethasone or betametason* or betametazon* or flubenisolon* | 25
S92 | AB betamethason* | 958
S91 | AB corticosteroid* or steroid* | 67583
S90 | AB Glucocorticoid* | 11619
S89 | (MH “Glucocorticoids+”) | 7869
S88 | S8 or S9 or S10 or S11 or S12 or S13 or S14 or S15 or S16 or S17 or S18 or S19 or S20 or S21 or S22 or S23 or S24 or S25 or S26 or S27 or S28 or S29 or S30 or S31 or S32 or S33 or S34 or S35 or S36 or S37 or S38 or S39 or S40 or S41 or S42 or S43 or S44 or S45 or S46 or S47 or S48 or S49 or S50 or S51 or S52 or S53 or S54 or S55 or S56 or S57 or S58 or S59 or S60 or S61 or S62 or S63 or S64 or S65 or S66 or S67 or S68 or S69 or S70 or S71 or S72 or S73 or S74 or S75 or S76 or S77 or S78 or S79 or S80 or S81 or S82 or S83 or S84 or S85 or S86 or S87 | 306838
S87 | AB abortive N1 therap* | 27
S86 | AB pharmacologic N1 manag* | 205
S85 | AB Placebo* | 44372
S84 | (MH “Combined Modality Therapy+”) | 977
S83 | (MH “Drug Combinations+”) | 49
S82 | (MH “Drug Therapy, Combination+”) | 26
S81 | AB magnesium N1 sulfat* or AB magnesium N1 sulphat* | 1169
S80 | (MH “Magnesium Sulfate”) | 636
S79 | AB nitric N1 oxide or AB nitrous N1 oxide | 41479
S78 | (MH “Nitric Oxide”) OR (MH “Nitrous Oxide”) | 34305
S77 | AB oxygen | 162547
S76 | AB xylocain* | 121
S75 | AB lidokaiini or lidokain* or lignocain* | 460
S74 | AB lidocain* | 3360
S73 | AB Botuliinitoksiini tyyppi A or Botulinum Toxin Type A or Botulinum A Toksini or Toxin typ A mot botulism or Toxina botulinica A or Toxine botulinique type A or Toxinum Botulinicum Typum A | 1681
S72 | (MH “Botulinum Toxins”) | 23
S71 | AB alisobumalum or allylbarbit* or butalbitaali or butalbitalum or itobarbital or tetrallobarbital | 0
S70 | AB butalbital* | 44
S69 | AB chloranautine or dimenhidrinat* or dimenhydramina or dimenhydrina* or diphenhydramin* | 744
S68 | AB dimenhydrinat* | 71
S67 | AB benzhydramin* or difenhidramin* or difenhydramiinihydrokloridi; difenhydramin* or dimedrolum | 5
S66 | AB diphenhydramin* | 628
S65 | (MH “Histamine H1 Antagonists+”) | 7
S64 | AB domperidon* | 272
S63 | AB metoklopramid* | 3
S62 | AB metoclopramid* | 637
S61 | AB droperidol* or haloperidol* or aloperidol* | 3502
S60 | AB ondansetron* | 902
S59 | AB chlormeprazine or prochlorpemazine or prochlorperazin* or proklooriperatsiini or proklorperazin | 144
S58 | AB prochlorperazin* | 136
S57 | AB levomeproma* or lewomepromazyny | 76
S56 | AB methotrimeprazin* | 17
S55 | AB prometatsiini or prometazin or prometazina or promethazinum | 2
S54 | AB promethazin* | 349
S53 | AB klooripromatsiini* or klorpromazin* or aminazine or chlor#promaz* | 1201
S52 | AB chlorpromazin* | 1081
S51 | (MH “Antipsychotic Agents, Phenothiazine+”) | 0
S50 | AB antiemetic* or AB anti-emetic* | 1303
S49 | (MH “Antiemetics+”) | 616
S48 | AB acide valproique or acido dipropilacetico or acido valproico or acidum valproicum or dipropylacetic acid or DPA or kyselina valproova or natrii valproas or natrio valproatas or natriumvalproaatti or natriumvalproat or natrium-valproat or valproat* or valproic acid or valproiinihappo or valproik asit or valproine rugutis or valproinsav or valproinsyra | 6534
S47 | (MH “Valproic Acid”) | 2333
S46 | AB ketamin* | 2796
S45 | AB disoprofol* | 0
S44 | AB propofol* | 3418
S43 | AB tramadol* | 1125
S42 | AB morphin* or hydromorphon* | 9694
S41 | AB nalbuphin* or nalbufin* | 136
S40 | AB pethidin* or petidiinihydrokloridi or petidin* or petidinhydroklorid or petydyny | 279
S39 | AB meperidin* | 287
S38 | AB kodeiini or kodein or kodeina or kodeinas or methylmorphine or metilmorfina or morphine methyl ether | 15
S37 | AB codein* | 1008
S36 | AB buprenorphin* or fentanyl | 4414
S35 | AB butorphanol* or butorfanol* | 295
S34 | (MH “Narcotics+”) | 3534
S33 | (MH “Analgesics, Opioid+”) | 46
S32 | AB naprok* | 6
S31 | AB naprox* | 1749
S30 | AB ketorola* | 507
S29 | AB ketoprof* or dexketoprofeno | 935
S28 | AB ibuprofeeni | 0
S27 | AB ibuprofen* | 3530
S26 | AB diklofen* or diclophen* | 38
S25 | AB diclofen* | 2719
S24 | AB acetaminofeno or acetominophen or apap or asetaminofen or paracetamol or paracetamolis or paracetamolum or parasetamol or parasetamoli | 3583
S23 | AB Acetaminophen | 3370
S22 | (MH “Analgesics, Nonnarcotic+”) | 0
S21 | (MH “Analgesics+”) | 8293
S20 | AB ergotami* | 273
S19 | AB DHE | 262
S18 | AB dihydroergotami* | 147
S17 | (MH “Ergot Alkaloids+”) | 167
S16 | AB frovatript* | 89
S15 | AB almotript* | 154
S14 | AB naratript* | 148
S13 | AB eletript* | 130
S12 | AB Rizatript* | 249
S11 | AB zolmitript* | 262
S10 | AB imitrex or AB sumavel or AB treximet | 75
S9 | AB Sumatript* | 974
S8 | (MH “Serotonin Agonists+”) | 453
S7 | S1 or S2 or S3 or S4 or S5 or S6 | 26293
S6 | AB cephalgi* or AB cephalalgi* | 594
S5 | AB head-ach* | 52
S4 | AB headach* | 20700
S3 | AB migrain* | 10169
S2 | (MH “Headache+”) | 9693
S1 | (MH “Migraine”) | 8446

Table A8 Acute migraine review - PubMed

Years/issue searched: last 180 days Search date: May 9, 2011 Number of results: 22
1.1.1 (((((((((((migraine disorders[MeSH Terms])) OR (migraine with aura[MeSH Terms])) OR (migraine without aura[MeSH Terms])) OR (headache[MeSH Terms])) OR (headache disorders[MeSH Terms])) OR (migrain*[Text Word]) OR ((headache*[Text Word]) OR head-ache*[Text Word]) OR (((cephalgi*[Text Word])) OR cephalalgi*[Text Word]))) AND ((((((((((((((injections, intramuscular[MeSH Terms])) OR (injections, intravenous[MeSH Terms])) OR (Injections, Subcutaneous[MeSH Terms])) OR (infusions, intravenous[MeSH Terms])) OR (infusions, parenteral[MeSH Terms])) OR (((IM[Text Word]) OR intramuscular*[Text Word]) OR intra-muscular*[Text Word])) OR (((IV[Text Word]) OR intravenous*[Text Word]) OR intra-venous*[Text Word])) OR ((((SC[Text Word]) OR subcultan*[Text Word]) OR sub-cutan*[Text Word]) OR sub-cu*[Text Word])) OR ((((parenteral* AND inject*[Text Word]) OR parenteral* AND administ*[Text Word]) OR parenteral* AND therap*[Text Word]) OR parenteral* AND treatment*[Text Word]))) AND ((((((((((((Ergot alkaloids[MeSH Terms]) OR Dihydroergotami*[Text Word]) OR DHE[Text Word]) OR Ergotami*[Text Word])) OR ((((((((Serotonin 5-HT1 receptor agonists[MeSH Terms]) OR Sumatript*[Text Word]) OR Zolmitript*[Text Word]) OR Rizatript*[Text Word]) OR Eletript*[Text Word]) OR Naratript*[Text Word]) OR Almotript*[Text Word]) OR Frovatript*[Text Word])) OR ((valproic acid[MeSH Terms]) OR ((((((((((((((((((acide valproique[Text Word]) OR acido dipropilacetico[Text Word]) OR acido valproico[Text Word]) OR acidum valproicum[Text Word]) OR dipropylacetic acid[Text Word]) OR DPA[Text Word]) OR kyselina valproova[Text Word]) OR natrii valproas[Text Word]) OR natrio valproatas[Text Word]) OR natriumvalproaatti[Text Word]) OR natriumvalproat[Text Word]) OR natrium-valproat[Text Word]) OR valproat*[Text Word]) OR valproic acid[Text Word]) OR valproiinihappo[Text Word]) OR valproik asit[Text Word]) OR valproine rugutis[Text Word]) OR valproinsav[Text Word]) OR valproinsyra[Text Word])) OR ((((((((((((((((((((((((((((((((((Analgesics, non-narcotic[MeSH terms]) OR Acetaminophen[Text Word]) OR acetaminofeno[Text Word]) OR acetominophen[Text Word]) OR apap[Text Word]) OR asetaminofen[Text Word]) OR paracetamol[Text Word]) OR paracetamolis[Text Word]) OR paracetamolum[Text Word]) OR parasetamol[Text Word]) OR parasetamoli[Text Word]) OR NSAIA*[Text Word]) OR NSAID*[Text Word]) OR nonsteroidal anti-inflammator*[Text Word]) OR non-steroidal anti-inflammator*[Text Word]) OR Aspirin[Text Word]) OR acetylsalicylic acid[Text Word]) OR ASA[Text Word]) OR acetilsalicilico[Text Word]) OR acetilszalicilsav[Text Word]) OR acetylsalicyl*[Text Word]) OR asetilsalisilik[Text Word]) OR asetyylisalisyylihappo[Text Word]) OR acetylosalicylowy[Text Word]) OR Diclofen[Text Word]) OR diklofen*[Text Word]) OR diclophen*[Text Word]) OR Ibuprofen*[Text Word]) OR Ibuprofeeni[Text Word]) OR ketoprof*[Text Word]) OR dexketoprofeno[Text Word]) OR Ketorola*[Text Word]) OR Naprox*[Text Word]) OR Naprok*[Text Word])) OR (((((((histamine h1 antagonists[MeSH Terms]) OR diphenhydramin*[Text Word]) OR ((((benzhydramin*[Text Word]) OR difenhidramin*[Text Word]) OR difenhydramiinihydrokloridi[Text Word]) OR difenhydramin*[Text Word]) OR dimedrolum[Text Word]) OR dimenhydrinat*[Text Word]) OR ((((chloranautine[Text Word]) OR dimenhidrinat*[Text Word]) OR dimenhydramina[Text Word]) OR dimenhydrina*[Text Word]) OR diphenhydramin*[Text Word]) OR butalbital*[Text Word]) OR (((((alisobumalum[Text Word]) OR allylbarbit*[Text Word]) OR butalbitaali[Text Word]) OR butalbitalum[Text Word]) OR itobarbital[Text Word]) OR tetrallobarbital[Text Word])) OR (((((((nitric oxide[MeSH Terms]) OR nitrous oxide[MeSH Terms]) OR nitric oxide[Text Word]) OR nitrous oxide[Text Word]) OR Magnesium sulphate[MeSH Terms]) OR magnesium sulfat*[Text Word]) OR magnesium sulphat*[Text Word])) OR ((((((botulinum toxins, type a[MeSH Terms]) OR ((((((Botuliinitoksiini tyyppi A[Text Word]) OR Botulinum Toxin Type A[Text Word]) OR Botulinum A Toksini[Text Word]) OR Toxin typ A mot botulism[Text Word]) OR Toxina botulinica A[Text Word]) OR Toxine botulinique type A[Text Word]) OR Toxinum Botulinicum Typum A[Text Word]) OR Lidocain*[Text Word]) OR ((lidokaiini[Text Word]) OR lidokain*[Text Word]) OR lignocain*[Text Word]) OR Xylocain*[Text Word]) OR Oxygen[Text Word])) OR ((((((drug therapy, combination[MeSH Terms]) OR drug combinations[MeSH Terms]) OR combined modality therapy[MeSH Terms]) OR placebo*[Text Word]) OR pharmacologic manag*[Text Word]) OR abortive therap*[Text Word])))) OR ((((((((((((((((((glucocorticoids[MeSH Terms])) OR (glucocorticoid*[Text Word])) OR ((corticosteroid*[Text Word]) OR steroid*[Text Word])) OR (betamethason*[Text Word])) OR (((((beetametasoni[Text Word]) OR betadexamethasone[Text Word]) OR betametason*[Text Word]) OR betametazon*[Text Word]) OR flubenisolon*[Text Word])) OR (dexamethason*[Text Word])) OR ((((((deksametason*[Text Word]) OR desamethason*[Text Word]) OR dexametason*[Text Word]) OR dexametazon*[Text Word]) OR dexamethason*[Text Word]) OR hexadecadrol[Text Word])) OR (hydrocortison*[Text Word])) OR ((((((cortisol[Text Word]) OR hidrocortisona[Text Word]) OR hidrokortizon*[Text Word]) OR hydrocortisonum[Text Word]) OR hydrokortison*[Text Word]) OR hydrokortyzon[Text Word])) OR (methylprednisolon*[Text Word])) OR ((((((meilprednizolon[Text Word]) OR methyl-prednisolon*[Text Word]) OR metilprednisolon*[Text Word]) OR metilprednizolonas[Text Word]) OR metylprednisolon[Text Word]) OR metyyliprednisoloni[Text Word])) OR (prednisolon*[Text Word])) OR (((deltahydrocortisone[Text Word]) OR metacortandralone[Text Word]) OR prednizolon*[Text Word])) OR (prednison[Text Word])) OR ((((deltacortisone[Text Word]) OR deltadehydrocortisone[Text Word]) OR metacortandracin[Text Word]) OR prednizon*[Text Word])) OR (triamcinolon[Text Word])) OR (((fluoxiprednisolonum[Text Word]) OR triamcynolon[Text Word]) OR triamsinoloni[Text Word])))) AND (((((((((((((((((((((((((emergency treatment[MeSH Terms])) OR (emergency service, hospital[MeSH Terms])) OR (emergency medical services[MeSH Terms])) OR (emergencies[MeSH Terms])) OR (ambulatory care facilities[MeSH Terms])) OR (community health centers[MeSH Terms])) OR (outpatient clinics, hospital[MeSH Terms])) OR (community health services[MeSH Terms])) OR (general practice[MeSH Terms])) OR (primary health care[MeSH Terms])) OR (((((((((((emerg department*[Text Word])) OR emerg ward*[Text Word]) OR emerg service*[Text Word]) OR emerg unit*[Text Word]) OR emerg room*[Text Word]) OR emerg hospital*[Text Word]) OR emerg care[Text Word]) OR emerg medicin*[Text Word]) OR emerg treatment*[Text Word]) OR emerg admission*[Text Word])) OR ((((((((((emergenc* AND department*[Text Word]) OR emergenc* AND ward*[Text Word]) OR emergenc* AND service*[Text Word]) OR emergenc* AND unit*[Text Word]) OR emergenc* AND room*[Text Word]) OR emergenc* AND hospital*[Text Word]) OR emergenc* AND care[Text Word]) OR emergenc* AND medicin*[Text Word]) OR emergenc* AND treatment*[Text Word]) OR emergenc* AND admission*[Text Word])) OR ((ED*[Text Word]) OR ER*[Text Word])) OR (((((ambulatory clinic*[Text Word]) OR ambulatory care[Text Word]) OR ambulatory center*[Text Word]) OR ambulatory centre*[Text Word]) OR ambulatory service*[Text Word])) OR (((((out-patient clinic*[Text Word]) OR out-patient care[Text Word]) OR out-patient center*[Text Word]) OR out-patient centre*[Text Word]) OR out-patient service*[Text Word])) OR (((((outpatient clinic*[Text Word]) OR outpatient care[Text Word]) OR outpatient center*[Text Word]) OR outpatient centre*[Text Word]) OR outpatient service*[Text Word])) OR ((community service*[Text Word]) OR community care[Text Word])) OR (primary care[Text Word])) OR (urgent care[Text Word])) OR (((((pain clinic*[Text Word]) OR pain center*[Text Word]) OR pain centre*[Text Word]) OR pain service*[Text Word]) OR pain unit*[Text Word])) OR (((((headache clinic*[Text Word]) OR headache center*[Text Word]) OR headache centre*[Text Word]) OR headache service*[Text Word]) OR headache unit*[Text Word])) OR (((((head-ache clinic*[Text Word]) OR head-ache center*[Text Word]) OR head-ache centre*[Text Word]) OR head-ache service*[Text Word]) OR head-ache unit*[Text Word])) OR (((((walkin clinic*[Text Word]) OR walkin center*[Text Word]) OR walkin centre*[Text Word]) OR walkin service*[Text Word]) OR walkin unit*[Text Word])) OR (((((walk-in clinic*[Text Word]) OR walk-in center*[Text Word]) OR walk-in centre*[Text Word]) OR walk-in service*[Text Word]) OR walk-in unit*[Text Word])))) AND (adult[MeSH] AND “last 180 days”[PDat])

Table A9 Acute migraine review - ISI Web of Knowledge^SM^

BIOSIS Previews® 1926–2011 Science Citation Index Expanded (SCI-EXPANDED) --1899-present Conference Proceedings Citation Index- Science (CPCI-S) --1990-present Search date: May 6, 2011 Number of results: BIOSIS: 476; SCI-EXPANDED: 671; CPCI-S: 51

ID | Search
#1 | TS=(migrain* or headach* or cephalgi* or cephalalgi*)
#2 | TS=(sumatript* or zolmitript* or rizatrip* or eletript* or naratript* or almotript* or frovatript* or ergot alkaloid* or dihydroergotami* or DHE or ergotami*)
#3 | TS=(acetaminophen or paracetamol or NSAIA* or NSAID* or aspirin or acetylsalicylic acid or ASA or diclofen* or ibuprofen* or ketoprof* or ketorola* or naprox*)
#4 | TS=(morphin* or buprenorphin* or butorphanol* or codein* or fentan* or hydromorphon* or meperidin* or pethidin* or nalbuphin* or tramadol* or propofol* or disoprofol or ketamin* or valproic or valproat*)
#5 | TS=(phenothiazin* or chlorpromazin* or promethazin* or methotrimeprazin* or prochlorperazin* or ondansetron* or haloperidol* or aloperidolo* or droperidol* or metoclopramid* or domperidon* or diphenhydramin* or dimenhydrinat*)
#6 | TS=(butalbital* or Botulinum Toxin Type A or lidocain* or xylocain* or oxygen or nitric oxide or nitrous oxide or magnesium sulfat* or magnesium sulphat*)
#7 | TS=(glucocorticoid* or corticosteroid* or steroid* or betamethason* or dexamethason* or hydrocortison* or methylprednisolon* or prednisolon* or prednison* or triamcinolon*)
#8 | TS=(IM or intramuscular* or IV or intravenous* or SC or subcutan* or parenteral or inject*)
#9 | TS=((emerg or emergenc*) SAME (department* or ward* or service* or unit* or room* or hospital* or care or medicin* or treatment* or admission*))
#10 | TS=(ED or ER)
#11 | TS=((pain or headache or head-ache or walkin or walk-in or out-patient or outpatient) SAME (clinic* or centre* or center* or service* or unit*))
#12 | #11 OR #10 OR #9
#13 | #12 AND #8 AND #2 AND #1
#14 | #12 AND #8 AND #3 AND #1
#15 | #12 AND #8 AND #4 AND #1
#16 | #12 AND #8 AND #5 AND #1
#17 | #12 AND #8 AND #6 AND #1
#18 | #12 AND #8 AND #7 AND #1
#19 | #18 OR #17 OR #16 OR #15 OR #14 OR #13

Table A10 Acute migraine review - Dissertations &; Theses

ProQuest Dissertations and Theses | ProQuest Dissertations and Theses - UK &; Ireland
Years/issue searched: 1637-current | Years/issue searched: 1716-current
Search date: May 1, 2011 | Search date: May 1, 2011
Number of results: 13 | Number of results: 13
(migrain* or headach* or cephalgi* or cephalalgi*) AND ( IM or intramuscular* or IV or intravenous* or SC or subcutan* or parenteral or inject*) AND (emergenc* or ED* or ER* or clinic or centre or center)
Theses Canada Portal http://www.nlc-bnc.ca/thesescanada/ Searched: 01.05.2011 Results: 1 Searched “any keyword” field combinations of: migraine or headach or cephalgi or cephalalgi AND treatment or therapy AND emergency or ED or ER or clinic or centre or center Any keyword: migraine and treatment and emergency
AMICUS No. 38061086 Richer, Lawrence. Practice variation in the treatment of children with migraine in the emergency department [microform] -- Ottawa : Library and Archives Canada = Bibliothèque et Archives Canada, 2010.
National Library of Australia Trove http://trove.nla.gov.au/ Searched: 01.05.2011 Query: migraine emergency Limit: theses Results: 3
1. The Role of Acceptance in Appraisal and Coping with Migraine Headaches (http://trove.nla.gov.au/work/24135110?l-format=Thesis&;q=+%28migraine+emergency%29&;c=book); Chiros, Christine E; [ Thesis : 2007]; Keywords: acceptance; coping; migraine; Available online (http://trove.nla.gov.au/goto?i=book&;w=24135110&;d=http%3A%2F%2Frave.ohiolink.edu%2Fetdc%2Fview%3Facc_num%3Dbgsu1189641256); 2. New Targets in Migraine Therapy; Nieuwe Behandelingstrategieën voor Migraine (http://trove.nla.gov.au/work/31424354?l-format=Thesis&;q=+%28migraine+emergency%29&;c=book); Van der Schueren, Bart; [ Thesis : 2009]; Available online (http://trove.nla.gov.au/goto?i=book&;w=31424354&;d=http%3A%2F%2Fhdl.handle.net%2F1979%2F2683); 3. Entwicklung und Habituation der P300 EKP-Komponente bei Kindern und Jugendlichen mit und ohne Migräne; Development and Habituation of the P300 ERP component with children and adolescents with and without migraine (http://trove.nla.gov.au/work/28959765?l-format=Thesis&;q=+%28migraine+emergency%29&;c=book); Pfüller, Ute; [ Thesis : 2004]; Languages: German; Keywords: p300; oddball paradigma; ereigniskorreliertes potenzial; Available online (http://trove.nla.gov.au/goto?i=book&;w=28959765&;d=http%3A%2F%2Farchiv.ub.uni-heidelberg.de%2Fvolltextserver%2Fvolltexte%2F2005%2F5204%2F); OhioLINK ETDs http://etd.ohiolink.edu/ Searched: 01.05.2011 - scanning first 100 results – none relevant Query 1: migraine emergency (any field) Results: 1773 PhD (1087) MS (239) doctoral (1170) masters (575) Query 2: keywords:(migraine emergency) Results: 79

Table A11 Acute migraine review - Meeting Abstracts &; Proceedings

Years/issue searched: 1993 – present Search date: May 1, 2011 Number of results: ProceedingsFirst: 129; papers first: 6
(kw: migrain* or kw: headach* or kw: cephalgi* or kw: cephalalgi*) and (kw: sumatript* or kw: zolmitript* or kw: rizatrip* or kw: eletript* or kw: naratript* or kw: almotript* or kw: frovatript* or kw: dihydroergotami* or kw: DHE or kw: ergotami* or kw: acetaminophen or kw: paracetamol or kw: NSAIA* or kw: NSAID* or kw: aspirin or kw: acetylsalicylic or kw: ASA or kw: diclofen* or kw: ibuprofen* or kw: ketoprof* or kw: ketorola* or kw: naprox* or kw: butorphanol* or kw: buprenorphin* or kw: fentanyl or kw: codein* or kw: morhpin* or kw: hydromorphon* or kw: meperidin* or kw: pethidin* or kw: nalbuphin* or kw: tramadol* or kw: propofol* or kw: disoprofol or kw: ketamin* or kw: valproic or kw: valproat* or kw: phenothiazin* or kw: chlorpromazin* or kw: promethazin* or kw: methotrimeprazin* or kw: prochlorperazin* or kw: ondansetron* or kw: droperidol* or kw: haloperidol* or kw: aloperidol* or kw: metoclopramid* or kw: domperidon* or kw: diphenhydramin* or kw: dimenhydrinat* or kw: butalbital* or kw: Botulinum w2 Toxin or kw: lidocain* or kw: xylocain* or kw: oxygen or kw: nitric and kw: oxide or kw: nitrous and kw: oxide or (kw: magnesium and kw: sulfat*) or (kw: magnesium and kw: sulphat*) or kw: glucocorticoid* or kw: corticosteroid* or kw: steroid* or kw: betamethason* or kw: dexamethason* or kw: hydrocortison* or kw: methylprednisolon* or kw: prednisolon* or kw: prednison* or kw: triamcinolon*) and (kw: IM or kw: intramuscular* or kw: IV or kw: intravenous* or kw: SC or kw: subcutan* or kw: parenteral or kw: inject*) and (kw: emergenc* w2 department* or kw: emergenc* w2 ward* or kw: emergenc* w2 service* or kw: emergenc* w2 unit* or kw: emergenc* w2 room* or kw: emergenc* w2 hospital* or kw: emergenc* w2 care or kw: emergenc* w2 medicin* or kw: emergenc* w2 treatment* or kw: emergenc* w2 admission* or kw: ED* or kw: ER* or kw: walk-in w2 clinic* or kw: walk-in w2 centre* or kw: walk-in w2 center* or kw: walk-in w2 service* or kw: walk-in w2 unit* or kw: headache w2 clinic* or kw: headache w2 centre* or kw: headache w2 center* or kw: headache w2 service* or kw: headache w2 unit* or kw: out-patient w2 clinic* or kw: out-patient w2 centre* or kw: out-patient w2 center* or kw: out-patient w2 service* or kw: out-patient w2 unit* or kw: out-patient w2 clinic* or kw: out-patient w2 centre* or kw: out-patient w2 center* or kw: out-patient w2 service* or kw: out-patient w2 unit)

Table A12 Acute migraine review - NLM Gateway

Search date: May 1, 2011
Query 1: emergency treatment adult migraine
Results: 206 →no meeting abstracts
Query 2: adult migraine emergency
Results: 420 → no meeting abstracts | ClinicalTrials.gov: 18
Query 3: adult migraine emergency therapy
Results: 285 → no meeting abstracts | ClinicalTrials.gov: 17

Table A13 Acute migraine review - Handsearching (Journals – supplements)

Websites (Google and Exalead)

FDA.gov http://www.fda.gov/ FDA site search based on highlighted terms; - Used Google advanced search, searching within a site or domain; - DRUG NAME parenteral injection migraine adult site:http://www.fda.gov/; This is a screenshot of a Google advanced search screen.; Search terms taken from search below. Searching only US spelling of generic drug name; no synonyms or acronyms Search date: June 21, 2011–July 27, 2011
1. Migraine Disorders/; 2. migraine with aura/; 3. migraine without aura/; 4. Headache/; 5. exp Headache Disorders/; 6. migrain$.mp.; 7. (headach$ or head-ach$).tw.; 8. (cephalgi$ or cephalalgi$).tw.; 9. or/1–8; 10. exp serotonin 5-HT1 receptor agonists/; 11. sumatript$.mp.; 12. zolmitript$.mp.; 13. rizatrip$.mp.; 14. eletript$.mp.; 15. naratript$.mp.; 16. almotript$.mp.; 17. frovatript$.mp.; 18. exp ergot alkaloids/; 19. dihydroergotami$.mp.; 20. DHE.tw.; 21. ergotami$.mp.; 22. exp analgesics, non-narcotic/; 23. acetaminophen.mp.; 24. (acetaminofeno or acetominophen or apap or asetaminofen or paracetamol or paracetamolis or paracetamolum or parasetamol or parasetamoli).tw.; 25. exp anti-inflammatory agents, non-steroidal/; 26. (NSAIA? or NSAID?).tw.; 27. ((nonsteroidal or non-steroidal) adj anti-inflammator$).tw.; 28. aspirin.mp.; 29. (acetylsalicylic acid or ASA).tw.; 30. (acetilsalicilico or acetilszalicilsav or acetylsalicyl$ or asetilsalisilik or asetyylisalisyylihappo or acetylosalicylowy).tw.; 31. diclofen$.mp.; 32. (diklofen$ or diclophen$).tw.; 33. ibuprofen$.mp.; 34. ibuprofeeni.tw.; 35. (ketoprof$ or dexketoprofeno).mp.; 36. ketorola$.mp.; 37. naprox$.mp.; 38. naprok$.tw.; 39. exp analgesics, opioid/; 40. exp narcotics/; 41. morphine/; 42. (morphin* or morfiini* or morfin*).mp.; 43. buprenophin*.mp.; 44. butorphanol$.mp.; 45. butorfanol$.tw.; 46. codein$.mp.; 47. (kodeiini or kodein or kodeina or kodeinas or methylmorphine or metilmorfina or morphine methyl ether).tw.; 48. fentanyl.mp.; 49. hydromorphon*.mp.; 50. meperidin$.mp.; 51. (pethidin$ or petidiinihydrokloridi or petidin$ or petidinhydroklorid or petydyny).tw.; 52. nalbuphin$.mp.; 53. nalbufin$.tw.; 54. tramadol$.mp.; 55. propofol$.mp.; 56. disoprofol.tw.; 57. ketamin$.mp.; 58. valproic acid/; 59. (acide valproique or acido dipropilacetico or acido valproico or acidum valproicum or dipropylacetic acid or DPA or kyselina valproova or natrii valproas or natrio valproatas or natriumvalproaatti or natriumvalproat or natrium-valproat or valproat$ or valproic acid or valproiinihappo or valproik asit or valproine rugutis or valproinsav or valproinsyra).tw.; 60. exp antiemetics/; 61. (antiemetic$ or anti-emetic$).tw.; 62. haloperidol/; 63. (haloperidol* or aloperidolo).mp.; 64. Trimethobenzamide.mp.; 65. exp Phenothiazines/; 66. chlorpromazin$.mp.; 67. (klooripromatsiini$ or klorpromazin$ or aminazine or chlor#promaz$).tw.; 68. promethazin$.mp.; 69. (prometatsiini or prometazin or prometazina or promethazinum).tw.; 70. methotrimeprazin$.mp.; 71. (levomeproma$ or lewomepromazyny).tw.; 72. prochlorperazin$.mp.; 73. (chlormeprazine or prochlorpemazine or proklooriperatsiini or proklorperazin).tw.; 74. ondansetron$.mp.; 75. droperidol$.mp.; 76. metoclopramid$.mp.; 77. metoklopramid$.tw.; 78. domperidon$.mp.; 79. exp histamine h1 antagonists/; 80. diphenhydramin$.mp.; 81. (benzhydramin$ or difenhidramin$ or difenhydramiinihydrokloridi or difenhydramin$ or dimedrolum).tw.; 82. dimenhydrinat$.mp.; 83. (chloranautine or dimenhidrinat$ or dimenhydramina or dimenhydrina$ or diphenhydramin$).tw.; 84. butalbital$.mp.; 85. (alisobumalum or allylbarbit$ or butalbitaali or butalbitalum or itobarbital or tetrallobarbital).tw.; 86. Botulinum Toxins, Type A/; 87. (Botuliinitoksiini tyyppi A or Botulinum Toxin Type A or Botulinum A Toksini or Toxin typ A mot botulism or Toxina botulinica A or Toxine botulinique type A or Toxinum Botulinicum Typum A).tw.; 88. lidocain$.mp.; 89. (lidokaiini or lidokain$ or lignocain$).tw.; 90. xylocain$.tw.; 91. oxygen.mp.; 92. nitric oxide/ or nitrous oxide/; 93. ((nitric or nitrous) adj oxide).tw.; 94. magnesium sulfate/; 95. (magnesium adj (sulfat$ or sulphat$)).tw.; 96. drug therapy, combination/; 97. drug combinations/; 98. combined modality therapy/; 99. placebo$.mp.; 100. (pharmacologic adj manag$).tw.; 101. (abortive adj therap$).tw.; 102. or/10–101; 103. cortisone/; 104. (coritson* or kortison* or kortizon* or kortyzon*).mp.; 105. exp glucocorticoids/; 106. glucocorticoid?.tw.; 107. (corticosteroid? or steroid$).tw.; 108. betamethason$.mp.; 109. (beetametasoni or betadexamethasone or betametason$ or betametazon$ or flubenisolon$).tw.; 110. (budesonid* or budezonid*).mp.; 111. dexamethason$.mp.; 112. (deksametason$ or desamethason$ or dexametason$ or dexametazon$ or hexadecadrol).tw.; 113. hydrocortison$.mp.; 114. (cortisol or hidrocortisona or hidrokortizon$ or hydrocortisonum or hydrokortison$ or hydrokortyzon).tw.; 115. methylprednisolon$.mp.; 116. (meilprednizolon or methyl-prednisolon$ or metilprednisolon$ metilprednizolonas or metylprednisolon or metyyliprednisoloni).tw.; 117. prednisolon$.mp.; 118. (deltahydrocortisone or metacortandralone or prednizolon$).tw.; 119. prednison$.mp.; 120. (deltacortisone or deltadehydrocortisone or metacortandracin or prednizon$).tw.; 121. triamcinolon$.mp.; 122. (fluoxiprednisolonum or triamcynolon or triamsinoloni).tw.; 123. or/103–122; 124. or/10–122; 125. Injections, Intramuscular/; 126. Injections, Intravenous/; 127. Injections, Subcutaneous/; 128. Infusions, Intravenous/; 129. Infusions, Parenteral/; 130. (IM or intramuscular$ or intra-muscular$).tw.; 131. (IV or intravenous$ or intra-venous$).tw.; 132. (SC or subcutan$ or sub-cutan$ or sub-cu?).tw.; 133. (parenteral$ adj2 (inject$ or administ$ or therap$ or treatment?)).tw.; 134. or/125–133; 135. Emergency Treatment/; 136. Emergency Service, Hospital/; 137. Emergency Medical Services/; 138. Emergencies/; 139. Ambulatory Care Facilities/; 140. Community Health Centers/; 141. exp Outpatient Clinics, Hospital/; 142. Community Health Services/; 143. exp General Practice/; 144. Primary Health Care/; 145. ((emerg or emergenc$) adj3 (department? or ward? or service? or unit? or room? or hospital? or care or medicin$ or treatment? or admission?)).tw.; 146. ED?.tw.; 147. ER?.tw.; 148. (ambulatory adj2 (clinic? or care or centre? or center? or service?)).tw.; 149. ((out-patient or outpatient) adj2 (clinic? or care or centre? or center? or service?)).tw.; 150. (community adj2 (service? or care)).tw.; 151. (primary adj2 care).tw.; 152. (urgent adj2 care).tw.; 153. ((pain or headache or head-ache or walkin or walk-in) adj2 (clinic? or centre? or center? or service? or unit?)).tw.; 154. or/135–153; 155. and/9,124,134,154; 156. limit 155 to “all adult (19 plus years)”; 157. exp animals/ not humans.sh.; 158. 156 not 157; 159. (comment or editorial or letter).pt.; 160. 158 not 159; 161. remove duplicates from 160; 162. and/102,134; 163. or/123,162; 164. and/9,154,163; 165. limit 164 to “all adult (19 plus years)”; 166. 165 not 161

Table A14 Acute migraine review - Cited Reference Search

Trials Registries ClinicalTrials.gov http://clinicaltrials.gov/ Searched: 01.05.2011 Limits: Adult, senior Results: 7 Excel file: AcuteMigraineTrials_20110501 Query: emergency \| acute migraine \| Adult, Senior metaRegister of Controlled Trials (mRCT) http://www.controlled-trials.com/mrct/ Searched: 01.05.2011 Results: 79 Word file: AcuteMigraine_Trials_20110501 (p1–11) Query: acute migraine WHO International Clinical Trials Registry Platform (ICTRP) http://www.who.int/ictrp/en/ Search portal: http://apps.who.int/trialsearch/ Results: Word file: AcuteMigraine_Trials _20110501 (p12 Query 1: Basic search: acute migraine AND emergency Results: 4 Query 2: Advanced search: Condition: acute migraine; Recruitment status: ALL Results: 9 CenterWatch – no longer freely accessible – see webpage on “Headaches”* http://www.centerwatch.com/ Follow link: Drug Information > Drugs in Clinical Trials Database Subscription Information: The Drugs in Clinical Trials Database is accessible only by subscription (http://store.centerwatch.com/p-127-drugs-in-clinical-trials-database.aspx), which can be purchased in the CenterWatch Bookstore (http://store.centerwatch.com/p-127-drugs-in-clinical-trials-database.aspx). For a free trial, please contact tracy.lawton@centerwatch.com. *Home (http://www.centerwatch.com/)» Clinical Trials (http://www.centerwatch.com/clinical-trials/) » Search Clinical Trials (http://www.centerwatch.com/clinical-trials/listings/) Parent Therapeutic Areas: Neurology (http://www.centerwatch.com/clinical-trials/listings/categorylist.aspx?AreaID=10) “H” Headaches (5) http://www.centerwatch.com/clinical-trials/listings/studylist.aspx?CatID=388

Table A15 Results summary

Database | Dates Searched | Number of results: Before TEP call (May); After TEP call (June) | After Duplicate Removal
Medline <1948 to June Week 1 2011> | 1948 to June 2011 | 152; 57 | 150; 46
Embase <1980 to 2011> | 13 June 2011 | 283; 197 | 172; 157
EBM Reviews—CENTRAL (2^nd^ Quarter 2011) | 13 June 2011 | 4; 0 | 2; 0
EBM Reviews—CDSR (2005 to March 2011) | 30 June 2011 | 182; 80 | 182; 78
EBM Reviews—DARE (2^nd^ Quarter 2011) | 30 June 2011 | 12; 3 | 12; 3
Medline In-Process &; Other Non-Indexed Citations (30 June 2011) | 30 June 2011 | 9; 11 | 6; 7
Pascal (1984 to 2011 Week 26) | 30 June 2011 | 89; 33 | 12; 8
International Pharmaceutical Abstracts (1970 to June 2011) | 30 June 2011 | 34; 7 | 20; 5
CINAHL Plus with Full Text (1937 to present) | 14 June 2011 | 54; 77 | 43; 50
Academic Search Complete (1887 to present) | 14 June 2011 | 87; 114 | 82; 39
PubMed (last 180 days) | 14 June 2011 | 8; 14 | 8; 6
Biosis Previews (1926–2011) | 5 June 2011 | 249; 230 | 94; 82
Science Index Expanded (1899 to present) | 5 June 2011 | 466; 205 | 358; 149
Conference Proceedings Citation Index–Science (1990 to present) | 5 June 2011 | 51; 0 | 1; 0
ProQuest Dissertations and Theses–Ireland (1637 to current) &; UK (1716 to current) | 1 May 2011 | 13; 0 | 13; 0
These Canada Portal | 1 May 2011 | 1; 0 | 1; 0
National Library of Australia Trove | 1 May 2011 | 3; 0 | 3; 0
OCLC Papers First (1993 to present) | 1 May 2011 | 6; 0 | 6; 0
OCLC Proceedings First (1993 to present) | 1 May 2011 | 129; 0 | 129; 0
Total results | | 2858 | 1922