# Acronyms

AHRQ: Agency for Healthcare Research and Quality
CER: Comparative effectiveness review
CI: confidence interval
DHE: dihydroergotamine
ED: emergency department
EPC: Evidence-based Practice Center
GRADE: Grading of Recommendations Assessment, Development and Evaluation
HT: 5-hydroxytryptamine
hr: hour(s)
IQR: interquartile range
IV: intravenous
kg: kilogram(s)
MD: mean difference
mg: milligram(s)
MgSO_4_: magnesium sulfate
ml: milliliter(s)
mm: millimeter(s)
min: minutes
NRCT: nonrandomized controlled trial
NSAIDs: nonsteroidal anti-inflammatory drug
OR: odds ratio
RCT: randomized controlled trial
RR: risk ratio
VAS: visual analogue scale