# Acknowledgments

The authors gratefully acknowledge the following individuals for their contributions to this project: Ms. Annabritt Chisholm (article retrieval), Ms. Teodora Radisic (article retrieval), Ms. Tamara Durec (literature searching), and Ms. Andrea Milne (literature searching).