# Results

## Introduction

In this Chapter, the results of literature searches come first, followed by the descriptions of all included studies and the overall strength of evidence table. The results of our syntheses were presented in the order of the Key Questions, from Key Question 1 to 4. Within each Key Question, we first summarize the key points of the findings and then present a more detailed synthesis of the literature. Please refer to Chapter 2. Methods for the methods used to synthesize the literature.

The majority of the included studies were related to test performance (Key Question 2), and they addressed many different laboratory markers and reference standard pairs. Thus, we organized studies included in Key Question 2 alphabetically by newer laboratory markers of iron status.

A list of abbreviations and acronyms can be found at the end of the report, following the references.

## Literature Searches

The literature search yielded 6407 citations. From these, 694 articles were retrieved for full-text screening on the basis of abstracts and titles. Full-text articles were screened on the basis of study eligibility criteria; thirty articles were judged to have met the inclusion criteria. Figure 3 summarizes the study selection flow. A total of 664 articles were rejected on double, independent full-text screening because they did not meet one or more of the PICO criteria for a particular Key Question (see Appendix B for the list of rejected articles and the reasons for their rejection). The two most common reasons for rejection were: a) no diagnostic outcomes reported (studies reported only correlations between markers or the measurements of levels of markers before and after treatment); b) no comparative data for the outcomes of management strategies where treatment decisions were guided by test results (newer versus classical markers). Finally, a total of 30 articles were accepted,41–70 including one Polish and one Japanese language publication.

Figure 3 Literature flow

^*^ Total for articles included in the Key Questions do not add up to 30 because one study66 contributed to both Key Question 2 and Key Question 3.

Figure 4 is a flow chart that summarizes the study retrieval and selection process of articles on laboratory biomarkers for iron deficiency anemia in late stage chronic kidney disease, relevant to the four Key Questions addressed within this report. The figure displays the same information as enumerated in the second paragraph of the chapter entitled Results. In addition, the figure includes the following numbers of studies that were reviewed for each Key Question: Key Question 1, 0 studies; Key Question 2, 27 studies; Key Question 3, 2 studies; Key Question 4, 2 studies.

## Description of Included Studies

Thirty articles were included. Twenty seven articles reported data on the test performance of newer markers of iron status compared with classical markers (Key Question 2),41–67 two reported the intermediate outcomes comparing the iron management guided by the newer laboratory markers with that guided by the classical markers (Key Question 3),66,70 and three (in two articles) reported data on the factors that affected the test performance comparing newer with classical laboratory markers of iron status (Key Question 4).68,69 Most studies enrolled only adult CKD patients undergoing hemodialysis. Eighteen studies did not reported information regarding their funding sources. Four studies were funded by the industry.41,64,68,70 Eight studies received funding from nonprofit sources, such as national kidney training fellowships,43,59 internal university hospital grant,52 academic foundation grant,56 or government funding.42,47,62,66

Detailed characteristics of included studies are presented later with results for each Key Question.

## Key Question 1 Comparative Effectiveness of Newer Versus Older Markers of Iron Status for the Diagnosis and Management of Iron Deficiency Anemia

No study reported on patient centered outcomes (mortality, morbidity, quality of life, and adverse effects) when using newer laboratory markers as a replacement for or an add-on to the classical laboratory markers for assessing iron status and management of iron deficiency in stages 3–5 CKD nondialysis and dialysis patients, and in patients with a kidney transplant.

This question of overall impact on patient centered outcomes was broken out into three component Key Questions (Key Questions 2 to 4). Combining evidence gather to address these three component Key Questions can thus inform the conclusions for this reviews primary, overarching question.

## Key Question 2 Test Performance of Newer Markers Compared With the Older Markers of Iron Status

### 2a Reference Standards for the Diagnosis of Iron Deficiency in Studies Evaluating Test Performance

A total of 27 studies were included for Key Question 2. Current studies use two distinct methods to operationalize a reference standard for assessing test performance: (1) a response to intravenous (IV) iron treatment; and (2) classical laboratory biomarkers, alone or in combination with each other. However, across studies, there are large variations in the definitions of these reference standards.

Of the 27 included studies, 15 used classical markers of iron status to define “iron deficiency” as the reference standard in calculating the test accuracy (sensitivity and specificity) of newer markers of iron status.41–43,45,48,49,51,53–57,60,63,66 These studies used the following definitions: (1) TSAT ≤ 15%;48 (2) TSAT ≤ 20%;41–43,53,57,63,66 (3) ferritin ≤100 ng/mL;43 (4) TSAT ≤20 percent and ferritin ≤100 ng/mL;49,51,53–55,63 (5) TSAT ≤20% or ferritin ≤100 ng/mL;51,56,60,66 (6) serum iron < 40 μg/dL, TSAT<20%, ferritin <100 ng/mL, and Hb <11 g/dL;45 (7) TSAT<20 percent, ferritin 100–800 ng/mL, and Hb <11 g/dL;45 and (8) TSAT <16 percent and ferritin <12 ng/mL.54 Many of these studies evaluated more than one newer marker at different test cutoffs, including content of hemoglobin in reticulocytes (CHr), percent hypochromic red blood cells (%HYPO), reticulocyte hemoglobin content (RetHe), soluble transferrin receptor (sTfR), and erythrocyte zinc protoporphyrin (ZPP). As described in Methods, results from these 15 studies are analogous to assessing the concordance between classical and newer biomarkers of iron status. Since concordance between the tests cannot tell us which test is better and which is worse—both may be equally bad or equally good for defining “iron deficiency”—and cannot answer Key Question 2, the results of these 15 studies are only described in Appendix D.

Of the 27 included studies, 12 studies investigated the test accuracy of newer or classical markers of iron status, using a response to IV iron treatment as the reference standard for diagnosis of iron deficiency.44,46,47,50,52,58,59,61,62,64,65,67 However, there exists a high degree of heterogeneity in the reference standards used across studies as well (details are described later in Table 2). The most commonly used definition for a response to IV iron treatment was an increase in hemoglobin (Hb) concentration ≥1 g/dL after a (variable) period of IV iron treatment.44,46,62,64,67 Other reference standards include a ≥ 15 percent increase in Hb,61 an increase in Hct of ≥3 percent and/or a ≥ 30 percent reduction in erythropoietin (EPO) dose,47 >1 point increase in corrected reticulocyte index,52 and 5 percent increase in Hct or a decrease in EPO dose of >2000 units per treatment.65 It should be noted that there was no uniform regimen of IV iron in terms of dosage and iron formulation across these studies. There was also a wide range of durations of IV iron treatment across studies. The potential impact of IV iron treatment regimen on the test performance of newer or classical laboratory markers of iron status is not known.

Table 2 An evidence map of studies of newer or classical markers of iron status in predicting a response to intravenous iron treatment in adult CKD patients

Study, Year [UI] | Population | Total N_enrolled_ | IV Iron Treatment | Reference Standard (Response to IV Iron Therapy) | Ferritin | TSAT | CHr | RetHe | %HYPO | ZPP | sTfR | Hepcidin
Studies Investigating Both Newer and Classical Markers
Bovy, 2007^44^ [17237481] | HD CKD | 32 | IV iron sucrose (1200 mg total)—100 mg at the end of dialysis session over 4 wks | ≥1 g/dL increase in Hb during the 4-week IV iron Tx | √ | √ | √ | | √ | | √
Buttarello, 2010^46^ [20472854] | HD CKD | 69 | IV iron gluconate and α-darbepoetin to maintain Hb between 11.0 & 12.0 g/dL | ≥1 g/dL increase in Hb at any time after the third wk of IV iron Tx | √ | √ | √ | √ | √
Fishbane, 1995^65^ [7872320] | HD CKD | 62 | 1,000 mg IV iron dextran in 100 mg doses over 10 sequential HD Tx | 5% increase in Hct or a decrease in EPO dose of >2000 units/ treatment over 3–6 mths | √ | √ | | | | √
Mitsuiki, 2003^58^ [14586744] | HD CKD | 27 | 40 mg of chondroitin sulfate-iron colloid IV once a wk after the regular dialysis session | Change in Hct ≥3% (or change in Hb ≥1 g/dL) within 8 wks after IV iron Tx | √ | √ | √
Mittman, 1997^59^ [9398141] U.S. | HD CKD | 79 | Single bolus of 500 mg IV iron dextran over 2 hours during a regular hemodialysis session | >1 point increase in corrected reticulocyte index at any point during the 2 wks after IV iron Tx | √ | √ | √
Tessitore, 2001^61^ [11427634] | HD CKD | 125 | IV sodium ferric gluconate complex in sucrose as a slow (2 min) IV bolus at end of dialysis with 31 or 62 mg iron as per predialysis serum transferrin (< or > 170 mg/dL, respectively) | ≥15% increase in Hb at any 2 consecutive measurements (evaluated every 2 wks) | √ | √ | √ | | √* | √ | √
Tessitore, 2010^62^ [20538788] | HD CKD | 56 | 1 g intravenous iron (62.5 mg ferric gluconate at 16 consecutive dialysis sessions) | ≥1 g/dL increase in Hb after 6 wks IV iron treatment | √ | √ | √ | | √* | | | √
Van Wyck, 2005^64^ [16316362] | ND CKD | 95 | IV iron sucrose 1,000 mg in divided doses over 14 days, as either 500 mg IV infusions on study days 0 and 14 or 200 mg injections on five different days from day 0 to day 14. | ≥ 1 g/dL increase in Hb after 8 wks IV iron Tx | √ | √ | √
Studies Investigating Newer Markers Alone
Chuang, 2003^47^ [12543894] | HD CKD | 95 | IV iron saccharate 100 mg at end of each dialysis session, three times a week for 4 wks, then 100 mg every 2 wks for 5 mths | Rise in Hct of ≥3% or a reduction in rHuEpo dose of ≥30% over the baseline values at the end of the study | | | √
Fishbane, 1997^52^ [9211366] | HD CKD | 50 | 1,000 mg of IV iron dextran infused over two hours as a single-dose infusion | 1 point increase in the corrected reticulocyte index within two wks of IV iron Tx | | | √ | | √
Silva, 1998^67^ [9794562] | HD CKD | 33 | IV Iron saccarate 20 mg diluted in 10 mL saline, and given in last 10 minutes of dialysis | ≥ 1 g/dL increase in Hb during the 6 mths of IV iron Tx | | | | | √
Domrongkitchaiporn, 1999^50^ [10401012] | PD CKD | 23 | IV iron—1000 mg ferric saccharate-infused over 2 hours in two divided doses 1 wk apart | Sustained >1 g/dL increase in Hb within 3 mths of IV iron Tx | | | √

%HYPO=percent of hypochronic red blood cell; CHr=content of hemoglobin in reticulocytes; CKD=chronic kidney disease; ESRD=end stage renal disease; Hb=hemoglobin; Hct=hematocrit; HD=hemodialysis; IV=intravenous; mths=months; ND=nondialysis; PD=peritoneal dialysis; RetHe=reticulocyte hemoglobin equivalent; rHuEpo=recombinant human erythropoietin; sTfR=soluble transferrin receptor; TSAT=transferrin saturation; Tx=treatment; UI=universal identifier/Pubmed ID; wk=week; ZPP=erythrocyte zinc protoporphyrin

√ = marker was investigated

√* = best predictors of iron deficiency among all other markers

As described in Methods, these 12 studies, which used a response to IV iron treatment as the reference standard for iron deficiency, allowed us to directly compare the test performance of classical with newer biomarkers in predicting a response. Thus, the results from these studies were synthesized to answer Key Question 2.

#### Comparisons of Test Performance of Newer Versus Classical Markers of Iron Status To Predict a Response to Intravenous Iron Treatment

In this section, we summarize the findings from 12 studies (10 prospective cohorts, one retrospective cohort, and one cohort study of unclear directionality) evaluating the test performance of newer or classical laboratory markers of iron status, using a response to IV iron treatment as the reference standard for diagnosis of iron deficiency. Of these 12 studies, eight reported comparative data between five of the newer markers (no studies addressed SQUIDD) and the classical markers (although not all studies performed formal statistical testing for the comparisons). Seven of these eight enrolled adult hemodialysis (HD CKD) patients,44,46,52,58,59,61,62 and one study enrolled adult nondialysis (ND CKD) patients.64 The remaining four studies investigated the test performance of newer laboratory markers alone. Of these four, three enrolled adult HD CKD patients,47,52,67 and one enrolled adult peritoneal dialysis (PD CKD) patients.50 None of the reviewed studies enrolled pediatric CKD patients, and we did not include studies evaluating the test performance of classical markers alone.

Table 2 tabulates the newer or classical markers of iron status that were investigated in each study. In summary, content of hemoglobin in reticulocytes (CHr) was investigated in 10 studies, percent hypochromic red blood cells (%HYPO) in six studies, soluble transferrin receptor (sTfR) and erythrocyte zinc protoporphyrin (ZPP) in two studies each, and hepcidin and reticulocyte hemoglobin content (RetHe) in one study each. Five studies investigated more than one newer marker. Both transferrin saturation (TSAT) and ferritin were investigated in the seven studies that reported comparative data between newer and classical markers. The most commonly used definition for a response to IV iron treatment was an increase in hemoglobin (Hb) concentration ≥1 g/dL after a period of IV iron treatment (Table 2). However, there was no uniform regimen of IV iron in terms of dosage and iron formulation. There was also a wide range of durations of IV iron treatment across studies. The potential impacts of IV iron treatment regimen on the test performance of newer or classical laboratory markers of iron status are not known. Additionally, there was a high degree of heterogeneity in definitions for the reference standard (a response to IV iron treatment) and background treatment across studies (Table 3). This heterogeneity prevented us from performing meta-analyses and limits our confidence in the validity of evaluating the consistency of findings across studies.

Table 3 Characteristics of studies evaluating the ability of newer or classical markers of iron status to predict the response to IV iron treatment

Study, Year [UI] Country | Study Design Recruitment Method | Sampling Population | N_enrolled_ /N_analyzed_ | Demographics | Anemia and Iron Status Indices | Background Treatment | Risk of Bias
Studies Investigated Both Newer and Classical Markers
Bovy, 2007^44^ [17237481] Belgium | Prospective cohort Selected sample | HD CKD | 32/32 | Male (%): 59 Age (yr): 65 Race (%): NR | Hb (g/dL): 12.3 Hct (%): 38.8 ferritin (ng/mL): 347 TSAT (%): 21 | ESA dose: 153.5 IU/kg/wk Iron washout: 4 wks | Medium
Buttarello, 2010^46^ [20472854] Italy | Prospective cohort Selected sample | HD CKD | 69/59 | Male (%):NR Age (yr): NR Race (%): NR | Hb (g/dL): 11.0 Hct (%): NR ferritin (ng/mL): 238 TSAT (%): 18 | ESA dose: NR Iron washout: 3 wks | Medium
Fishbane, 1995^65^ [7872320] U.S. | Prospective cohort | HD CKD | 62/62 | Male (%): 47 Age (yr): 52 Race (%): NR | Hb (g/dL): NR Hct (%):NR ferritin (ng/mL): NR TSAT (%): NR | ESA dose: NR Iron washout: No washout, though subjects with transfusions within 3 months were excluded | High
Mitsuiki, 2003^58^ [14586744] Japan | Retrospective cohort Selected sample | HD CKD | 27/27 | Male (%): 30 Age (yr): 59 Race (%): NR | Hb (g/dL): NR Hct (%): 26.8 ferritin (ng/mL):83.6 TSAT (%): 27.7 | ESA dose: 4139 IU/wk Iron washout: 12 wks | Medium
Mittman, 1997^59^ [9398141] U.S. | Prospective cohort | HD CKD | 79/79 | Male (%): 50 Age (yr): 63 Race (%): Black-75 | Hb (g/dL): NR Hct (%): 34.1 ferritin (ng/mL): 155.5 TSAT (%): 24.5 | ESA dose: NR Iron washout: 4 wks | Medium
Tessitore, 2001^61^ [11427634] Italy | Cohort (prospective or retrospective NR) Selected sample | HD CKD | 125/125 | Male (%): 80 Age (yr): 31 to 84 Race (%): NR | Hb (g/dL): 9.9 Hct (%): NR ferritin (ng/mL): 201 TSAT (%): 22 | ESA dose: 7216 IU/wk Iron washout: 3 wks | High
Tessitore, 2010^62^ [20538788] Italy | Prospective cohort Selected sample | HD CKD | 56/56 | Male (%): 57 Age (yr): 67 Race (%): NR | Hb (g/dL): 11.6 Hct (%): NR ferritin (ng/mL):146 TSAT (%): 20 | ESA dose: 8000 IU/wk Iron washout: 10 wks | Low
Studies Investigated Newer Markers Alone
Chuang, 2003^47^ [12543894] Taiwan | Prospective Cohort Selected sample | HD CKD | 95/65 | Male (%): 51 Age (yr): 60 Race (%): NR | Hb (g/dL): 9.8 Hct (%): 30.1 ferritin (ng/mL): 244 TSAT (%): 38.5 | ESA dose: 90 IU/wk/kg Iron washout: 12 wks | High
Fishbane, 1997^52^ [9211366] U.S. | Prospective cohort Random sampling | HD CKD | 50/32 | Male (%): NR Age (yr): NR Race (%): NR | Hb (g/dL): NR Hct (%): 32.7 ferritin (ng/mL): 231 TSAT (%): NR | ESA dose: NR Iron washout: 4 wks | High
Silva, 1998^67^ [9794562] Portugal | Prospective cohort Selected sample | HD CKD | 33/33 | Male (%): 61 Age (yr): 58 Race (%): NR | Hb (g/dL):10.8 Hct (%): NR ferritin (ng/mL):137 TSAT (%): 27 | ESA dose: 118.2 IU/kg/wk Iron washout: NR (61% patients received oral iron) | High
Van Wyck, 2005^64^ [16316362] U.S. | Prospective cohort | ND CKD (stage 3–5) | 95/79 | Male (%): 33 Age (yr): 62 Race (%): Caucasian-56 Black-38 Other-6 | Hb (g/dL): 10.2 Hct (%): NR ferritin (ng/mL): 92.6 TSAT (%): 16.4 | ESA dose: NR Iron washout: 24 wks | Medium
Domrongkitchaiporn, 1999^50^ [10401012] Thailand | Prospective Cohort Selected sample | PD CKD | 23/21 | Male (%): 67 Age (yr): 51 Race (%): NR | Hb (g/dL): 8.4 Hct (%): NR ferritin (ng/mL): 643 TSAT (%): 33.9 | ESA dose: 71 IU/wk/kg Iron washout: 4 wks | Medium

CKD=chronic kidney disease; ESA=erythropoiesis stimulating agents; ESRD=end stage renal disease; Hb=hemoglobin; Hct=hematocrit; HD=hemodialysis; Hr=content of hemoglobin in reticulocytes; IV=intravenous; IU=international units; ND=nondialysis; NR=not reported; PD=peritoneal dialysis; TSAT=transferrin saturation; UI=universal identifier/Pubmed ID; wk=week; yr=year

Interpretations of the summarized results for the overall test accuracy (measured by area under the ROC curve) or sensitivity and specificity (at specified cutoff values) comparing newer with classical markers of iron status to predict iron deficiency (as defined by a response to IV iron treatment) in adult HD CKD patients are described in Table 4. To facilitate indirect comparisons across studies through visual inspections, the test accuracy of the newer or classical markers of iron status for diagnosing iron deficiency among adult HD CKD patients were plotted in a receiver operating characteristics (ROC) space (Figures 4 and 5). Individual markers of iron status were plotted in a separate panel of Figures 4 and 5. Data in this figure were extracted from the seven studies that reported comparative data between newer and classical markers,44,46,58,59,61,62,65 and three additional studies that investigated the test performance of newer laboratory markers alone.47,52,67 The results from each of the single studies examining adult ND CKD patients64 and adult PD CKD patients50 were not plotted in the ROC space.

Table 4 Interpretations of the summarized results for the direct comparisons of the overall test accuracy or sensitivity and specificity (at specified cutoff values) of newer versus classical markers of iron status (at baseline) to predict a response to intravenous iron treatment^a^ in seven cohort studies among adult HD CKD patients

Iron Status Marker | Total Number of Studies (Total N) [Risk of Bias] | Overall Test Accuracy When Compared With TSAT | Sensitivity and Specificity When Compared With TSAT <20% | Overall Test Accuracy When Compared With Ferritin | Sensitivity and Specificity When Compared With Ferritin <100 ng/mL | Sensitivity and Specificity When Compared With TSAT <20% or Ferritin <100 ng/mL | Other Comparative Results
CHr/RetHe | 6 CHr studies44,46,58,59,61,62 (388) [1 low,62 4 medium,44,46,58,59 1 high risk61] | NS difference (4 studies)44,61,62 CHr better (2 study)46,58 | CHr <30 or <29 pg worse (1 study)44 CHr <27 or <28 pg better (1 study)59 | NS difference (2 studies)44,62 CHr better (3 studies)46,58,61 | CHr <29 pg worse (1 study)44 CHr <30 pg better (1 study)44 CHr <27 or <28 pg better (1 study)59 | CHr <30 or <29 pg worse (1 study)44 CHr <27 or <28 pg better (1 study)59 | Combination of %HYPO >6% with CHr ≤29 pg produced minor improvement in sensitivity and specificity (1 study)61
CHr/RetHe | 1 RetHe study46 (69) [1 medium risk46] | RetHe better (1 study)46 | | | | | NS difference between RetHe and CHr (1 study)46
%HYPO | 4 studies44,46,61,62 (282) [1 low,62 2 medium,44,46 1 high risk61] | NS difference (1 study)44 %HYPO better (3 studies)46,61,62 | %HYPO >10% better (1 study)44 %HYPO >6% better (1 study)61 | NS difference (1 study)44 %HYPO better (3 studies)46,61,62 | %HYPO >10% better (1 study)44 %HYPO >6% better (1 study)61 | %HYPO >10% better (1 study)44 %HYPO >6% better (1 study)61 | %HYPO was the only significant predictor of a response to IV iron treatment among all other markers^b^ (2 study)61,62 Combination of % HYPO >6 with TSAT≤20% produced a substantial increase in sensitivity but reduce in specificity (1 study)61
ZPP | 2 studies61,65 (187) [2 high risk61,65] | NS difference (1 study)61 ZPP better (1 study)65 | ZPP >90 μmol/mol better (1 study)65 ZPP >52 μmol/mol better (1 study)61 | NS difference (1 study)61 ZPP better (1 study)65 | ZPP >90 μmol/mol better (1 study)65 ZPP >52 μmol/mol better (1 study)61 | ZPP >52 μmol/mol better (1 study)61 | Combination of % HYPO >6 with ZPP >52 μmol/mol produced a substantial increase in sensitivity but reduce in specificity (1 study)61
sTfR | 2 studies44,61 (157) [1 medium,44 1 high risk61 | NS difference (2 studies)44, 61 | sTfR >1.5 pg better (1 study)61 | NS difference (2 studies)44, 61 | sTfR >1.5 pg better (1 study)61 | sTfR >1.5 pg better (1 study)61
Hepcidin | 1 study62 (56) [1 low risk62] | NS difference (1 study)62 | | NS difference (1 study)62

%HYPO=percent hypochromic red blood cells; AUC=area under the curve; CHr=content of hemoglobin in reticulocytes; IV=intravenous; NS=not significant; RetHe=reticulocyte hemoglobin equivalent; sTfR=soluble transferrin receptor; TSAT=transferrin saturation; ZPP= erythrocyte zinc protoporphyrin

a Response to IV iron treatment (the reference standard) was defined variably across studies (see also Table 2).

b The multivariate logistic regression analysis included HFE genotype, ferritin, TSAT, %Hypo, CHr, Hep-25 and Hep-20 in the same model.

Figure 4 Indirect comparisons of the overall test accuracy of newer with classical markers of iron status (at baseline) to predict response to IV iron among adult HD CKD patients—CHr, %HYPO, sTfR

%HYPO=percent hypochromic red blood cells; CHr=content of hemoglobin in reticulocytes; CRI=corrected reticulocyte index; EPO= erythropoietin stimulating agents; Hb=hemoglobin; HD=hemodialysis; IV=intravenous; sTfR= soluble transferrin receptor; TSAT=transferrin saturation; ZPP=erythrocyte zinc protoporphyrin

Note: Each symbol represents one reference standard, and sensitivity/specificity pairs from the same study (using different cutoffs) are connected with lines. Each study was labeled by its first author’s last name (next to the corresponding symbol). Studies that fall in the shaded area to the left of the near vertical line have a positive likelihood ratio ≥ 10, and studies that fall in the shaded area above the near horizontal line have a negative likelihood ratio ≤ 0.1. Studies that reported LR+ ≥10 and LR- ≤0.1 were deemed to have adequate predictive ability of the marker’s test result for the response to IV iron.

Figure 4 is a multi-panel graph, containing three panels of square plots. From left to right, the overall test performance or test accuracy of CHr, %HYPO, and sTfR were plotted in Panel A, B, and C of Figure 4, respectively. Each panel is a square plot that graphs a calculated value that is 100 percent minus the specificity of the study on the x-axis against the reported sensitivity on the y-axis. The positive and negative likelihood ratios of all included studies are calculated and plotted on the graph. Studies with a positive likelihood ratio of 10 or more, or a negative likelihood ratio of 0.1 or less, are considered as representing informative test results; the vertical and horizontal shaded areas on the plot represent areas of the graph where studies with these values would be located (respectively). We visual compared the locations of the ROC curves across panels to aid the indirect comparisons across studies. It appears that that curves for CHr (Panel A) and %HYPO (Panel B) are closer to the upper left hand corner (denoting perfect ability to predict response) than the curves for ferritin and TSAT (in Panels E and F of Figure 5, respectively), indicating better test performance. However, it appears that that there was no difference in the test performance between sTfR (Panel C) and ferritin or TSAT (Panels E and F of Figure 6, respectively).

Figure 5 Indirect comparisons of the overall test accuracy of newer versus classical markers of iron status (at baseline) to predict response to IV iron among adult HD CKD patients—ZPP, Ferritin, TSAT

%HYPO=percent hypochromic red blood cells; CHr=content of hemoglobin in reticulocytes; CRI=corrected reticulocyte index; EPO= erythropoietin stimulating agents; Hb=hemoglobin; HD=hemodialysis; IV=intravenous; sTfR= soluble transferrin receptor; TSAT=transferrin saturation; ZPP=erythrocyte zinc protoporphyrin

Note: Each symbol represents one reference standard, and sensitivity/specificity pairs from the same study (using different cutoffs) are connected with lines. Each study was labeled by its first author’s last name (next to the corresponding symbol). Studies that fall in the shaded area to the left of the near vertical line have a positive likelihood ratio ≥ 10, and studies that fall in the shaded area above the near horizontal line have a negative likelihood ratio ≤ 0.1. Studies that reported LR+ ≥10 and LR− ≤0.1 were deemed to have adequate predictive ability of the marker’s test result for the response to IV iron.

Figure 5 is a multi-panel graph, containing three panels of square plots. From left to right, the overall test performance or test accuracy of ZPP, Ferritin, and TSAT were plotted in Panel D, E, and F of Figure 5, respectively. Each panel is a square plot that graphs a calculated value that is 100 percent minus the specificity of the study on the x-axis against the reported sensitivity on the y-axis. The positive and negative likelihood ratios of all included studies are calculated and plotted on the graph. Studies with a positive likelihood ratio of 10 or more, or a negative likelihood ratio of 0.1 or less, are considered as representing informative test results; the vertical and horizontal shaded areas on the plot represent areas of the graph where studies with these values would be located (respectively). We visual compared the locations of the ROC curves across panels to aid the indirect comparisons across studies. it appears that that there was no difference in the test performance between sTfR (Panel D) and ferritin or TSAT (Panels E and F of Figure 5, respectively).

##### Summary of Key Points

(Tables 2 to 4; Figures 4 and 5)

- Among adult HD CKD patients, there is a low level of evidence that:
  ○ CHr has a similar or better overall test accuracy compared with classical markers (TSAT or ferritin) to predict a response to IV iron treatment. Data suggest that CHr (with cutoff values of <27 or <28 pg) has a better sensitivity and specificity to predict iron deficiency than classical markers (TSAT <20 or ferritin <100 ng/mL).
  ○ %HYPO has similar or better overall test accuracy compared with TSAT, and better overall test accuracy compared with ferritin, to predict a response to IV iron treatment. Data suggest that %HYPO (with cutoff values of >6% or >10%) has a better sensitivity and specificity to predict iron deficiency (as defined by a response to IV iron treatment) than classical markers (TSAT <20% or ferritin <100 ng/mL).
  ○ sTfR has a similar test performance compared with classical markers (TSAT or ferritin) to predict a response to IV iron treatment.
  ○ There exists a high degree of heterogeneity across studies in the background treatment and the definitions of the reference standard (a response to IV iron treatment), limiting our ability in evaluating the consistency of findings.
- There is insufficient evidence regarding:
  ○ Test performance of newer markers of iron status as an add-on to older markers.
  ○ Test performance comparing erythrocyte ZPP, RetHe, and hepcidin to predict a response to IV iron treatment in adult HD CKD patients.
  ○ Test performance comparing newer (CHr, %HYPO, RetHe, sTfR, ZPP, and hepcidin) with classical laboratory markers to predict a response to IV iron treatment in adult PD and ND CKD patients, and in pediatric CKD patients.

##### Content of Hemoglobin in Reticulocytes (CHr)/Reticulocyte Hemoglobin Equivalent (RetHe)

###### Key Points

(Table 5)

Table 5 Overall strength of evidence for the test performance of reticulocyte hemoglobin content (CHr) comparing with that of classical markers of iron status to predict a response to IV iron treatment

Number of Studies (Total N Analyzed) | Risk of Bias | Consistency | Directness | Precision | Overall Strength of Evidence
8 (533 HD CKD patient) | 1 low risk 4 medium risk 3 high risk | Consistent | Indirect | Imprecise | Low
1 (23 PD CKD patients) | 1 medium risk | NA (only one study) | Not applicable (no direct comparison) | Imprecise | Insufficient
1 (95 ND CKD patients) | 1 medium risk | NA (only one study) | Indirect | Imprecise | Insufficient

CKD=chronic kidney disease; HD=hemodialysis; NA=not applicable; ND=nondialysis; PD=peritoneal dialysis

Eight cohort studies enrolling 533 adult HD CKD CKD patients,44,46,47,52,58,59,61,62 one cohort study enrolling 23 PD CKD patients,50 and one cohort study enrolling 95 ND CKD patients64 evaluated the test accuracy of CHr to predict a response to IV iron treatment. Of the eight studies in HD CKD patients, six compared the test performance of CHr with that of classical markers of iron status (TSAT or ferritin, alone or in combination with each other), and two studies reported the test performance of CHr alone. There were four different test platforms used across studies, and considerable heterogeneity likely existing between testing platforms. Of these studies, one was rated as being at low risk of bias, four at a medium risk of bias, and three at a high risk of bias. Studies enrolled primarily older patients who received maintenance ESA treatment; however, maintenance ESA doses varied across studies. Baseline iron status (based on mean serum ferritin and TSTA concentrations) also varied across studies.

Overall, there is a low level of evidence that CHr has similar or better overall test accuracy compared with classical markers (TSAT or ferritin) to predict a response to IV iron treatment among HD CKD patients. Four different definitions of a response to IV iron treatment were used among these eight studies. Studies examined the sensitivities and specificities at different cutoff values of CHr, ranging from <26 to <32 pg, to predict iron deficiency, but data did not allow us to assess threshold effect, due to the heterogeneity in the definitions of reference standards. Other heterogeneity, such as the variable iron status of the study populations and background treatment across studies, further limited our ability in making comparisons across studies. Two studies also reported the sensitivities and specificities of classical markers (TSAT <20 or ferritin <100 ng/mL) to predict iron deficiency, and data suggest that CHr (with cutoff values of <27 or <28 pg) has a better sensitivity and specificity to predict iron deficiency than classical markers (TSAT <20 or ferritin <100 ng/mL).44,59 Only one study performed multivariate analyses to predict a response to IV iron treatment (defined as an increase in Hct of ≥3 percent and/or a ≥ 30 percent reduction in EPO dose), and reported that CHr (with cutoff of <28 pg) had a much higher diagnostic odds ratio than serum ferritin (with cutoff of <300 ng/mL).47

The strength of evidence is insufficient to draw conclusions regarding the test performance of CHr compared with that of classical markers of iron status among PD or ND CKD patients. We identified no study that evaluated the test performance of CHr to predict a response to IV iron treatment among pediatric CKD patients.

###### Detailed Synthesis

(Tables 3 and 6)

Table 6 Summary results of the ability of CHr to predict the response to IV iron treatment

Study, Year [UI] | Testing Platforms or Methods | N_analyzed_ (% Responders) | CHr Cut-off (pg) | Sens, % | Spec, % | AUC (CI) | Ferritin AUC (CI) | Comparison CHr vs. Ferritin P value | TSAT AUC (CI) | Comparison CHr vs. TSAT P value | Other Results
Adult HD CKD
Tessitore, 2010^62^ [20538788] | PBSCIIc mass spectrometer and copperloaded immobilized metal-affinity capture ProteinChip arrays (IMAC30-Cu2+) | 56 (38) | <32 | 57 | 75 | 0.697 (0.537,0.855) | 0.552 (0.391, 0.713) | NS | 0.593 (0.431, 0.754) | NS | CHr AUC not significantly different from AUC of hepcidin isoforms (P >0.12)
Bovy, 2007^44^ [17237481] | ADVIA 120 cell counter system, Bayer | 32 (38) | <29 | 25 | 100 | 0.752 (0.583, 0.921) | 0.834 (0.685, 0.983) | NS | 0.896 (0.778, 1.0) | NS | NR
Bovy, 2007^44^ [17237481] | ADVIA 120 cell counter system, Bayer | 32 (38) | <30 | 33 | 100 | 0.752 (0.583, 0.921) | 0.834 (0.685, 0.983) | NS | 0.896 (0.778, 1.0) | NS | NR
Buttarello, 2010^46^ [20472854] | ADVIA 120 hematology system, Bayer (CHr) | 59 (NR) | <31.2 | 47 | 83 | 0.74 (0.60, 0.89) | 0.53 (0.38, 0.69) | NR | 0.56 (0.40, 0.72) | NR | NR
Buttarello, 2010^46^ [20472854] | XE 5000 (RetHe) | 59 (NR) | <30.6 | 45 | 83 | 0.72(0.58,0.86) P<0.003 | 0.53 (0.38, 0.69) | NR | 0.56 (0.40, 0.72) | NR | NR
Mitsuiki, 2003^58^ [14586744] | ADVIA 120 hematology system, Bayer | 27 (63) | <32 | 100 | 90 | 0.95 (0.89,1.00) | 0.591 (0.415, 0.767) | NR | 0.676 (0.474, 0.878) | NR | NR
Mittman, 1997^59^ [9398141] | Technicon H3RTC Hematology Analyzer, Bayer Diagnostic | 79 (59) | <26 | 44 | 88 | NR | NA | NA | NA | NA | NR
Mittman, 1997^59^ [9398141] | Technicon H3RTC Hematology Analyzer, Bayer Diagnostic | | <27 | 67 | 82 | NR | NA | NA | NA | NA | NR
Mittman, 1997^59^ [9398141] | Technicon H3RTC Hematology Analyzer, Bayer Diagnostic | | <28 | 78 | 71 | NR | NA | NA | NA | NA | NR
Mittman, 1997^59^ [9398141] | Technicon H3RTC Hematology Analyzer, Bayer Diagnostic | | Change in CHr from baseline to 2 wks >2 pg | 100 | 31 | NR | NA | NA | NA | NA | NR
Mittman, 1997^59^ [9398141] | Technicon H3RTC Hematology Analyzer, Bayer Diagnostic | | Change in CHr from baseline to 2 wks >2.5 pg | 89 | 40 | NR | NA | NA | NA | NA | NR
Mittman, 1997^59^ [9398141] | Technicon H3RTC Hematology Analyzer, Bayer Diagnostic | | Change in CHr from baseline to 2 wks >3 pg | 56 | 59 | NR | NA | NA | NA | NA | NR
Chuang, 2003^47^ [12543894] | Technicon H*3 automated cell counter, Bayer Laboratory | 65 (65) | <28 | 78 | 87 | NR | NA | NA | NA | NA | OR=29.04 (5.36,157.33) with the best cutoff <28 pg
Chuang, 2003^47^ [12543894] | Technicon H*3 automated cell counter, Bayer Laboratory | | Change in CHr from baseline to 2 wks >1.2 pg | 80 | 83 | NR | NA | NA | NA | NA | OR=27.85 (5.37,144.3) with the best cutoff >1.2 pg
Chuang, 2003^47^ [12543894] | Technicon H*3 automated cell counter, Bayer Laboratory | | Change in CHr from baseline to 4 wks >1.2 | 87 | 83 | NR | NR | NR | NR | NR | OR=6.2 (1.94,19.8, P=0.002) with a cut off >1.2 pg
Fishbane, 1997^52^ [9211366] | Technicon H*3, Bayer Laboratory | 32 | <26 | 100 | 80 | NR | NR | NR | NR | NR | NR
Tessitore, 2001^61^ [11427634] | Advia 120 Hematology Analyser, Bayer Diagnostics | 125 (41) | ≤29 | 57 | 93 | 0.798 (0.714, 0.880) | 0.633 (0.514, 0.752) | P<0.05 | 0.753 (0.669, 0.837) | NS | NR
Adult PD CKD
Domrongkitchaiporn, 1999^50^ [10401012] | Technicon H*3, Bayer Laboratory | 21 (71) | <28 | 20 | 83 | NR | NR | NR | NR | NR | NR
Domrongkitchaiporn, 1999^50^ [10401012] | Technicon H*3, Bayer Laboratory | | <29 | 47 | 83 | NR | NR | NR | NR | NR | NR
Domrongkitchaiporn, 1999^50^ [10401012] | Technicon H*3, Bayer Laboratory | | <31 | 53 | 66 | NR | NR | NR | NR | NR | NR
Adult ND CKD
Van Wyck, 2005^64^ [16316362] U.S. | NR | 35 (44) | < 25 | 0 | 97 | NR | NR | NR | NR | NR | “Baseline TSAT, ferritin, and CHr are poor predictors of response to IV iron” as shown in the ROC curves
Van Wyck, 2005^64^ [16316362] U.S. | NR | | < 27 | 3 | 92 | NR | NR | NR | NR | NR | “Baseline TSAT, ferritin, and CHr are poor predictors of response to IV iron” as shown in the ROC curves
Van Wyck, 2005^64^ [16316362] U.S. | NR | | < 29 | 12 | 86 | NR | NR | NR | NR | NR | “Baseline TSAT, ferritin, and CHr are poor predictors of response to IV iron” as shown in the ROC curves
Van Wyck, 2005^64^ [16316362] U.S. | NR | | < 31 | 33 | 84 | NR | NR | NR | NR | NR | “Baseline TSAT, ferritin, and CHr are poor predictors of response to IV iron” as shown in the ROC curves
Van Wyck, 2005^64^ [16316362] U.S. | NR | | < 33 | 83 | 57 | NR | NR | NR | NR | NR | “Baseline TSAT, ferritin, and CHr are poor predictors of response to IV iron” as shown in the ROC curves
Van Wyck, 2005^64^ [16316362] U.S. | NR | | < 35 | 95 | 24 | NR | NR | NR | NR | NR | “Baseline TSAT, ferritin, and CHr are poor predictors of response to IV iron” as shown in the ROC curves

AUC=area under the curve; CHr=content of hemoglobin in reticulocytes; CI=95% confidence interval; CRI=corrected reticulocyte index; IV=intravenous; NR=not reported; NS=not significant; OR=odds ratio; rHuEpo=recombinant human erythropoietin; SE=standard error; Sens=sensitivity; Spec=specificity; TSAT=transferrin saturation, UI=universal identifier/Pubmed ID

###### HD CKD Patients

Eight studies evaluated the test performance of CHr to predict a IV response in 533 adult CKD patients.44,46,47,52,58,59,61,62 Of these, one (with a total of 69 adult HD CKD patients) also evaluated the ability of RetHe to predict the response to IV iron treatment, and showed that CHr and RetHe are similar in terms of test performance.46 Study sample sizes ranged from 27 to 125 patients. The mean age of patients, reported in five studies, ranged from 59 to 67 years old; one additional study reported subjects’ ages (31 to 84 years), while the remaining two did not report subjects’ age. The baseline mean Hb concentrations (reported in 5 studies) ranged from 9.9 to 12.3 g/dL, mean ferritin concentrations from 84 to 347 ng/mL (reported in 8 studies), and mean TSAT from 18 to 39 percent (reported in 7 studies). Most studies reported that patients were on maintenance ESA treatment during the trial of iron treatment; however, maintenance ESA doses varied across studies. The indices monitored for assessing a response were Hb, hematocrit, and the corrected reticulocyte index (which is calculated by multiplying the reticulocyte count by the hematocrit and dividing the result by 40). The iron formulations used were ferric gluconate, iron sucrose, chondroitin-sulfate iron colloid, iron dextran, and iron saccharate. The duration of iron treatment also varied across studies, ranging from 2 weeks to 6 months. Of the eight total studies, two evaluated the ability of change in CHr values from baseline to 2 or 4 weeks to predict response to IV iron treatment.47,59

Studies examined the sensitivities and specificities at different cutoff values of CHr, ranging from <26 to <32 pg, to predict iron deficiency; however, the data did not allow us to assess threshold effect, due to the heterogeneity in the definitions of reference standards. Four different definitions of reference standards (a response to IV iron treatment) were used : 1) an increase in Hb of ≥1 g/dL;44,46,58,62, 2) a ≥ 15 percent increase in Hb;61 3) an increase in Hct of ≥3 percent and/or a ≥ 30 percent reduction in EPO dose;47 and 4) >1 point increase in corrected reticulocyte index.52,59 There was no uniform regimen of intravenous iron treatment in terms of dosage and iron formulation. There was also a wide range of durations of intravenous iron treatment (2 weeks to 5 months) across studies. One study was rated as being at a low risk of bias,62 six at a medium risk of bias,44,46,58,59 and three at a high risk of bias.47,52,61 The common limitations among the studies rated as being at medium or high risk of bias included potential selection bias (due to inclusion of nonconsecutive patients), inadequate description of recruitment and the study population, and inadequate information on the blinding between the test readers of the index and reference tests.

Studies reported either a similar (not statistically different) or better overall test accuracy for CHr as compared with TSAT and ferritin based on the AUC values (Table 3). Only one out of the eight studies performed multivariate analyses to predict a response to IV iron treatment (defined as an increase in Hct of ≥3 percent and/or a ≥ 30 percent reduction in EPO dose).47 The logistic regression model included both newer and classical markers as independent variables, with the marker cutoffs being derived from ROC curves. The study reported that CHr <28 pg was associated with a 29-fold increased in the odds of a response (odds ratio=29; 95 percent CI 5 to 157), which was much higher than the odds ratio for serum ferritin (OR=8.71; 95 percent CI: 1.55, 48.96, with cutoff of <300 ng/mL). This study also reported the odds ratios for predicting a response based on a >1.2 pg change in CHr from baseline to 2 weeks (OR=29.04 [5.36,157.33]) and a >1.2 pg change in CHr from baseline to 4 weeks (OR=6.2 [1.94,19.8]).47 In the lone study where CHr was used in combination with a newer marker (%HYPO with a cutoff < 6 percent), the combination showed a higher sensitivity with no change in specificity.61

Only two studies reported the sensitivities and specificities of CHr (at different cutoff values) in comparison with classical markers (TSAT <20 or ferritin <100 ng/mL) to predict iron deficiency (as defined by a response to IV iron treatment).44,59 Data from these two studies showed that CHr cutoff values of <27 or <28 pg had a better sensitivity and specificity to predict iron deficiency than classical markers (TSAT <20 or ferritin <100 ng/mL). However, the two studies used different definitions for a response to IV iron treatment, which limited the interpretation of findings across studies.

To aid the indirect comparisons across studies, the ability of CHr, ferritin, and TSAT to predict a response to IV iron treatment was plotted in ROC space (Panel A of Figure 4, and Panels E and F of Figure 5, respectively). Through visual inspection of the ROC curves for the three markers, it appears that that curves for CHr are closer to the upper left hand corner (denoting perfect ability to predict response) than the curves for ferritin and TSAT, indicating better overall test accuracy.

###### PD CKD Patients

In PD CKD patients with anemia, one cohort study with 23 patients evaluated the ability of CHr to predict a response to IV iron treatment, defined as an increase ≥ 1.0 g/dL of Hb within three months of starting treatment.50 The study was rated as being at a medium risk of bias due to potential selection bias.

This study assessed multiple cutoffs, ranging from 28 to 31 pg of CHr to predict a response. The reported ranges of sensitivity and specificity were 20 to 53 percent and 83 to 67 percent, respectively, from lowest to highest CHr cutoffs. The study also assessed multiple cutoffs for serum ferritin (<100 to < 800 ng/mL) and TSAT (<20 to < 50 percent) to predict a response. Ferritin <100 ng/mL had sensitivity and specificity of 13 and 100 percent, respectively. Similarly, TSAT <20% had sensitivity and specificity of 20 and 100 percent, respectively. The authors reported that none of the sensitivity specificity pairs for various cutoffs for CHr, ferritin and TSAT provided reliable estimates to predict response to iron. This conclusion is consistent with our interpretations based on the calculated Likelihood Ratios falling below our prespecified limits (LR+ ≥10 and LR− ≤0.1) suggesting that none of these tests have adequate predictive ability for diagnosing iron deficiency in PD CKD patients.

###### ND CKD Patients

One cohort study, enrolling 95 ND CKD patients, evaluated the test accuracy of CHr to predict response to iron treatment, defined as a Hb increase ≥ 1.0 g/dL.64 This cohort study (at a medium risk of bias) analyzed data from the IV iron arm of an RCT comparing the efficacy of IV iron sucrose with oral ferrous sulfate over a period of 8 weeks.

The study publication reported ROC curves for CHr, ferritin, and TSAT with different cutoffs indicated in the text; however, the locations of the cutoffs were not indicated on the curve. Hence, the ROC curves were digitized to obtain sensitivity/specificity pairs. It was assumed that the cutoffs were presented in ascending order of sensitivity. The CHr cutoffs used to define response to IV iron ranged from <25 to <35 pg. The ranges of sensitivity and specificity to determine response to IV iron were 0 to 95 percent and 97 to 24 percent, respectively, from lowest to highest CHr cutoffs.

The study also assessed multiple cutoffs for ferritin (<50 to < 300 ng/mL), TSAT (<5 to < 25 percent), and the combination of ferritin and TSAT to predict a response. The authors reported that CHr, ferritin and TSAT had “poor clinical utility” at each cutoff value examined. Through visual inspection of the ROC curves for the all markers, it appears that CHr covered larger AUC than ferritin and TSAT, indicating better overall test accuracy. However, none of these markers were close to the upper left hand corner (denoting perfect ability to predict response).

##### Percent Hypochromic Red Blood Cells

###### Key Points

(Table 7)

Table 7 Overall strength of evidence for the test performance of Percent Hypochromic Red Blood Cells (%HYPO) comparing with that of classical markers of iron status to predict a response to IV iron treatment

Number of Studies (Total N Analyzed) | Risk of Bias | Consistency | Directness | Precision | Overall Strength of Evidence
6 (356 CKD patients on HD) | 1 low risk 2 medium risk 3 high risk studies | Consistent | indirect | Imprecise | Low

CKD=chronic kidney disease; HD=hemodialysis

Six cohort studies, enrolling a total of 365 adult HD CKD patients, evaluated the test performance of %HYPO to predict a response to IV iron treatment.44,46,52,61,62,67 There were two different test platforms used across studies. One study was rated as being at a low risk of bias, two at a medium risk, and three at a high risk of bias. Studies enrolled primarily older patients who received maintenance ESA treatment; however, maintenance ESA doses varied across studies. Baseline iron status (based on mean serum ferritin and TSTA concentrations) also varied across studies.

Overall, there is a low level of evidence that %HYPO has similar or better overall test accuracy compared with classical markers (TSAT or ferritin) to predict a response to IV iron treatment among HD CKD patients. Three different definitions of a response to IV iron treatment were used among these six studies. Studies examined the sensitivities and specificities of %HYPO, with a cutoff value of either >6% or >10%, to predict iron deficiency. Data suggest that %HYPO (with cutoff values of >6% or >10%) has a better sensitivity and specificity to predict iron deficiency than classical markers (TSAT <20 or ferritin <100 ng/mL). Furthermore, two studies (from the same group of investigators) performed a multivariate regression analysis, and it showed that %HYPO was the only significant predictor of a response to IV iron treatment among all other markers included in the model.61,62

We did not identify any study evaluated the test performance of %HYPO to predict a response to IV iron treatment among adult PD or ND CKD patients, or among pediatric CKD patients.

###### Detailed Synthesis

(Tables 3 and 8)

Table 8 Summary results of the ability of %HYPO to predict the response to IV iron treatment in HD CKD patients

Study, Year [UI] | Population | Testing Platforms or Methods | %HYPO Cutoff (%) | N_analyzed_ (% responders) | Sens, % | Spec, % | AUC (CI) | Ferritin AUC (CI) | Comparison %HYPO vs. Ferritin P value | TSAT AUC (CI) | Comparison %HYPO vs. TSAT P value | Other Results
Tessitore, 2010^62^ [20538788] | HD CKD | Advia 120 Hematology Analyser | >6 | 56 (38) | 76 | 89 | 0.844 (0.737, 0.950) | 0.552 (0.391, 0.713) | NS | 0.593 (0.431, 0.754) | NS | OR = 1.60 [95% CI=1.08,2.39], P=0.02).
Bovy, 2007^44^ [17237481] | HD CKD | Advia 120 cell counter | > 10 | 32 (38) | 67 | 95 | 0.937 (0.837, 1.00) | 0.834 (0.685, 0.983) | NS | 0.896 (0.778, 1.014) | NS | NR
Buttarello, 2010^46^ [20472854] | HD CKD | Advia 120 | ≥ 5.8 | 59 (NR) | 45 | 87 | 0.72 (0.58, 0.86) | 0.53 (0.38, 0.69) | NR | 0.56 (0.40, 0.72) | NR | NR
Fishbane, 1997^52^ [9211366] | HD CKD | Technicon H*3 hematology analyzer | > 10 | 32 (22) | 43 | 80 | NR | NR | NR | NR | NR | NR
Silva, 1998^67^ [9794562] | HD CKD | Technicon Mod. H2 System | > 10 | 33 (88) | 10 | 100 | NR | NR | NR | NR | NR | NR
Tessitore, 2001^61^ [11427634] | HD CKD | Advia 120 Hematology Analyser | > 6 | 125 (41) | 82 | 95 | 0.93 (0.884, 0.976) | 0.633 (0.514, 0.752) | P<0.001 | 0.753 (0.669, 0.837) | P<0.05 | NR

Δ = Change in blood levels; AUC=area under the curve; CI=95% confidence interval; CKD=chronic kidney disease; CRI=corrected reticulocyte index; Hb=hemoglobin; HD=hemodialysis; IV=intravenous; NR=not reported; NS=not significant; Sens=sensitivity; Spec=specificity; UI=universal identifier/pubmed ID

Six cohort studies, enrolling a total of 356 HD CKD patients, evaluated the ability of %HYPO to predict a response to IV iron treatment.44,46,52,61,62,67 All studies also compared the predictive ability of %HYPO with that of classical laboratory markers (TSAT or ferritin). One study recruited anemia HD CKD patients,46 and two studies excluded patients with high normal serum ferritin values.52,67 Most studies reported that patients were on maintenance ESA treatment during the IV iron treatment; however maintenance ESA doses varied across studies. The mean age of patients ranged from 57 to 80 years old (reported in four studies). Baseline mean Hb concentrations ranged from 9.9 to 12.3 g/dL (reported in five studies), mean ferritin concentrations ranged from 137 to 347 ng/mL (reported in six studies), and mean TSAT ranged from 18 to 27 percent (reported in five studies). Four studies defined a response to IV iron treatment as an increase in Hb concentration ≥1 g/dL after treatment,44,46,62,67 one study defined response as ≥15 percent increase in Hb at any two consecutive measurements, 61 and one study defined response as >1 point increase in corrected reticulocyte index within 2 weeks.52 There was no uniform regimen of intravenous iron treatment in terms of dosage and iron formulation. There was also a wide range of durations of intravenous iron treatment (2 weeks to 6 months) across studies. One study was rated as being at a low risk of bias,62 two at a medium risk,44,46 and three at a high risk of bias.52,61,67 The studies rated as being at a medium or high risk of had issues related to potential selection bias and inadequate descriptions of the study population, patient recruitment, and tests.

Three of the four studies showed that %HYPO reported a significantly better overall test accuracy as compared with TSAT and ferritin, based on the AUC values.46,61,62 These studies defined a response to IV iron treatment as either an increase in Hb concentration ≥1 g/dL after treatment,44,46,62 or ≥15 percent increase in Hb at any two consecutive measurements.61 Two studies also reported the sensitivities and specificities of classical markers (TSAT <20 or ferritin <100 ng/mL) to predict iron deficiency, and data suggest that %HYPO (with cutoff values of >6% or >10%) has a better sensitivity and specificity to predict iron deficiency than classical markers (TSAT <20 or ferritin <100 ng/mL).44,62 Furthermore, two studies performed a multivariate regression analysis, which showed that %HYPO was the only significant predictor of a response to IV iron treatment among all other markers (HFE genotype, ferritin, TSAT, %Hypo, CHr, Hep-25 and Hep-20 in the same model).61,62 Combination of markers were assessed in two studies.44,61 In one study, when %HYPO was combined with newer or classical markers, the sensitivity of the test combination was higher than %HYPO alone but the reported specificity was lesser than that of %HYPO alone.61 In the other study, the combination of %HYPO and classical markers resulted in lower sensitivity and high specificity.44

To aid the indirect comparisons across studies, the abilities of %HYPO, ferritin, and TSAT to predict a response to IV iron treatment were plotted in ROC space (Panel B of Figure 4, and Panels E and F of Figure 5, respectively). Through visually inspection of the ROC curves for the three markers, it appears that that there is a better test performance for %HYPO as compared with TSAT and ferritin, with the ROC curves for %HYPO being closer to the upper left hand corner (denoting perfect ability to predict the response) than the ROC curves for ferritin and TSAT. This is also supported by the higher AUC values reported for %HYPO as compared with ferritin and TSAT in all studies.

##### Soluble Transferrin Receptor

###### Key Points

(Table 9)

Table 9 Overall strength of evidence for the test performance of Soluble Transferrin Receptor (sTfR) comparing with that of classical markers of iron status to predict a response to IV iron treatment

Number of Studies (Total N Analyzed) | Risk of Bias | Consistency | Directness | Precision | Overall Strength of Evidence
2 (157 HD CKD patients) | 1 medium risk 1 high risk | Consistent | Indirect | Imprecise | Low

CKD=chronic kidney disease; HD=hemodialysis

Two cohort studies, enrolling a total of 157 adult HD CKD patients, evaluated the test performance of sTfR to predict a response to IV iron treatment.44,61 Both studies also compared the test performance of sTfR with that of classical laboratory markers (TSAT or ferritin). One study was rated as being at a high risk of bias,61 and one at a medium risk of bias.44 The response to IV iron treatment was defined differently in the two studies, either as an increase in Hb concentration ≥1g/dL after intravenous iron treatment,44 or as an increase in Hb >15 percent from baseline.61

Overall, there is a low level of evidence that sTfR has similar overall test accuracy compared with classical markers (TSAT or ferritin) to predict a response to IV iron treatment (although defined differently between the two studies) among HD CKD patients. We did not identify any study evaluated the test performance of sTfR to predict a response to IV iron treatment among adult PD or ND CKD patients, or among pediatric CKD patients.

###### Detailed Synthesis

(Tables 3 and Table 10)

Table 10 Summary results of the ability of sTfR to predict the response to IV iron treatment in HD CKD patients

Study, Year [UI] | Testing Platforms or Methods | sTfR Cut-off (pg) | N_analyzed_ (% Responders) | Sens, % | Spec, % | AUC (CI) | Ferritin AUC (CI) | Comparison sTfR vs. Ferritin P value | TSAT AUC (CI) | Comparison sTfR vs. TSAT P value | Other Results
Bovy, 2007^44^ [17237481] Belgium | Enzyme-linked immunosorbent assays (QuantikineTM IVDTM, R&D Systems, Minneapolis, MN, USA | >6.6 (Best cutoff) | 32 (NR) | NR | NR | 0.989 (0.922, 1.0) | 0.834 (0.685, 0.983) | NS | 0.896 (0.778, 1.014) | NS | NR
Tessitore, 2001^61^ [11427634] | Commercially available automated particle-enhanced immunephelometric (PETIA) assay (Dade Behring, Marburg, Germany), using highly purified sTfR isolated from human serum as a calibrator | >1.5 | 125 (41) | 81 | 71 | 0.7834 (0.668,0.899) | 0.633 (0.514, 0.752) | NS | 0.753 (0.669, 0.837) | NS | NR
Tessitore, 2001^61^ [11427634] | Commercially available automated particle-enhanced immunephelometric (PETIA) assay (Dade Behring, Marburg, Germany), using highly purified sTfR isolated from human serum as a calibrator | sTfR >1.5 or TSAT <19 | | 91 | 66 | NR | NR | NR | NR | NR | NR

AUC=area under the curve; CI=95% confidence interval; CKD=chronic kidney disease; IV=intravenous; NR=not reported; NS=not significant; Sens=sensitivity; Spec=specificity; sTfR=soluble transferrin receptor; TSAT=transferrin saturation; UI=universal identifier/pubmed ID

Two cohort studies, enrolling a total of 157 adult HD CKD patients (32 and 125 patients), evaluated the ability of sTfR to predict the response to IV iron treatment.44,61 Both studies also compared the test performance of sTfR with that of classical laboratory markers (TSAT or ferritin). Baseline mean Hb concentrations were 12.3 and 9.9 g/dL, mean ferritin concentrations were 347 and 201 ng/mL, and mean TSAT was 21 and 22 percent, respectively.44,61 One study was rated as being at a high risk of bias,61 and one at a medium risk of bias,44 due to potential selection bias, inadequate reporting of eligibility criteria, or inadequate descriptions of the study populations. The response to IV iron treatment were defined differently in the two studies, either as an increase in Hb concentration ≥1g/dL after intravenous iron treatment,44 or as an increase in Hb >15 percent from baseline.61 This limited our confidence in evaluating the consistency of findings across studies.

Both studies did not show significant differences in the overall test accuracy between sTfR and TSAT or ferritin, based on the AUC values. When sTfR (with a cutoff >1.5 pg ) was combined with another newer marker (%HYPO with a cutoff >6 percent), the sensitivity of the test combination was higher than either test alone, but the reported specificity was lesser than that of %HYPO alone and higher than that of sTfR alone.61

To aid the indirect comparisons across studies, the ability of sTfR, ferritin, and TSAT to predict a response to IV iron treatment was plotted in ROC space (Panel C of Figure 4, and Panels E and F of Figure 5, respectively). Through visual inspection of the ROC curves for the three markers, it appears that that there was no difference in the test performance between these three markers of iron status in predicting a response to IV iron treatment.

##### Erythrocyte Zinc Protoporphyrin

###### Key Points

(Table 11)

Table 11 Overall strength of evidence for the test performance of ZPP comparing with that of classical markers of iron status to predict a response to IV iron treatment

Number of Studies (Total N Analyzed) | Risk of Bias | Consistency | Directness | Precision | Overall Strength of Evidence
2 (187 HD CKD patients) | 2 high risk | Not applicable (different reference standards) | Indirect | Imprecise | Insufficient

CKD=chronic kidney disease; HD=hemodialysis

Two cohort studies, enrolling a total of 187 adult HD CKD patients, evaluated the test performance of ZPP in predicting a response to IV iron treatment.61,65 Both studies also compared the test performance of ZPP with that of classical laboratory markers (TSAT or ferritin). However, because the reference standards (Hb versus Hct/decrease in EPO dose) were not comparable, the two studies should be evaluated separately. Therefore, the strength of evidence is insufficient to draw conclusions regarding the test performance of ZPP compared with that of classical laboratory markers (TSAT or ferritin). When the three markers were assessed in a multivariate regression analysis in one study, the test performance of ZPP was comparable with TSAT and ferritin, and none of the three markers was a significant predictor of response to IV iron treatment.61

We did not identify any study evaluated the test performance of ZPP to predict a response to IV iron treatment among adult PD or ND CKD patients, or among pediatric CKD patients.

###### Detailed Synthesis

(Tables 3 and 12)

Table 12 Summary results of the test performance of ZPP in predicting a response to IV iron treatment in adult HD CKD patients

Study, Year [UI] | Testing platforms or methods | N_analyzed_ (% Responders) | ZPP Cut-off (pg) | Sens, % | Spec, % | AUC (CI) | Ferritin AUC (CI) | ZPP vs. Ferritin P value | TSAT AUC (CI) | ZPP vs. TSAT P value | Other Results
Fishbane, 1995^65^ [7872320] | Hematofluorometer, AVIV Biomedicals | 62 (62) | >52 | 100 | 17 | 0.853 (0.760, 0.946)^a^ | 0.785 (0.672, 0.897)^a^ | NR | 0.665 (0.53, 0.80) a | NR | NR
Fishbane, 1995^65^ [7872320] | Hematofluorometer, AVIV Biomedicals | | >66 | 90 | 35 | 0.853 (0.760, 0.946)^a^ | 0.785 (0.672, 0.897)^a^ | NR | 0.665 (0.53, 0.80) a | NR | NR
Fishbane, 1995^65^ [7872320] | Hematofluorometer, AVIV Biomedicals | | >90 | 87 | 83 | 0.853 (0.760, 0.946)^a^ | 0.785 (0.672, 0.897)^a^ | NR | 0.665 (0.53, 0.80) a | NR | NR
Fishbane, 1995^65^ [7872320] | Hematofluorometer, AVIV Biomedicals | | >103 | 80 | 91 | 0.853 (0.760, 0.946)^a^ | 0.785 (0.672, 0.897)^a^ | NR | 0.665 (0.53, 0.80) a | NR | NR
Fishbane, 1995^65^ [7872320] | Hematofluorometer, AVIV Biomedicals | | >107 | 70 | 91 | 0.853 (0.760, 0.946)^a^ | 0.785 (0.672, 0.897)^a^ | NR | 0.665 (0.53, 0.80) a | NR | NR
Fishbane, 1995^65^ [7872320] | Hematofluorometer, AVIV Biomedicals | | >109 | 60 | 91 | 0.853 (0.760, 0.946)^a^ | 0.785 (0.672, 0.897)^a^ | NR | 0.665 (0.53, 0.80) a | NR | NR
Fishbane, 1995^65^ [7872320] | Hematofluorometer, AVIV Biomedicals | | >112 | 50 | 96 | 0.853 (0.760, 0.946)^a^ | 0.785 (0.672, 0.897)^a^ | NR | 0.665 (0.53, 0.80) a | NR | NR
Fishbane, 1995^65^ [7872320] | Hematofluorometer, AVIV Biomedicals | | >122 | 40 | 96 | 0.853 (0.760, 0.946)^a^ | 0.785 (0.672, 0.897)^a^ | NR | 0.665 (0.53, 0.80) a | NR | NR
Fishbane, 1995^65^ [7872320] | Hematofluorometer, AVIV Biomedicals | | >138 | 30 | 100 | 0.853 (0.760, 0.946)^a^ | 0.785 (0.672, 0.897)^a^ | NR | 0.665 (0.53, 0.80) a | NR | NR
Fishbane, 1995^65^ [7872320] | Hematofluorometer, AVIV Biomedicals | | >140 | 20 | 100 | 0.853 (0.760, 0.946)^a^ | 0.785 (0.672, 0.897)^a^ | NR | 0.665 (0.53, 0.80) a | NR | NR
Fishbane, 1995^65^ [7872320] | Hematofluorometer, AVIV Biomedicals | | >177 | 10 | 100 | 0.853 (0.760, 0.946)^a^ | 0.785 (0.672, 0.897)^a^ | NR | 0.665 (0.53, 0.80) a | NR | NR
Fishbane, 1995^65^ [7872320] | Hematofluorometer, AVIV Biomedicals | | >190 | 0 | 100 | 0.853 (0.760, 0.946)^a^ | 0.785 (0.672, 0.897)^a^ | NR | 0.665 (0.53, 0.80) a | NR | NR
Tessitore, 2001^61^ [11427634] | Fluorometer, Shimadzu, Rf-551 | 125 (41) | >52 | 81 | 69 | 0.77 (0.63, 0.91) | 0.633 (0.51, 0.75) | NS | 0.753 (0.67, 0.84) | NS | Not a significant predictor in the multivariate regression analysis
Tessitore, 2001^61^ [11427634] | Fluorometer, Shimadzu, Rf-551 | | >90 | 14 | 97 | 0.77 (0.63, 0.91) | 0.633 (0.51, 0.75) | NS | 0.753 (0.67, 0.84) | NS | Not a significant predictor in the multivariate regression analysis
Tessitore, 2001^61^ [11427634] | Fluorometer, Shimadzu, Rf-551 | | ZPP >52 or %HYPO >6% | 94 | 72 | 0.77 (0.63, 0.91) | 0.633 (0.51, 0.75) | NS | 0.753 (0.67, 0.84) | NS | Not a significant predictor in the multivariate regression analysis

AUC=area under the curve; CKD=chronic kidney disease; CI=confidence interval; EPO=erythropoietin; Hb=hemoglobin; HD=hemodialysis; Hct=hematocrit; IV=intravenous; NR=not reported; NS=not significant; Sens=sensitivity; Spec=specificity; TSAT=transferrin saturation; UI=universal identifier/pubmed ID; ZPP= erythrocyte zinc protoporphyrin

a CI estimated from reported sensitivity and specificity pairs at different cutoffs using Watkins, M. W. (2000). An EXCEL program for calculating and graphing the Receiver Operating Characteristic (ROC) [Computer software]. State College, PA: Ed & Psych Associates.

Two cohort studies, enrolling a total of 187 adult HD CKD patients (62 and 125 patients), evaluated the test performance of ZPP in predicting a response to IV iron treatment.61,65 Both studies also compared the predictive ability of ZPP with that of classical laboratory markers (TSAT or ferritin). One study did not report any information on the anemia or iron status of the study population at baseline.65 The other study reported a mean Hb concentration of 9.9 g/dL, mean ferritin concentration of 201 ng/mL, and mean TSAT of 22 percent at baseline.61 Both studies were rated as being at a high risk of bias, due to a potential for selection bias or an inadequate description of the study population. The two studies used very deferent definitions to define a response to IV iron therapy: a 15 percent or more increase in Hb,61 or a 5 percent increase in Hct or a decrease in erythropoietin dose of more than 2000 units.65 Because the reference standards (Hb versus Hct/decrease in EPO dose) were not comparable, the two studies should be evaluated separately.

Both studies showed that ZPP and ferritin had a similar overall test accuracy, based on the AUC values. However, the studies also showed different findings comparing the test accuracy of ZPP with that of TSAT. Specifically, in predicting a response to IV iron treatment, one study reported a higher sensitivity and specificity for ZPP as compared with TSAT,65 and the other study reported a higher sensitivity and lower specificity for ZPP as compared with TSAT.61 When the three markers were assessed in a multivariate regression analysis in the latter study, the test accuracy of ZPP was comparable with TSAT and ferritin, and none of the three markers was a significant predictor of response to IV iron treatment.61 This same study also assessed the test accuracy of ZPP combined with another newer marker (%HYPO) to predict a response to IV iron treatment, as compared with classical markers (TSAT or ferritin), and found that the test accuracy of the combination of newer markers (ZPP>52 pg or %Hypo >6 percent) was better than TSAT<20% or ferritin <100 ng/mL (either alone or in combination). The other study reported that utility of ZPP in predicting the need for IV iron is better than that of TSAT and ferritin.65

To aid the indirect comparisons across studies, the ability of ZPP, ferritin, and TSAT to predict a response to IV iron treatment was plotted in ROC space (Panels D, E, and F of Figure 5, respectively). Through visual inspection of the ROC curves for the three markers, it appears that that there was no difference in the overall test accuracy between these three markers of iron status in predicting a response to IV iron treatment.

##### Hepcidin

###### Key Points

One prospective cohort study evaluated the test performance of both isoforms of hepcidin (hepcidin-20 and hepcidin-25) to predict iron deficiency among 56 older adult HD CKD patients who were on maintenance ESA treatment. The study was rated as being at a low risk of bias. The strength of evidence is insufficient to draw conclusions regarding the overall test accuracy or test accuracy of hepcidin-20 or hepcidin-25 comparing with that of classical markers of iron status among adult HD CKD patients.

We identified no study evaluating the test performance of hepcidin to predict a response to IV iron treatment among adult PD or ND CKD patients, or among pediatric CKD patients.

###### Detailed Synthesis

(Tables 3 and 13)

Table 13 Summary results of the ability of serum hepcidin to predict the response to IV iron treatment in HD CKD patients

Study, Year [UI] | Testing Platforms or Methods | N_analyzed_ (% Responders) | Index Test | Sens, % | Spec, % | AUC (CI) | Ferritin AUC (CI) | Comparison Hepcidin vs. Ferritin P value | TSAT AUC (CI) | Comparison Hepcidin vs. TSAT P value | Other Results
Tessitore, 2010^62^ [20538788] | PBSCIIc mass spectrometer and copperloaded immobilized metal-affinity capture ProteinChip arrays (IMAC30-Cu2+) | 56 (NR) | Hepcidin-20 | NR | NR | 0.541 (0.373, 0.710) | 0.552 (0.391, 0.713) | NS | 0.593 (0.431, 0.754) | NS | NR
Tessitore, 2010^62^ [20538788] | PBSCIIc mass spectrometer and copperloaded immobilized metal-affinity capture ProteinChip arrays (IMAC30-Cu2+) | 56 (NR) | Hepcidin-25 | NR | NR | 0.517 (0.330, 0.672) | 0.552 (0.391, 0.713) | NS | 0.593 (0.431, 0.754) | NS | NR

AUC=area under the curve; CI=95% confidence interval; CKD=chronic kidney disease; HD=hemodialysis; IV=intravenous; NR=not reported; NS=not significant; Sens=sensitivity; Spec=specificity; TSAT=transferrin saturation; UI=universal identifier/pubmed ID

One prospective cohort study evaluated the test performance of hepcidin-20 and hepcidin-25 to predict iron deficiency, defined by a reponse to IV iron treatment among 56 older adult HD CKD patients (mean age of 67 years).62 All enrolled patients were on maintenance ESA treatment, aiming at target Hb within the range of 10.5 to 12.5 g/dL. Baseline mean Hb concentration was 11.6 g/dL, mean ferritin concentration was 146 ng/mL, and mean TSAT was 20 percent. The study was rated as being at a low risk of bias. A response to IV iron treatment was defined as an increase in Hb concentration ≥1 g/dL after treatment with 62.5 mg ferric gluconate over 16 consecutive dialysis sessions.

The overall test accuracy to predict a response to IV iron treatment for hepcidin-20 or hepcidin-25 was no better than chance (AUC= 0.54 and 0.52, respectively), and was not significantly different from that of TSAT or ferritin.

### 2b Adverse Effects or Harms Associated With Testing

Only seven of the 27 identified studies reported information on harms.47,50,59,64–67 Specifically, three studies reported no adverse events associated with iron therapy during the study periods. A total of five deaths were reported across two studies. Studies did not attribute these deaths to either testing or treatment. However, iron testing itself is unlikely to cause deaths, and most of the reported harms were attributed to iron therapy (if reported). Additional details regarding these adverse events are provided in Table 14.

Table 14 Adverse effects or harms reported in the 27 studies included in Key Question 2

Author, Year [PMID] | Adverse Effects or Harms Reported
Chuang, 2003^47^ [12543894] | No adverse reactions were found to be associated with iron therapy.
Domrongkitchaiporn, 1999^50^ [10401012] | No adverse reaction developed during or immediately after intravenous iron infusion.
Fishbane, 1995^65^ [7872320] | Development of bleeding episodes: 5/62 (8%); significant intercurrent illnesses: 5/62 (8%); death: 2/62 (3%).
Kaneko, 2003^66^ [12631092]^a^ | Three patients died during this study. 2 patients in the CHr group died; 1 during week 4 (bacterial pneumonia) and one during week 16 (sudden death by unknown cause) of the trial period. 1 patient in the TSAT group died in week 7 because of a liver tumor that was not discovered at patient enrollment and randomization. 1 patient in the TSAT group was prematurely discontinued from the study because of massive bleeding due to a femoral bone fracture and need for blood transfusion. No differences in hospitalizations or infection rate were observed. 1 patient in the CHr group and 1 patient in the TSAT group were hospitalized for infection of renal cysts and internal shunt obstruction, respectively.
Mittman, 1997^59^ [9398141] | No adverse reactions were found to be associated with iron treatment.
Silva, 1998^67^ [9794562] | Four of 33 patients (12%)—Metallic taste, when iron administration was too fast; No anaphylactoid reactions; No skin rashes; No intestinal or respiratory allergy; No infectious complications when on IV iron; No hepatic or pancreatic dysfunction related to iron Tx.
Van Wyck, 2005^64^ [16316362] | No serious adverse effects (hypersensitivity reaction, hospitalization or deaths) were reported associated with iron treatment. Gastrointestinal disturbances, constipation, nausea, vomiting and dyspepsia associated with oral iron therapy. Gastrointestinal disturbances, constipation, nausea/vomiting, dyspepsia, transient taste disturbance (dysgeusia), headache, myalgia and hypotension associated with IV iron treatment.

CHr=content of hemoglobin in reticulocytes; IV=intravenous; TSAT=transferrin saturation; Tx=treatment

a This study was also included in Key Question 3, and thus the same data on harms are also reported there.

## Key Question 3 Intermediate Outcomes Comparing Iron Management Guided by Newer Laboratory Markers With Those of Iron Management Guided by Older Laboratory Markers

### Key Points

(Table 15)

Table 15 Overall strength of evidence for intermediate outcomes comparing iron management guided by newer laboratory markers with those of iron management guided by older laboratory markers

Number of Studies (Total N Analyzed) | Risk of Bias | Consistency | Directness | Precision | Overall Strength of Evidence
2 RCTs (354 adult CKD HD patients) | 2 medium risk | Inconsistent (dose of epoetin treatment) Consistent (dose of iron treatment—post hoc intermediate outcome) | Indirect | Imprecise | Low

CKD=chronic kidney disease; HD=hemodialysis; RCT=randomized controlled trial

Two short-term RCTs (4 and 6 months), enrolling a total of 354 adult CKD patients (mean age of 60 years old) undergoing hemodialysis, compared the intermediate outcomes of iron management guided by classical markers of iron status (TSAT and/or ferritin ) with those of iron management guided by a newer marker of iron status (CHr). It should be noted that the two trials (one in U.S. and one in Japan) employed different protocols for initiating intravenous iron therapy and anemia management, which affect the applicability of the trial findings.

The two trials showed different findings in terms of the doses of epoetin required to maintain hematocrit (Hct) targets. Specifically, the U.S. trial showed that guiding iron management via CHr resulted in similar epoetin dosing compared with iron management guided by ferritin or TSAT. In contrast, the Japanese trial found the doses of epoetin were significantly decreased (lower by 36 percent) in the group guided by TSAT, but did not change significantly in the group guided by CHr. However, it should be noted that the Hct target was higher in the U.S. trial, which may explain that the U.S. trial used much higher doses of epoetin than the Japanese trial during the trial period. Despite the differences in the protocols for initiating intravenous iron therapy, both trials reported a significant decrease in the intravenous iron doses administered to patients whose iron management was guided by CHr compared with those guided by TSAT or ferritin. Only the Japanese trial specifically monitored the adverse events associated with study medication; no differences in the hospitalization or infection rates between the two iron management groups were reported.

In conclusion, there is a low level of evidence for a reduction in the number of iron status tests and resulting intravenous iron treatments (a post-hoc intermediate outcome) administered to patients whose iron management was guided by CHr compared with those guided by TSAT or ferritin. Both RCTs reported that Hct remained in the targeted ranges (an indication for the adequacy of anemia management) throughout the study period in all randomized arms, although the Hct target was higher in the U.S. trial than the Japanese trial. We identified no study comparing iron management guided by classical markers with that guided by newer markers (%HYPO, sTfR, Ret-He, ZPP, or hepcidin).

### Detailed Synthesis

#### Description of Included Studies

(Table 16)

Table 16 Characteristics of randomized controlled trials comparing intermediate outcomes of iron management guided by classical laboratory markers with those of iron management guided by newer laboratory markers of iron status in CKD patients undergoing hemodialysis

Study, Year [UI] Country | N_enrolled_/N_analyzed_ | Demographics | Duration of HD | Anemia and Iron Status Indices | Intervention | Comparator | Iron Treatment Regimen | Anemia Management Protocol Targets | Followup Months | Risk of Bias
Fishbane, 2001^70^ [11737617] U.S. | 157/138 | Male (%):54 Age (yr): 60 Race (%):; - Caucasian 46; - African American 44; - Hispanic 7; - Other 3 | ≥3 months | Hb (g/dL):NR Hct (%):35.6 ferritin (ng/mL):240.65 TSAT (%):23.5 | Iron management based on serum CHr measured every 4 wks | Iron management based on ferritin or TSAT measured every 4 wks | IV iron dextran 100 mg for 10 consecutive treatments if presence of iron Tx trigger | Hb and Hct every 2 wks; the dose of EPO adjusted to maintain Hct 33–36% a | 6 | Medium
Kaneko, 2003^66^ [12631092] Japan | 197/183 | Male (%):61 Age (yr): 59 Race (%): NR | 2 months to 26 years | Hb (g/dL):NR Hct (%):31.3 ferritin (ng/mL):247.4 TSAT (%):25.8 | Iron management based on serum CHr measured twice a month | Iron management based TSAT measured twice a month | IV iron colloid with chondroitin sulfate 40 mg 3 times per wk for 2 wks if presence of iron Tx trigger | Hct twice per mo; the dose of EPO adjusted to maintain Hct 29.5–32.5%^b^ | 4 | Medium

CHr=reticulocyte hemoglobin content; EPO= erythropoietin; Hb=hemoglobin; Hct=hematocrit; HD=hemodialysis; NR=not reported; TSAT=transferrin saturation

a Protocol called for 25% dose reductions for Hct >36% and holding doses if Hct >40%, or 50% dose increases for Hct <33%.

b Doses of EPO administered were categorized as 0, 750, 1500, 2250, 3000, 4500, 6000, or 9000 IU/week and modified as follows: (1) dose was raised by 200% if Hct <26%; (2) dose was raised by 100% if 26% ≤ Hct <29.5%; (3) dose was raised by 50% if 29% ≤ Hct <32.5%; (4) dose was reduced by 33% if 32.5% ≤ Hct <33%; (5) dose was reduced by 50% if 33% < Hct ≤36%; (6) if Hct >36%, administration of EPO was suspended. When the administration of EPO had been suspended and Hct was <29.5%, 2250 IU/week of EPO was resumed. If the modified EPO dose in accordance with rule mentioned earlier did not apply to any of the categories, the nearest dose category was adopted.

Two RCTs, with a total of 354 adult CKD patients (mean age: 60 years), undergoing hemodialysis were included.66,70 One trial was conducted in the U.S., with a followup duration of 6 months,70 and the other in Japan, with a followup duration of 4 months.66 Both trials compared the intermediate outcomes of iron management guided by classical markers (TSAT and/or ferritin) with those of iron management guided by a newer marker of iron status (CHr); however, the two trials employed different protocols for initiating intravenous iron therapy and anemia management. Both trials were rated as being at a medium risk of bias, as the analyses were conducted among trial completers only, and allocation concealment and the methods of randomization were not clearly reported.

#### Results

Both RCTs reported that the mean Hct remained in the targeted ranges throughout the study period in all randomized arms, suggesting that the anemia management protocols were adequate in both trials.

##### Dose of Epoetin

(Table 17)

Table 17 Dose of epoetin required to maintain hematocrit targets

Study, Year [UI] Country | Arms (Trigger for Iron Tx) | N | Unit | Baseline | 4 Wks | 8 Wks | 9 Wks | 11 Wks | 16 Wks | 24 Wks | 28 Wks | P_within_ | P_between_
Fishbane, 2001^70^ [11737617] | Iron management guided by serum CHr measured every 4 wks (CHr <29 pg) | 64 | Mean (SD), IU/week | 12237 (12001) | NR | 12200 (12049) | NR | NR | 11300 (11785) | 10933 (12095) | 10949 (12154) | NS | NR
U.S. | Iron management guided by ferritin or TSAT measured every 4 wks (ferritin <100 ng/mL or TSAT < 20%) | 74 | Mean (SD), IU/week | 12232 (11029) | NR | 12077 (11444) | NR | NR | 12100 (11029) | 11902 (11320) | 11772 (11780) | NS
Kaneko, 2003^66^ [12631092] | Iron management guided by serum CHr (CHr <32.5 pg) twice a month | 94 | Mean (SD), IU/week | 4121 (2922) | 5426 (3481) | NR | 3957 (3320) | 3638 (3276) | 3606 (3347) | NA | NA | <0.05 at 4 wks | <0.05 from 11 wks
Japan | Iron management guided by TSAT (TSAT <20%) twice a month | 89 | Mean (SD), IU/week | 4081 (3123) | 4803 (3325) | NR | 3051 (2730) | 2528 (2730) | 2629 (2640) | NA | NA | <0.01 from 11 wks

CHr= reticulocytes hemoglobin content; NA=not applicable; NR=not reported; NS=not statistically significant; SD=standard deviation; TSAT=transferrin saturation; Tx=treatment; UI=universal identifier; wk=week

Both RCTs reported the dose of epoetin required to maintain the Hct target as the primary outcome.66,70 The epoetin dose adjustment schedule was more frequent in the U.S. trial (every 2 weeks)70 than the Japanese trial (twice per month, 3 days after the previous hemodialysis therapy).66 The Hct target was higher in the U.S. trial (Hct target between 33 and 36 percent) than the Japanese trial (Hct target between 29.5 and 32.5 percent). The protocols for initiating intravenous iron therapy also differed between the two trials. Generally, the U.S. trial used much higher doses of epoetin than the Japanese trial at baseline (12,232 vs. 4121 IU/week) and at the end of trial period (10,949 vs. 3606 IU/week).

The U.S. trial analyzed the change in the doses of epoetin administered among 138 patients who completed the 28-week trial.70 The investigators found a decreasing trend in the mean epoetin dose requirement for both iron management groups, but these trends were not statistically significant. Specifically, the mean epoetin dose decreased from 12,237 to 10,949 IU per week in the iron management group guided by the newer marker (CHr <29 pg), and decreased from 12,232 to 11,772 IU per week in the iron management group guided by the classical markers (ferritin <100 ng/mL or TSAT < 20 percent). The authors did not conduct statistical testing for the differences between groups.

The Japanese trial analyzed the change in the doses of epoetin administered among 184 patients who completed the 16-week trial.66 This trial showed a significant increase in the epoetin dose requirement in the iron management group guided by the newer marker (CHr <32.5 pg) from baseline (4121 IU/week) to 4-week followup (5426 IU/week, P<0.05). During later followup time points, a decreasing trend in the epoetin dose requirement (3957 and 3606 IU/week at 9 and 16 weeks, respectively) was observed; however, these doses did not differ significantly from the baseline dose. A similar trend was observed in the iron management group guided by the classical marker (TSAT < 20 percent). However, the dose of epoetin requirement was significantly lower in the iron management group guided by the classical marker from 11 weeks to the end of the 16-week trial (2528 and 2629 IU/week, respectively), compared with the doses in the iron management group guided by the newer marker.

##### Iron Testing and Resulting Iron Treatment

Total iron dose requirement was the primary outcome in the U.S. trial70 and the secondary outcome in the Japanese trial.66 The U.S. trial initiated 100 mg intravenous iron dextran treatment for 10 consecutive hemodialysis therapies, either when ferritin was <100 ng/mL or TSAT was < 20 percent (the group guided by classical markers) or when CHr was <29 pg (the group guided by the newer laboratory marker). Intravenous iron was not administered if ferritin was > 800 ng/mL or TSAT > 50 percent. Patients in the Japanese trial were treated with 40 mg iron colloid with chondroitin sulfate 3 times per week for 2 weeks at the end of each hemodialysis therapy when either TSAT was < 20 percent (the group guided by the classical marker) or CHr was <32.5 pg (the group guided by the newer laboratory marker).66

The U.S. trial compared the number of courses of intravenous iron triggered, the number of patients in whom testing triggered a course of intravenous iron treatment, and the mean weekly dose of intravenous iron between the two iron management groups during the 28-week trial.70 Of the 64 patients in the newer marker group, CHr was tested a total of 369 times, resulting in 27 (42 percent) patients receiving 42 courses of intravenous iron; the weekly dose of intravenous iron dextran was 22.9 (±20.5 SD) mg. Of the 74 patients in the classical markers group, ferritin and TSAT were tested a total of 419 times, resulting in 59 (80 percent) patients receiving 104 courses of intravenous iron; the weekly dose of intravenous iron dextran was 47.7 (±35.5 SD) mg. The number of iron status tests and resulting treatments were significantly higher in the classical markers group.

The Japanese trial compared the total dose of iron colloid administered between the two iron management groups during the 16-week trial.66 There was a 4-week run-in period before the start of the RCT during which oral and intravenous iron administration was suspended. The total dosage of iron colloid administered was significantly higher in the classical marker group (as compared with the newer marker group) from 13 weeks to the end of the trial (mean total dose 377.5 vs. 267.7 mg, P<0.05).

Both RCTs compared the changes in iron status markers between the two iron management groups. In both RCTs, the CHr test displayed much less test variability, expressed as coefficient of variation (CV), in comparison with the ferritin or TSAT tests. The reported CVs for CHr, ferritin, and TSAT were 3.4, 43.6, and 39.5 percent, respectively, in the U.S. trial;70 and 6.3, 130.5, and 48.9 percent, respectively in the Japanese trial.66 In both trials, none of the iron status markers differed significantly between the two iron management groups at baseline; however, changes in markers after iron treatments were inconsistent across the two trials (Table 18).

Table 18 Changes in iron status markers

Study, Year [UI] Country | Arms (Trigger for Iron Tx) | N | Followup Duration (wk) | Outcome | Unit | Baseline | Final | P_within_ | P_between_
Fishbane, 2001^70^ [11737617] U.S. | Iron management guided by serum CHr measured every 4 wks (CHr <29 pg) | 64 | 28 | ferritin | Mean (SD), ng/mL | 251.7 (231.3) | 304.7 (290.6) | NS | 0.05 at final
Fishbane, 2001^70^ [11737617] U.S. | Iron management guided by ferritin or TSAT measured every 4 wks (ferritin <100 ng/mL or TSAT < 20%) | 74 | | ferritin | Mean (SD), ng/mL | 229.6 (178.8) | 399.5 (247.6) | <0.05
Fishbane, 2001^70^ [11737617] U.S. | Iron management guided by serum CHr measured every 4 wks (CHr <29 pg) | 64 | 28 | TSAT | Mean (SD), % | 22.3 (11.7) | 25.8 (16.6) | NS | 0.04 at final
Fishbane, 2001^70^ [11737617] U.S. | Iron management guided by ferritin or TSAT measured every 4 wks (ferritin <100 ng/mL or TSAT < 20%) | 74 | | TSAT | Mean (SD), % | 24.7 (12.7) | 29.4 (17.8) | <0.05
Fishbane, 2001^70^ [11737617] U.S. | Iron management guided by serum CHr measured every 4 wks (CHr <29 pg) | 64 | 28 | CHr | Mean (SD), pg | 30.8 (1.7) | 30.8 (1.8) | NS | NS
Fishbane, 2001^70^ [11737617] U.S. | Iron management guided by ferritin or TSAT measured every 4 wks (ferritin <100 ng/mL or TSAT < 20%) | 74 | | CHr | Mean (SD), pg | 31.1 (1.8) | 31.1 (1.8) | NS
Kaneko, 2003^66^ [12631092] Japan | Iron management guided by serum CHr (CHr <32.5 pg) twice a month | 94 | 16 | ferritin | Mean (SD), ng/mL | 234.5 (307.0) | 279.5 (326.9) | <0.01 | NS
Kaneko, 2003^66^ [12631092] Japan | Iron management guided by TSAT (TSAT <20%) twice a month | 89 | | ferritin | Mean (SD), ng/mL | 257.0 (453.4) | 372.6 (518.1) | <0.0001
Kaneko, 2003^66^ [12631092] Japan | Iron management guided by serum CHr (CHr <32.5 pg) twice a month | 94 | 16 | TSAT | Mean (SD), % | 25.5 (12.6) | 28.2 (14.3) | NS | <0.05 at final
Kaneko, 2003^66^ [12631092] Japan | Iron management guided by TSAT (TSAT <20%) twice a month | 89 | | TSAT | Mean (SD), % | 25.7 (15.6) | 32.7 (14.9) | <0.0001
Kaneko, 2003^66^ [12631092] Japan | Iron management guided by serum CHr (CHr <32.5 pg) twice a month | 94 | 16 | CHr | Mean (SD), pg | 33.2 (2.2) | 34.4 (1.6) | <0.0001 | NS
Kaneko, 2003^66^ [12631092] Japan | Iron management guided by TSAT (TSAT <20%) twice a month | 89 | | CHr | Mean (SD), pg | 32.8 (2.4) | 34.3 (1.9) | <0.0001

CHr= reticulocytes hemoglobin content; NA=not applicable; NR=not reported; NS=not statistically significant; TSAT=transferrin saturation; Tx=treatment; UI=universal identifier; wk=week

##### Adverse Events

In the U.S. trial, 19 (12 percent) patients were withdrawn during the study period. Reasons for withdrawal included prolonged hospitalization (8 patients), bleeding requiring blood transfusion (3 patients), transplant (1 patient), withdrawal of consent (1 patient), protocol violation (4 patients), and death (2 patients).70 However, any association of these events with iron testing or study medication is unclear. It was also not clear whether the dropout rate was unbalanced between the two randomized groups, but it is likely that more patients dropped out from the iron management group guided by CHr than the group guided by classical markers, based on the number of completers.

The Japanese trial specifically monitored the adverse events associated with study medication during the trial.66 Signs and symptoms were evaluated during and after each hemodialysis session, and the rates of incidence of hospitalization, infections, and deaths were recorded. There were a total of three deaths (2 patients in the CHr group; 1 patient in the TSAT group) due to bacterial pneumonia (at week 4 in the CHr group), sudden death by unknown cause (at week 16 in the CHr group), and liver tumor (at week 7 in the TSAT group). One patient in the TSAT group dropped out because of massive bleeding due to a femoral bone fracture and need for blood transfusion. There were no significant differences in the hospitalization or infection rates of the two iron management groups. Overall, two patients were hospitalized: one due to infection of renal cysts (1 patient in the CHr group) and one due to internal shunt obstruction (1 patient in the TSAT group).

## Key Question 4 Factors Affecting Test Performance and Clinical Utility

### Key Points

Only single studies or indirect comparisons across studies provided data on the potential impacts of some factors (i.e., interactions between iron and ESA treatment, route of iron administration, and treatment regimen) on the test performance of newer or classical laboratory markers of iron status. Therefore, the strength of evidence is insufficient to draw conclusions regarding factors that may affect the test performance or clinical utility of laboratory markers of iron status.

### Detailed Synthesis

(Tables 19 and 20)

Table 19 Characteristics of studies evaluating factors affecting test performance and clinical utility

Study, Year [UI] Country, Design | Study Population | Groups | Intervention | N | Demographics | Anemia and Iron Status Indices | Followup Duration (wk) | Risk of Bias
Singh, 2007^68^ [17396118] U.S. RCT | HD CKD | IV iron | IV ferric gluconate 1 g & 25% increase in weekly epoetin dose for 6 weeks | 64 | Male (%):58 Age (yr): 61 Race (%):; - Caucasian 31; - African American 47; - Hispanic 14; - Asian/Pacific islander 8 | Hb (g/dL): 10.4 Hct (%): NR ferritin (ng/mL): 759 TSAT (%): 18.5 | 6 | Medium
Singh, 2007^68^ [17396118] U.S. RCT | HD CKD | No IV Iron | 25% increase in weekly epoetin dose for 6 weeks | 65 | Male (%):43 Age (yr): 59 Race (%):; - Caucasian 31; - African American 51; - Hispanic 14; - Asian/Pacific islander 3; - Other 2 | Hb (g/dL): 10.2 Hct (%): NR ferritin (ng/mL): 765 TSAT (%): 19 | 6 | Medium
Ahluwalia, 1997(study 1; study 4)69 [9328369] U.S. Prospective cohorts | HD CKD | ESA naïve patient starting ESA treatment | One ferrous sulfate tablet (containing 50 mg elemental iron) per day with mean ESA dose of 162 IU/kg/week | 17 | Male (%):NR Age (yr): 46 Race (%):NR | Hb (g/dL):7.1 Hct (%):NR ferritin (ng/mL):98.5 TSAT (%):NR | 12 | Medium
Ahluwalia, 1997(study 1; study 4)69 [9328369] U.S. Prospective cohorts | HD CKD | Increase in ESA dose for patient on maintenance ESA treatment | One 65 mg ferrous sulfate tablet per day with mean ESA dose of 121 IU/kg/week | 16 | Male (%):NR Age (yr): 46 Race (%):NR | Hb (g/dL):7.8 Hct (%):NR ferritin (ng/mL):59.5 TSAT (%):17 | 4 | Medium

CKD=chronic kidney disease; ESA=erythropoiesis stimulating agents; Hb=hemoglobin; Hct=hematocrit; HD=hemodialysis; IV=intravenous; IU=international units; NR=not reported; TSAT=transferrin saturation; wk=week; yr=year

Table 20 Test accuracy of TSAT, ferritin, CHr, and sTfR for predicting change in hemoglobin in subgroups of IV iron and no IV iron treatment

Study, Year [UI] Country Design | Group | N | Reference Standard—Dx of Iron Deficiency | Index Test | Cutoff for Index Test | Sensitivity, % | Specificity, %
Singh, 2007^68^ [17396118] U.S. RCT | IV Iron | 64 | Hb change of ≥ 2 g/dL | TSAT | ≥ 19% | 48.5 | 54.8
Singh, 2007^68^ [17396118] U.S. RCT | IV Iron | 64 | Hb change of ≥ 2 g/dL | ferritin | ≥ 726 ng/mL | 46.9 | 53.1
Singh, 2007^68^ [17396118] U.S. RCT | IV Iron | 64 | Hb change of ≥ 2 g/dL | CHr | ≥ 31.2 pg/cell | 63.9 | 75
Singh, 2007^68^ [17396118] U.S. RCT | IV Iron | 64 | Hb change of ≥ 2 g/dL | sTfR | ≥ 5.9 mg/L | 42.4 | 48.4
Singh, 2007^68^ [17396118] U.S. RCT | IV Iron | 64 | Hb change of ≥ 2 g/dL
Singh, 2007^68^ [17396118] U.S. RCT | No IV Iron | 65 | Hb change of ≥ 2 g/dL | TSAT | ≥19% | 28.6 | 70
Singh, 2007^68^ [17396118] U.S. RCT | No IV Iron | 65 | Hb change of ≥ 2 g/dL | ferritin | ≥ 726 ng/mL | 27.3 | 68.8
Singh, 2007^68^ [17396118] U.S. RCT | No IV Iron | 65 | Hb change of ≥ 2 g/dL | CHr | ≥ 31.2 pg/cell | 26.7 | 68.6
Singh, 2007^68^ [17396118] U.S. RCT | No IV Iron | 65 | Hb change of ≥ 2 g/dL | sTfR | ≥ 5.9 mg/L | 35.3 | 77.4
Ahluwalia, 1997 (study 1; study 4)69 [9328369] U.S. (study 1;study4) Prospective cohorts | ESA naïve patient starting ESA treatment | 16 | > 2 g/dL increase in Hb at 3 months after initiation of rHuEPO therapy | sTfR | <6 mg/L | 88 | 78
Ahluwalia, 1997 (study 1; study 4)69 [9328369] U.S. (study 1;study4) Prospective cohorts | ESA naïve patient starting ESA treatment | 16 | > 2 g/dL increase in Hb at 3 months after initiation of rHuEPO therapy | ferritin | >50 μg/L | 88 | 44
Ahluwalia, 1997 (study 1; study 4)69 [9328369] U.S. (study 1;study4) Prospective cohorts | ESA naïve patient starting ESA treatment | 16 | > 2 g/dL increase in Hb at 3 months after initiation of rHuEPO therapy | ferritin & sTfR | >50 μg/L & <6 mg/L | 75 | 78
Ahluwalia, 1997 (study 1; study 4)69 [9328369] U.S. (study 1;study4) Prospective cohorts | Increase in ESA dose for patient on ESA treatment | 17 | > 1 g/dL increase in Hb 4 weeks over the baseline level | sTfR | > 20 % increase in sTfR at 1 week | 69 | 100

CHr=reticulocytes hemoglobin content; Dx=diagnosis; ESA=erythropoiesis stimulating agents; Hb=hemoglobin; Hct=hematocrit; IV=Intravenous; NR=not reported; rHuEPO=recombinant human erythropoietin; sTfR= soluble transferrin receptor; TSAT=transferrin saturation; Tx=treatment

Although only two studies included in this section, from all 27 studies included in Key Questions 2, relevant data on factors that may affect the test performance of laboratory markers of iron status were also reported here.

#### Interactions Between Iron and ESA Treatment

One trial randomized 134 HD CKD patients to either no IV iron or IV iron (1 gram of ferric gluconate) group.68 This trial was rated as being at a medium risk of bias. This trial enrolled a special population of HD CKD patients with high ferritin (500–1200 ng/mL) and a low TSAT levels (≤ 25%), possibly due to functional iron deficiency. The test accuracy of baseline laboratory biomarkers of iron status in predicting a response to ESA treatment, defined as a Hb increase ≥2 g/dL, was assessed in both groups (IV iron or no IV iron group). Baseline epoetin doses were raised by 25 percent in both groups, starting with the first hemodialysis session of week 1 and then maintained for the entire study until the first hemodialysis session of week 6. Laboratory biomarkers were obtained weekly.

Within the no intravenous iron group (25% epoetin dose increase alone), the sensitivity and specificity pairs for a TSAT cutoff of ≥19 percent and a ferritin cutoff of ≥726 ng/mL were 29 and 70 percent, and 27 and 69 percent, respectively. The sensitivity and specificity pairs for a CHr cutoff of ≥31.2 pg and a sTfR cutoff of ≥5.9 mg/L were 27 and 69 percent, and 35 and 77 percent, respectively. Multivariable logistic regression analysis showed that none of response markers (including TSAT, ferritin, CHr, sTfR, c-reactive protein, and epoetin) other than absolute value of epoetin dose increase predicted a statistically and clinically significant response to anemia treatment.

In contrast, in the intravenous iron group, a cutoff of CHr of ≥31.2 pg had a higher sensitivity (64 percent) and specificity (75 percent) in predicting treatment response. However, the test accuracies were lower for sTfR, TSAT, and ferritin. Multivariable logistic regression analysis showed that a higher baseline CHr and a lower baseline c-reactive protein predicted greater likelihood of a response to anemia and iron treatment. In the intention to treat population, the odds ratio of achieving a ≥2 g/dL Hb response in patients with baseline CHr ≥31.2 pg relative to those with lower values was 5.3 (95 percent CI, 1.78, 15.83).

#### Biological Variation in Diagnostic Indices

No study examined the impacts of biological variation in diagnostic indices on the test performance or clinical utility of laboratory markers of iron status.

#### Use of Different Diagnostic Reference Standards

Included in Key Question 2a, one study examined the test performance of RetHe using two different reference standards, and showed that the test performance of RetHe was less favorable for assessing “functional iron deficiency” (TSAT<20%, ferritin 100–800 ng/mL, and Hb <11 g/dL) than for assessing “traditional parameters for iron deficiency” (serum iron < 40 μg/dL, TSAT<20%, ferritin <100 ng/mL, and Hb <11 g/dL) in HD CKD patients.45 In addition, the heterogeneity in the definitions for the reference standard (a response to IV iron treatment) may explain the differences in study findings.

#### Type of Dialysis (i.e., Peritoneal or Hemodialysis)

No study examined the impacts of type of dialysis on the test performance or clinical utility of laboratory markers of iron status.

#### Patient Subgroups

No study performed analyses by patient subgroups.

#### Route of Iron Administration (i.e., Oral or Intravenous) or Treatment Regimen (i.e., Repletion or Continuous Treatment)

No study examined the impacts of route of iron administration or treatment regimen on test performance or clinical utility of laboratory markers of iron status. Indirect comparisons between studies included in the Key Question 2 and the studies included in this section suggest potential impacts of these factors on the test accuracy of newer and classical laboratory markers of iron status.

Most studies included in the Key Question 2 reported that patients were on maintenance ESA (i.e., no change in ESA dose during study) and received IV iron treatment. This is in contrast to the study included in this section. Two cohorts (reported in one article, rated as being at a medium risk of bias) assessed test performance of sTfR in predicting a Hb response to initiation of ESA treatment (> 2 g/dL increase in Hb at 3 months after initiation of ESA therapy, study 1 in the article), and in predicting a response to an increase in ESA treatment dose (> 1 g/dL increase in Hb 4 weeks from baseline, study 4 in the article).69 Both cohorts also treated patients with oral iron. The results from the first cohort showed that a sTfR cutoff of <6 mg/L had better specificity, but the same sensitivity, than a ferritin cutoff of >50 μg/L in predicting an Hb response to initiation of ESA treatment in 17 adult HD CKD patients. In the second study (16 adult HD CKD patients), the results showed that the change in sTfR >20 percent from baseline to week 1 had perfect specificity but a lower sensitivity in predicting a Hb response to an increase in ESA treatment dose.