# References

1 National Kidney Foundation. What causes CKD?. www.kidney.org/kidneydisease/ckd/indexcfm#what. Accessed December 2011.
2 K/DOQI clinical practice guidelines for chronic kidney disease: evaluation, classification, and stratification. Am J Kidney Dis. Feb. Suppl 1. 2002;39(2):S1-266. [pmid: 11904577].
3 National Kidney Foundation. The Facts About Chronic Kidney Disease (CKD). www.kidney.org/kidneydisease/ckd/indexcfm#facts. Accessed December 2011.
4 Couser WG, Remuzzi G, Mendis S, et al. The contribution of chronic kidney disease to the global burden of major noncommunicable diseases. Kidney Int. Dec. 2011;80(12):1258-70. [pmid: 21993585].
5 KDOQI Clinical Practice Guidelines and Clinical Practice Recommendations for Anemia in Chronic Kidney Disease. 2006.
6 Mix TC, Kazmi W, Khan S, et al. Anemia: a continuing problem following kidney transplantation. Am J Transplant. Nov. 2003;3(11):1426-33. [pmid: 14525605].
7 Vanrenterghem Y, Ponticelli C, Morales JM, et al. Prevalence and management of anemia in renal transplant recipients: a European survey. Am J Transplant. Jul. 2003;3(7):835-45. [pmid: 12814475].
8 United States Renal Data System. USRDS 2006 annual data report: atlas of end-stage renal disease in the United States. Bethesda, MD. National Institute of Diabetes and Digestive and Kidney Diseases. 2006.
9 Robertson HT, Haley NR, Guthrie M, et al. Recombinant erythropoietin improves exercise capacity in anemic hemodialysis patients. Am J Kidney Dis. Apr. 1990;15(4):325-32. [pmid: 2321645].
10 Pickett JL, Theberge DC, Brown WS, et al. Normalizing hematocrit in dialysis patients improves brain function. Am J Kidney Dis. Jun. 1999;33(6):1122-30. [pmid: 10352201].
11 Foley RN, Parfrey PS, Harnett JD, et al. The impact of anemia on cardiomyopathy, morbidity, and and mortality in end-stage renal disease. Am J Kidney Dis. Jul. 1996;28(1):53-61. [pmid: 8712222].
12 Harris DC, Chapman JR, Stewart JH, et al. Low dose erythropoietin in maintenance haemodialysis: improvement in quality of life and reduction in true cost of haemodialysis. Aust N Z J Med. Oct. 1991;21(5):693-700. [pmid: 1759917].
13 Evans RW, Rader B, Manninen DL. The quality of life of hemodialysis recipients treated with recombinant human erythropoietin. Cooperative Multicenter EPO Clinical Trial Group. JAMA. Feb. 9. 1990;263(6):825-30. [pmid: 2404150].
14 Stevens ME, Summerfield GP, Hall AA, et al. Cost benefits of low dose subcutaneous erythropoietin in patients with anaemia of end stage renal disease. BMJ. Feb. 22. 1992;304(6825):474-77. [pmid: 1547417].
15 Collins AJ, Li S, Ebben J, et al. Hematocrit levels and associated Medicare expenditures. Am J Kidney Dis. Aug. 2000;36(2):282-93. [pmid: 10922306].
16 Anaemia Management in Chronic Kidney Disease—Rapid Update 2011. National Clinical Guideline Centre. 2011.
17 Eschbach JW, Abdulhadi MH, Browne JK, et al. Recombinant human erythropoietin in anemic patients with end-stage renal disease. Results of a phase III multicenter clinical trial. Ann Intern Med. Dec. 15. 1989;111(12):992-1000. [pmid: 2688507].
18 Eckardt KU. Chronic kidney disease: Are elevated doses of ESAs associated with adverse outcomes?. Nature Reviews Nephrology. Oct. 2010;6(10):566-68.
19 Hayat A. Safety issues with intravenous iron products in the management of anemia in chronic kidney disease. Clin Med Res. Dec. 2008;6(3–4):93-102. [pmid: 19325171].
20 IV. NKF-K/DOQI Clinical Practice Guidelines for Anemia of Chronic Kidney Disease: update 2000. Am J Kidney Dis. Jan. Suppl 1. 2001;37(1):S182-S238. [pmid: 11229970].
21 Bain BJ. Bone marrow biopsy morbidity: review of 2003. J Clin Pathol. Apr. 2005;58(4):406-08. [pmid: 15790706].
22 Winkel P, Statland BE, Bokelund H. Factors contributing to intra-individual variation of serum constituents: 5. Short-term day-to-day and within-hour variation of serum constituents in healthy subjects. Clin Chem. Dec. 1974;20(12):1520-27. [pmid: 4430129].
23 Winkel P, Statland BE, Bokelund H. The effects of time of venipuncture on variation of serum constituents. Consideration of within-day and day-to-day changes in a group of healthy young men. Am J Clin Pathol. Oct. 1975;64(4):433-47. [pmid: 1239188].
24 Wish JB. Assessing iron status: beyond serum ferritin and transferrin saturation. Clin J Am Soc Nephrol. Sep. Suppl 1. 2006;1:S4-S8. [pmid: 17699374].
25 Tietz NW, Rinker AD, Morrison SR. When is a serum iron really a serum iron? The status of serum iron measurements. Clin Chem. Apr. 1994;40(4):546-51. [pmid: 8149608].
26 Eckfeldt JH, Witte DL. Serum iron: would analytical improvement enhance patient outcome?. Clin Chem. Apr. 1994;40(4):505-07. [pmid: 8149600].
27 Braun J, Lindner K, Schreiber M, et al. Percentage of hypochromic red blood cells as predictor of erythropoietic and iron response after I.V. iron supplementation in maintenance haemodialysis patients. Nephrol Dial Transplant. Jun. 1997;12(6):1173-81. [pmid: 9198047].
28 Macdougall IC, Cavill I, Hulme B, et al. Detection of functional iron deficiency during erythropoietin treatment: a new approach. BMJ. Jan. 25. 1992;304(6821):225-26. [pmid: 1739797].
29 Braun J. Erythrocyte zinc protoporphyrin. Kidney Int Suppl. Mar. 1999;69:S57-S60. [pmid: 10084287].
30 Babitt JL, Lin HY. Molecular mechanisms of hepcidin regulation: implications for the anemia of CKD. Am J Kidney Dis. Apr. 2010;55(4):726-41. [pmid: 20189278].
31 Canavese C, Bergamo D, Ciccone G, et al. Validation of serum ferritin values by magnetic susceptometry in predicting iron overload in dialysis patients. Kidney Int. Mar. 2004;65(3):1091-98. [pmid: 14871430].
32 Centers for Medicare & Medicaid Services C. CMS PROPOSES NEW PROSPECTIVE PAYMENT SYSTEM FOR RENAL DIALYSIS FACILITIES. 2009.
33 Agency for Healthcare Research and Quality. Methods Reference Guide for Effectiveness and Comparative Effectiveness Reviews, Version 1.0. 2010.
34 Moher D, Liberati A, Tetzlaff J, et al. Preferred Reporting Items for Systematic Reviews and Meta-Analyses: The PRISMA Statement. PLoS Med. Jul. 21. 2009;6(7):e1000097. [doi: 10.1371/journal.pmed.1000097]. [pmid: 19621072].
35 Whiting P, Rutjes A, Reitsma J, et al. The development of QUADAS: a tool for the quality assessment of studies of diagnostic accuracy included in systematic reviews. BMC Medical Research Methodology. 2003;3(1):25. [pmid: 14606960].
36 Higgins JPT GSe. Cochrane handbook for systematic reviews of interventions. Version 5.0.2. [updated September 2009]. The Cochrane Collaboration. 2009.
37 Altman DG, Bland JM. Presentation of numerical data. BMJ. Mar. 2. 1996;312(7030):572. [pmid: 8595293].
38 Zweig MH, Campbell G. Receiver-operating characteristic (ROC) plots: a fundamental evaluation tool in clinical medicine. Clin Chem. Apr. 1993;39(4):561-77. [pmid: 8472349].
39 Florkowski CM. Sensitivity, specificity, receiver-operating characteristic (ROC) curves and likelihood ratios: communicating the performance of diagnostic tests. Clin Biochem Rev. Aug. Suppl 1. 2008;29:S83-S87. [pmid: 18852864].
40 Glas AS, Lijmer JG, Prins MH, et al. The diagnostic odds ratio: a single indicator of test performance. J Clin Epidemiol. Nov. 2003;56(11):1129-35. [pmid: 14615004].
41 Baldus M, Walter H, Thies K, et al. Transferrin receptor assay and zinc protoporphyrin as markers of iron-deficient erythropoiesis in end-stage renal disease patients. Clinical Nephrology. Mar. 1998;49(3):186-92. [pmid: 9543601].
42 Bhandari S, Norfolk D, Brownjohn A, et al. Evaluation of RBC ferritin and reticulocyte measurements in monitoring response to intravenous iron therapy. American Journal of Kidney Diseases. Dec. 1997;30(6):814-21. [pmid: 9398126].
43 Bhandari S, Turney JH, Brownjohn AM, et al. Reticulocyte indices in patients with end stage renal disease on hemodialysis. Journal of Nephrology. Mar. 1998;11(2):78-82. [pmid: 9589378].
44 Bovy C, Gothot A, Delanaye P, et al. Mature erythrocyte parameters as new markers of functional iron deficiency in haemodialysis: sensitivity and specificity. Nephrology Dialysis Transplantation. Apr. 2007;22(4):1156-62.
45 Brugnara C, Schiller B, Moran J. Reticulocyte hemoglobin equivalent (Ret He) and assessment of iron-deficient states. Clinical & Laboratory Haematology. Oct. 2006;28(5):303-08. [pmid: 16999719].
46 Buttarello M, Pajola R, Novello E, et al. Diagnosis of iron deficiency in patients undergoing hemodialysis. American Journal of Clinical Pathology. Jun. 2010;133(6):949-54. [pmid: 20472854].
47 Chuang CL, Liu RS, Wei YH, et al. Early prediction of response to intravenous iron supplementation by reticulocyte haemoglobin content and high-fluorescence reticulocyte count in haemodialysis patients. Nephrology Dialysis Transplantation. Feb. 2003;18(2):370-77.
48 Cullen P, Soffker J, Hopfl M, et al. Hypochromic red cells and reticulocyte haemglobin content as markers of iron-deficient erythropoiesis in patients undergoing chronic haemodialysis. Nephrology Dialysis Transplantation. Mar. 1999;14(3):659-65.
49 Daschner M, Mehls O, Schaefer F. Soluble transferrin receptor is correlated with erythropoietin sensitivity in dialysis patients. Clinical Nephrology. Oct. 1999;52(4):246-52. [pmid: 10543327].
50 Domrongkitchaiporn S, Jirakranont B, Atamasrikul K, et al. Indices of iron status in continuous ambulatory peritoneal dialysis patients. American Journal of Kidney Diseases. Jul. 1999;34(1):29-35. [pmid: 10401012].
51 Eguchi A, Tsuchiya K, Tsukada M, et al. Clinical usefulness of reticulocyte hemoglobin equivalent (RET-He) in patients at the pre-dialysis stage and in patients on peritoneal dialysis. [Japanese]. Nippon Jinzo Gakkai Shi. Japanese. 2010;(2):132-40. [pmid: 20415234].
52 Fishbane S, Galgano C, Langley RC Jr, et al. Reticulocyte hemoglobin content in the evaluation of iron status of hemodialysis patients. Kidney International. Jul. 1997;52(1):217-22. [pmid: 9211366].
53 Fusaro M, Munaretto G, Spinello M, et al. Soluble transferrin receptors and reticulocyte hemoglobin concentration in the assessment of iron deficiency in hemodialysis patients. Journal of Nephrology. Jan. 2005;18(1):72-79. [pmid: 15772926].
54 Gupta M, Kannan M, Gupta S, et al. Contribution of iron deficiency to anemia in chronic renal failure. Indian Journal of Pathology & Microbiology. Oct. 2003;46(4):563-64.
55 Hukic F, Nuhbegovic S, Brkic S, et al. Biochemical markers of iron status in hemodialysis patients. Medicinski Arhiv. 2010;64(4):219-22. [pmid: 21246919].
56 Kim JM, Ihm CH, Kim HJ. Evaluation of reticulocyte haemoglobin content as marker of iron deficiency and predictor of response to intravenous iron in haemodialysis patients. International Journal of Laboratory Hematology. Feb. 2008;30(1):46-52. [pmid: 18190467].
57 Matuszkiewicz-Rowinska J, Ostrowski G, Niemczyk S, et al. Red cell zinc protoporphyrin and its ratio to serum ferritin (ZPP/logSF index) in the detection of iron deficiency in patients with end-stage renal failure on hemodialysis. [Polish]. Polskie Archiwum Medycyny Wewnetrznej. Jul. 2003;110(1):703-10. [pmid: 14682204].
58 Mitsuiki K, Harada A, Miyata Y. Assessment of iron deficiency in chronic hemodialysis patients: investigation of cutoff values for reticulocyte hemoglobin content. Clinical & Experimental Nephrology. Mar. 2003;7(1):52-57. [pmid: 14586744].
59 Mittman N, Sreedhara R, Mushnick R, et al. Reticulocyte hemoglobin content predicts functional iron deficiency in hemodialysis patients receiving rHuEPO. American Journal of Kidney Diseases. Dec. 1997;30(6):912-22. [pmid: 9398141].
60 Miwa N, Akiba T, Kimata N, et al. Usefulness of measuring reticulocyte hemoglobin equivalent in the management of haemodialysis patients with iron deficiency. International Journal of Laboratory Hematology. Apr. 2010;32(2):248-55. [pmid: 19624802].
61 Tessitore N, Solero GP, Lippi G, et al. The role of iron status markers in predicting response to intravenous iron in haemodialysis patients on maintenance erythropoietin. Nephrology Dialysis Transplantation. Jul. 2001;16(7):1416-23.
62 Tessitore N, Girelli D, Campostrini N, et al. Hepcidin is not useful as a biomarker for iron needs in haemodialysis patients on maintenance erythropoiesis-stimulating agents. Nephrology Dialysis Transplantation. Dec. 2010;25(12):3996-4002.
63 Tsuchiya K, Okano H, Teramura M, et al. Content of reticulocyte hemoglobin is a reliable tool for determining iron deficiency in dialysis patients. Clinical Nephrology. Feb. 2003;59(2):115-23. [pmid: 12608554].
64 Van Wyck DB, Roppolo M, Martinez CO, et al. A randomized, controlled trial comparing IV iron sucrose to oral iron in anemic patients with nondialysis-dependent CKD. Kidney International. Dec. 2005;68(6):2846-56. [pmid: 16316362].
65 Fishbane S, Lynn RI. The utility of zinc protoporphyrin for predicting the need for intravenous iron therapy in hemodialysis patients. American Journal of Kidney Diseases. Mar. 1995;25(3):426-32. [pmid: 7872320].
66 Kaneko Y, Miyazaki S, Hirasawa Y, et al. Transferrin saturation versus reticulocyte hemoglobin content for iron deficiency in Japanese hemodialysis patients. Kidney International. Mar. 2003;63(3):1086-93. [pmid: 12631092].
67 Silva J, Andrade S, Ventura H, et al. Iron supplementation in haemodialysis—practical clinical guidelines. Nephrology Dialysis Transplantation. Oct. 1998;13(10):2572-77.
68 Singh AK, Coyne DW, Shapiro W, et al. Predictors of the response to treatment in anemic hemodialysis patients with high serum ferritin and low transferrin saturation. Kidney International. Jun. 2007;71(11):1163-71. [pmid: 17396118].
69 Ahluwalia N, Skikne BS, Savin V, et al. Markers of masked iron deficiency and effectiveness of EPO therapy in chronic renal failure. American Journal of Kidney Diseases. Oct. 1997;30(4):532-41. [pmid: 9328369].
70 Fishbane S, Shapiro W, Dutka P, et al. A randomized trial of iron deficiency testing strategies in hemodialysis patients. Kidney International. Dec. 2001;60(6):2406-11. [pmid: 11737617].
71 Wish JB. Anemia management under a bundled payment policy for dialysis: a preview for the United States from Japan. Kidney Int. Feb. 2011;79(3):265-67. [pmid: 21228798].
72 Singh AK, Szczech L, Tang KL, et al. Correction of anemia with epoetin alfa in chronic kidney disease. N Engl J Med. Nov. 16. 2006;355(20):2085-98. [pmid: 17108343].
73 Fryback DG, Thornbury JR. The efficacy of diagnostic imaging. Med Decis Making. Apr. 1991;11(2):88-94. [pmid: 1907710].
74 Bossuyt PM, Reitsma JB, Bruns DE, et al. Towards complete and accurate reporting of studies of diagnostic accuracy: The STARD Initiative. Ann Intern Med. Jan. 7. 2003;138(1):40-44. [pmid: 12513043].
75 Rothman K, Greenland S. Modern Epidemiology. Lippincott Williams and Wilkins. 1998.