# Methods

The methods for this comparative effectiveness review (CER) adhere to those suggested by the Agency for Healthcare Research and Quality in its Methods Guide for Effectiveness and Comparative Effectiveness Reviews, hereafter referred to as the Methods Guide (available at www.effectivehealthcare.ahrq.gov/methodsguide.cfm).33 The main sections in this chapter reflect the elements of the protocol established for the CER; certain methods map to the PRISMA checklist.34 All methods were determined a priori. Any deviations from or modifications to the original protocol are described in this chapter.

## AHRQ Task Order Officer

The AHRQ Task Order Officer (TOO) was responsible for overseeing all aspects of this project. The TOO facilitated a common understanding among all parties involved in the project, resolved ambiguities, and fielded all EPC queries regarding the scope and processes of the project. The TOO and other staff at AHRQ reviewed the report for consistency, clarity, and to ensure that it conforms to AHRQ standards.

## Topic Refinement and Review Protocol

During a topic refinement phase, the initial questions that had previously been nominated for this report were refined with input from a panel of Key Informants. Key Informants included two representatives from the original nominating organization (American Association of Clinical Chemistry), two nephrologists, one hematologist, one renal dietician, one nurse manager, one public payer representative, and one private payer representative. After a public review of the proposed Key Questions, the clinical experts were reconvened to form the Technical Expert Panel (TEP), which served in an advisory capacity to help refine Key Questions, identify important issues, and define parameters for the review of evidence. Discussions among the EPC, TOO, Key Informants, and, subsequently, the TEP occurred during a series of teleconferences and via email. In addition, input from the TEP was sought during compilation of the report when questions arose concerning the scope of the review.

## Literature Search Strategy

### Search Strategy

We conducted literature searches of studies in MEDLINE^®^ (from inception to May, 2012) and the Cochrane Central Register of Controlled Trials (through the first quarter of 2012). All studies published in any language with adult human subjects were screened to identify articles relevant to each Key Question. Our search strategy employed the National Library of Medicine’s Medical Subject Headings (MeSH) keyword nomenclature developed for MEDLINE. The full search strategy is described in Appendix A. The search strategy included MeSH or search terms for both newer and older laboratory biomarkers of interest, and MeSH or search terms for iron or erythropoietin treatment drugs and formulations. We combined these two groups of search strategies with MeSH or search terms for population and study designs of interest. We checked our search strategy against those used in relevant guidelines and systematic reviews. We also make sure our search covered key articles identified from the reference lists of key papers.

We did not search for unpublished studies, as such works and their data are not peer reviewed. However, we did search the Food and Drug Administration 510(k) database (www.accessdata.fda.gov/scripts/cdrh/cfdocs/cfpmn/pmn.cfm) for all listed automated hematology analyzer with Product Code GKZ in July, 2012. We limited the search to products that received approval since 2008, and did not find relevant data in CKD patients. We also screened the reference lists of related guidelines and selected narrative reviews and primary articles for additional articles. Finally, we searched ClinicalTrials.gov for ongoing or completed studies using the search string “iron deficiency AND (dialysis OR kidney disease)”. When potential relevant studies were found, we conducted Internet and Pubmed® search for associated peer-reviewed publications.

### Inclusion and Exclusion Criteria

The eligibility criteria for populations, interventions, comparators, outcomes, and study designs or settings (PICOS) are enumerated in Table 1. For all Key Questions, we excluded studies with fewer than 10 patients with CKD.

Table 1 Study eligibility criteria

Key Question/PICO | Inclusion Criteria
Key Question 1 (Overarching Question)
Populations | - Pediatric and adult nondialysis patients with stage 3, 4, or 5 CKD; - Patients with CKD undergoing dialysis (hemo- or peritoneal dialysis); - Patients with a kidney transplant
Interventions | - Newer laboratory biomarkers^*^ to assess iron status and manage iron deficiency either as a replacement for or in addition to older laboratory biomarkers
Comparators | - Older laboratory biomarkers^†^ to assess iron status and manage iron deficiency
Outcomes | - Mortality; - Morbidity (e.g., cardiac or liver toxicity and infection); - Quality of life, measured using standardized scales, including: Kidney Disease Quality of Life (KDQOL), Health Related Quality of Life (HRQOL), Medical Outcomes Study Short Form-36 (SF-36), and Pediatric Quality of Life Inventory (PQLI); - Adverse effects or harms associated with testing and associated treatments (e.g., test-related anxiety, adverse events secondary to venipuncture, effects of iron overload with iron treatments, and cardiovascular complications from use of erythropoietin at higher Hb levels)
Study designs | - Randomized controlled trials; - Nonrandomized controlled trials; - Observational studies with concurrent comparison groups
Key Question 2, 3 and 4
Populations | - Pediatric and adult nondialysis patients with stage 3, 4, or 5 CKD; - Patients with CKD undergoing dialysis (hemo- or peritoneal dialysis); - Patients with a kidney transplant
Interventions | - Newer laboratory biomarker alone^a^ or in combination with older laboratory biomarkers of iron status^b^
Comparators | - Older laboratory biomarkers of iron status, which include bone marrow iron stores, serum iron, transferrin saturation, iron-binding capacity, and ferritin
Outcomes | Key Question 2 and 4:; - Measures of test performance (e.g., concordance, sensitivity, specificity, predictive values, AUC) comparing newer with older markers of iron status. We accepted any “reference standard” used by the study authors for the analyses of sensitivity and specificity in the original study, including functional iron deficiency as defined by response or nonresponse to treatment; - Adverse effects or harms associated with laboratory testing; Key question 3 and 4:; - Intermediate outcomes; - Increase in Hb or hematocrit, or more consistent maintenance of Hb or hematocrit within the desired range; - Use of ESA for maintenance of Hb within the desired range (stable dose in contrast to escalating dose resulting in net decreased ESA dose in hyporesponsive patients or actual decreased ESA dose in relatively responsive patients); - Adverse effects or harms associated with different management strategies
Study designs | Key Question 2:; - Any design; Key Question 3 and 4:; - Randomized controlled trials; - Nonrandomized controlled trials; - Observational studies with concurrent comparison groups
Study settings | - Any setting: primary or specialty care, in-facility or home, and inpatient or outpatient

AUC=area under the curve; CKD=chronic kidney disease; ESA= erythropoiesis stimulating agents; Hb=hemoglobin; HD=hemodialysis; IV=intravenous; RetHe=reticulocyte hemoglobin equivalent; sTfR= soluble transferrin receptor; TSAT=transferrin saturation; ZPP=erythrocyte zinc protoporphyrin.

a Hemoglobin (Hb) content in reticulocytes, percentage of hypochromic red blood cells, erythrocyte zinc protoporphyrin, soluble transferrin receptor, hepcidin, and superconducting quantum interference devices.

b Bone marrow iron stores, serum iron, transferrin saturation, iron-binding capacity, and ferritin.

### Study Selection

We screened all abstracts available in English. Abstracts were screened based on eligibility criteria, with exclusions cross-checked by a second investigator. All studies that were accepted based on their abstracts were then reviewed in full. For those articles not available in English, we first employed Google Translate (translate.google.com) in attempting to determine their eligibility. If we had any question on the eligibility of non-English articles, we identified native language speakers to assist in full-text screening. It should be noted that most non-English articles in our literature search had English abstracts, and in many cases, non-English articles were excluded at the abstract screening level.

Full-text articles were evaluated independently by two investigators for eligibility. Disagreement on an article’s eligibility was resolved by consensus. A list of excluded articles and the reasons for excluding these articles are tabulated in Appendix B.

### Data Extraction

Each study was extracted by one investigator, and reviewed and confirmed by at least one other investigator. Any disagreements were resolved by discussion amongst the team members. Data were extracted into standard forms. The basic elements and design of these forms were similar to those we have used for other comparative effectiveness reviews, such as queries capturing population characteristics, sample size, study design, descriptions of the test and reference standard, analytic details, and outcomes. Prior to extraction, the form was customized to capture all elements relevant to the Key Questions. We used separate forms for questions related to test performance (Key Question 2) and the effectiveness of test-oriented treatments (Key Question 3). We tested the forms on several studies and revised as necessary prior to data extraction of all articles. A blank extraction form is provided in Appendix C.

## Risk of Bias—Assessment of Individual Studies

We assessed the risk of biases (methodological quality) for each individual study using the assessment instrument described in the AHRQ Methods Guide.33 Briefly, we rated each study as being of high, medium, or low risk of bias on the basis of adherence (Yes, No, or Unclear/Not reported) to generally accepted standard methodologies (Quality Assessment of Diagnostic Accuracy Studies [QUADAS] 35 tool for studies of diagnostic performance and the Cochrane risk of bias tool for intervention studies36), and assessed and reported each methodological quality item for all qualifying studies. We also considered the clarity and consistency in reporting as part of the overall judgment of risk of bias. Grading was outcome-specific, such that a given study that reported its primary outcome well but conducted an incomplete analysis of a secondary outcome would be graded as having different quality for the two outcomes. Studies of different study designs were graded within the context of their study design; RCTs and observational studies were graded separately to be at a high, medium, or low risk of bias. Only RCTs and prospective cohort studies could be rated as having a low risk of bias.

## Data Synthesis

We summarized all included studies in narrative form as well as in summary tables (see below) that condense the important features of the study populations, design, anemia and iron status indices, laboratory tests, reference standards, background treatment, intervention, outcomes, and results. Where appropriate we summarized the characteristics of eligible studies using summary statistics (means, medians, ranges and standard deviations).37

The synthesis of data for Key Question 2 was complicated by the fact that there is a lack of generally accepted reference standard tests for determining iron deficiency in the context of CKD.16 Thus, we accepted any “reference standard” used by the authors of the included primary studies for the analyses of test performance of newer or classical laboratory biomarkers of iron status. Based on our post-hoc observation of this body of literature, we separated the included studies into two distinct groups. Specifically, current studies use two distinct methods to operationalize a reference standard for assessing test performance: (1) a response to intravenous (IV) iron treatment, often referred to as “functional iron deficiency”; and (2) classical laboratory biomarkers, alone or in combination with each other, often referred to as “absolute iron deficiency”.

When a study used a response to IV iron treatment as the reference standard for iron deficiency, it allowed us to directly compare the test performance of classical with newer biomarkers in predicting a response. To facilitate the interpretation of study results, the reported sensitivity and specificity of both newer and classical laboratory biomarkers were visually depicted in receiver operating characteristic (ROC) space. We did not conduct meta-analyses because there was a high degree of heterogeneity across studies in the definitions of reference standard (a response to IV iron treatment), baseline iron status of the study populations, and background treatment.

When a study used classical laboratory biomarkers (alone or in combination with each other) as the reference standard for iron deficiency, we were prevented from comparing the test performance of classical with newer biomarkers. For the purpose of our review, this approach was analogous to assessing the concordance between classical and newer biomarkers of iron status. Since concordance cannot tell us which test is better and which is worse—both may be equally bad or equally good for defining “iron deficiency”—and cannot answer Key Question 2, these studies were only included for subquestion 2a (What reference standards are used for the diagnosis of iron deficiency in studies evaluating test performance?).

### Summary Tables

Summary tables succinctly report measures of the main outcomes evaluated, and additional information to assist their interpretation. We used separate summary tables for questions related to test performance (Key Question 2) and the effectiveness of test-oriented treatments (Key Question 3). For Key Question 2, we included information regarding study population, laboratory analysis or assay, index test cutoff, reference standard, percentage of patients with iron deficiency, test performance outcomes (e.g., sensitivity, specificity, and area under the ROC curve [AUC]), and risk of bias. For Key Question 3, we included additional information regarding iron treatment regimen, anemia management protocol targets, followup duration, the mean outcome values, their 95 percent confidence intervals (CI), standard deviations (SD) or other measures of variability and when available, the mean difference (between groups) and its corresponding P value, or CI, as appropriate.

### Graphical Presentation of Study Results

To facilitate the interpretation of study results, the reported sensitivity and specificity of both newer and classical laboratory biomarkers of iron status were visually depicted in ROC space,. Each point on the ROC curve represents a sensitivity/specificity pair corresponding to a particular decision threshold. A test with perfect discrimination (no overlap in the two distributions) has a ROC curve that passes through the upper left corner (100% sensitivity, 100% specificity). Therefore, the closer the ROC curve is to the upper left corner, the higher the overall accuracy of the test.38

When applicable, a published ROC curve that showed individual data points for multiple cutoffs on the curve was digitized using Engauge Digitizer, an open source digitizing software package (digitizer.sourceforge.net/). The digitization was accomplished by obtaining the image file of the published graph or plot, recording locations of data points and axes, and using the software to convert the data points on the graph into estimated data values. The digitized data were then exported into Stata^®^ (a data analysis and statistical software suite) to recreate the ROC curve.

### Test Performance Terms and Definitions

There are many quantitative indicators of test performance.39 Below, we list the test performance terms and definitions used in the current report:

- Receiver operating characteristic curve: ROC curves compare sensitivity with specificity across a range of values for the ability to predict a dichotomous outcome (defined as the reference standard). The ROC curve graphically displays the trade-off between sensitivity and specificity, and is useful in assigning the best cut-offs for clinical use.
- Overall test accuracy: Overall accuracy of a test is expressed as area under the ROC curve (AUC). The AUC provides another useful parameter for comparing test performance between, for example, classical and newer laboratory biomarkers of iron status. The AUC summarizes the ROC curve in a single number but loses information about the tradeoffs between sensitivity and specificity.
- Test accuracy: Test accuracy refers to sensitivity (true positive rate) and specificity (true negative rate) of a test. For any test, there is usually a trade-off between sensitivity and specificity. For example, a test may exhibit a high sensitivity and a low specificity, or vice versa.
- Diagnostic odds ratio (DOR): The DOR is a single indicator of test performance that combines the strengths of sensitivity and specificity.40 The DOR offers advantages when logistic regression is used with diagnostic problems, because the DOR equals the regression coefficient, after exponentiation. DORs are conditional: They depend on the other variables that have been used in the model. Consequently, the conditional DOR of each test variable, adjusted for the other variable (e.g., inflammation markers), can be estimated.

## Strength of the Body of Evidence

We followed the Methods Guide in evaluating the strength of the body of evidence for each Key Question with respect to four domains: risk of bias, consistency, directness, and precision.33,33 Briefly, we defined the risk of bias—low, medium, or high—on the basis of design and methodological quality of the underlying studies.

We rated the consistency of the data as: no inconsistency, inconsistency present, or not applicable if there was only one study available. We assessed the direction, magnitude, and statistical significance of all studies to make a determination. We described our logic where studies were not unanimous. For Key Question 2, we judged consistency based on the studies’ location in the ROC space as a measure of consistency

We assessed the precision of the evidence (assessed as precise or imprecise) on the basis of the degree of certainty surrounding an effect estimate. A precise estimate was an estimate that would allow a clinically useful conclusion. An imprecise estimate was one for which the confidence interval was wide enough to include clinically distinct conclusions (e.g., both clinically important benefits and harms—a situation in which the direction of effect is unknown), a circumstance that would preclude a conclusion. For Key Question 2, we judged precision based on the distance of the study’s positive and negative LR scores from our pre-determined LR cutoffs.

We assess the directness based on the types of outcomes. We considered studies provided patient-center outcomes as the direct evidence to address our key questions. Finally, we rated the body of evidence based on a four-level scale—high, moderate, low, and insufficient—on the basis if our level of confidence that the evidence reflected the true effect for the major comparisons of interest.33 The rating of the strength of the body of evidence was based on the consensus of all team investigators.

## Applicability

We followed the Methods Guide in evaluating the applicability of included studies to each patient population of interest,33 that is, nondialysis patients with stage 3, 4, or 5 CKD, patients with CKD undergoing hemo- or peritoneal dialysis, and patients with a kidney transplant. We evaluated and summarized studies of pediatric, adult, and elderly adults separately.

## Peer Review and Public Commentary

The initial draft report was prereviewed by the TOO and an AHRQ Associate Editor (a senior member of a sister EPC). Following revisions, the draft report was sent to invited peer reviewers and was simultaneously uploaded to the AHRQ Web site where it was available for public comment for 30 days. All reviewer comments (both invited and from the public) were collated and individually addressed. The revised report and the EPC’s responses to invited and public reviewers’ comments were again reviewed by the TOO and Associate Editor prior to completion of the report. The authors of the report had final discretion as to how the report was revised based on the reviewer comments, with oversight by the TOO and Associate Editor.