# Peer Reviewers

John W. Adamson, M.D.

Clinical Professor of Medicine

Hematology/Oncology

University of California, San Diego

Jeffrey S. Berns, M.D.

Associate Dean for Graduate Medical Education

Professor of Medicine and Pediatrics

Renal-Electrolyte and Hypertension Division

Hospital of the University of Pennsylvania

Philadelphia, PA

Alex C. Chin, Ph.D., DABCC, FACB

Clinical Chemist

Calgary Laboratory Services

Clinical Assistant Professor

Department of Pathology and Laboratory Medicine Faculty of Medicine University of Calgary

Calgary, AB Canada

Susan Furth, M.D., Ph.D.

Division Chief, Nephrology

Professor, Department of Pediatrics and Epidemiology, Perelman School of Medicine at the University of Pennsylvania

Senior Scholar, Clinical Epidemiology Unit, Center for Clinical Epidemiology and Biostatistics, Perelman School of Medicine at the University of Pennsylvania

Ameet R. Kini, M.D., Ph.D.

Associate Professor of Pathology

Director, Division of Hematopathology

Director, Hematology and Flow Cytometry Laboratories

Associate Director, Molecular Diagnostics

Loyola University Chicago Stritch School of Medicine

Maywood, IL

Mitchell Scott, Ph.D.

Professor of Pathology and Immunology

Co-Medical Director, Clinical Chemistry

Division of Laboratory and Genomic Medicine

St. Louis, MO

Jay B. Wish, M.D.

Professor of Medicine

Case Western Reserve

University School of Medicine

Medical Director, Dialysis Program

University Hospitals Case Medical Center

Cleveland, OH