# Technical Expert Panel

Ali K. Abu-Alfa M.D., FASN

Professor of Medicine

Head, Division of Nephrology and Hypertension

American University of Beirut

Beirut-Lebanon

and

Adjunct Faculty

Section of Nephrology

Yale School of Medicine

New Haven, CT

Meredith Atkinson, M.D., M.H.S.

Assistant Professor of Pediatrics

Division of Pediatric Nephrology

John Hopkins University School of Medicine

Baltimore, MD

Jeffrey S. Berns, M.D.

Associate Dean for Graduate Medical Education

Professor of Medicine and Pediatrics

Renal-Electrolyte and Hypertension Division

Hospital of the University of Pennsylvania

Philadelphia, PA

Jay B. Wish, M.D.

Professor of Medicine

Case Western Reserve

University School of Medicine

Medical Director, Dialysis Program

University Hospitals Case Medical Center

Cleveland, OH