# Key Informants

James Adamson, M.D., FACP, FCCP

Senior Vice President and Medical Officer for National Accounts

Arkansas Blue Cross Blue Shield (BCBS)

Little Rock, AR

James C. Boyd, M.D.

Associate Professor of Pathology

University of Virginia School of Medicine

Director of Clinical Pathology

Charlottesville, VA

Haewook Han, P. h.D., R.D., CSR, LDN

Renal Nutrition Specialist

Department of Nephrology,

Harvard Vanguard Medical Associate

Boston, MA

Csaba P Kovesdy, M.D.

Associate Professor of Clinical Internal Medicine

University of Virginia School of Medicine

Chief of Nephrology

Salem Veterans Affairs Medical Center

Charlottesville, VA

Kathe LeBeau

Patient Advocacy Project Manager

Renal Support Network

Albany, NY

Maureen M. Okam, M.D., M.P.H.

Associate Director, Brigham and Women’s Hospital Ambulatory Infusion Center

Brigham and Women’s Hospital

Boston, MA

James Rollins, M.D., M.S.H.A., Ph.D.

Director of Division of Items and Devices

Coverage & Analysis Group

Centers for Medicare and Medicaid (CMS)

Baltimore, MD

Deborah Van Allen R.N., M.S.

Nurse Manager

Dialysis Clinic, Inc. (DCI Boston)

Boston, MA

Jay B. Wish, M.D.

Professor of Medicine

Case Western Reserve

University School of Medicine

Medical Director, Dialysis Program

University Hospitals Case Medical Center

Cleveland, OH