# Acknowledgments

The authors would like to thank the clinical content expertise provided by Madhumathi Rao, M.D., Ph.D.