# Discussion

## Key Findings and Strength of Evidence

We did not identify any study that provided data directly addressing our overarching question regarding the impact on patient-centered outcomes (mortality, morbidity, quality of life, and adverse effects) of using newer laboratory biomarkers. In the absence of direct evidence, the overarching question could be answered by the component questions (Key Questions 2, 3, and 4). A number of studies addressing these component questions were identified. A summary of the strength of evidence addressing each Key Question is provided in Table 21.

Table 21 Summary of the strength of evidence addressing Key Questions

Key Question | Strength of Evidence | Summary, Comments, and Conclusions
Key Question 2. What is the diagnostic test accuracy of newer markers of iron status as a replacement for or an add-on to classical laboratory markers? | Low/Insufficient (depending on the test comparisons, study populations, or test performance outcomes) | - Among adult HD CKD patients, there is a low level of evidence that:; ○ Content of hemoglobin in reticulocytes (CHr) has similar or better overall test accuracy compared with TSAT or ferritin to predict a response to IV iron treatment. Data from a few studies suggest that CHr (with cutoff values of <27 or <28 pg) has better sensitivity and specificity to predict iron deficiency than classical markers (TSAT <20 or ferritin <100 ng/mL).; ○ Percent hypochromic red blood cells (%HYPO) has similar or better overall test accuracy compared with TSAT, and better overall test accuracy compared with ferritin to predict a response to IV iron treatment. Data suggest that %HYPO (with cutoff values of >6% or >10%) has a better sensitivity and specificity to predict iron deficiency (as defined by a response to IV iron treatment) than classical markers (TSAT <20% or ferritin <100 ng/mL).; ○ Soluble transferring receptor (sTfR) has a similar test performance compared with classical markers (TSAT or ferritin) to predict a response to IV iron treatment.; - There is insufficient evidence regarding:; ○ Test performance of newer markers of iron status as an add-on to older markers.; ○ Test performance comparing ZPP and hepcidin to predict a response to IV iron treatment in adult HD CKD patients.; ○ Test performance comparing newer with classical laboratory markers to predict a response to IV iron treatment, in adult PD CKD and ND CKD patients, and in pediatric CKD patients.
2a. What reference standards are used for the diagnosis of iron status in studies evaluating test accuracy? | Not rated (descriptive data) | - There is a lack of generally accepted reference standard tests for determining iron deficiency in the setting of CKD.16 This is reflected by the fact that current studies use two distinct methods to operationalize a reference standard for assessing test performance: 1) a response to intravenous (IV) iron treatment, often referred as “functional iron deficiency”; 2) classical laboratory biomarkers, alone or in combination with each other, often referred as “absolute iron deficiency.” However, across studies, there are large variations in the definitions of these reference standards.
2b. What are the adverse effects or harms associated with testing using newer and/or older markers of iron status? | Insufficient | - Only 7 of the 27 studies reported information:; ○ 3 studies reported no adverse events associated with iron therapy during the study periods.; ○ A total of 5 deaths reported. Studies did not attribute these deaths to either testing or any treatment.; ○ Most of the reported harms were attributed to iron therapy.
Key Question 3. What is the impact of managing iron status based on newer laboratory biomarkers either alone or in addition to older laboratory biomarkers on intermediate outcomes? | Low | - Two short-term RCTs (4 and 6 months) showed a reduction in the number of iron status tests and resulting intravenous iron treatments (a post-hoc intermediate outcome) administered to patients whose iron management was guided by CHr compared with those guided by TSAT or ferritin.; - Both RCTs reported that Hct remained in the targeted ranges (an indication for the adequacy of anemia management) throughout the study period in all randomized arms, although the Hct target differed between the two trials.; - One trial showed that guiding iron management via CHr resulted in similar epoetin dosing compared with iron management guided by ferritin or TSAT. In contrast, the other trial found the doses of epoetin were significantly decreased (lower by 36 percent) in the group guided by TSAT, but did not change significantly in the group guided by CHr.; - No study compared iron management guided by classical markers with that of newer markers (%HYPO, sTfR, Ret-He, ZPP, or hepcidin).
3a. What are the adverse effects or harms associated with the treatments guided by tests of iron status? | Insufficient | - Only 1 RCT explicitly monitored the adverse events:; ○ There were a total of three deaths (2 patients in the CHr group; 1 patient in the TSAT group) due to bacterial pneumonia (at week 4 in the CHr group), sudden death by unknown cause (at week 16 in the CHr group), and liver tumor (at week 7 in the TSAT group).; ○ One patient in the TSAT group dropped out because of massive bleeding due to a femoral bone fracture and need for blood transfusion.; ○ There were no significant differences in the hospitalization or infection rates of the two iron management groups.
Key Question 4. What factors affect the test performance and clinical utility of newer markers of iron status? | Insufficient | - Only single study or indirect comparisons across studies provided data on the potential impacts of some factors on the test performance of newer or classical laboratory markers of iron status:; ○ One RCT found an interaction between iron and ESA treatment on test accuracy of CHr. A higher baseline CHr predicted greater likelihood of a response to anemia and iron treatment only in the IV iron (plus epoetin) treatment group, but not in the no IV iron (epoetin only) treatment group.; ○ One study showed that the test accuracy of RetHe was lower for assessing “functional iron deficiency” (TSAT<20%, ferritin 100–800 ng/mL, and Hb <11 g/dL) than for assessing “traditional parameters for iron deficiency” (serum iron < 40 μg/dL, TSAT<20%, ferritin <100 ng/mL, and Hb <11 g/dL) in HD CKD patients.; ○ Indirect comparisons across studies suggested potential impacts of route of iron administration and treatment regimen on the test accuracy of newer and classical laboratory markers of iron status.; - No study performed analyses by patient subgroups.; - No study examined the impacts of biological variation or type of dialysis in diagnostic indices on the test performance or clinical utility of laboratory markers of iron status.

CHr=reticulocytes hemoglobin content; CKD=chronic kidney disease; Hb=hemoglobin; Hct=hematocrit; HD=hemodialysis; IV=intravenous; PD=peritoneal dialysis; RetHe=reticulocyte hemoglobin equivalent; sTfR= soluble transferrin receptor; TSAT=transferrin saturation; ZPP=erythrocyte zinc protoporphyrin

We synthesized 27 studies to answer Key Question 2 (test performance of newer markers compared with the older markers of iron status), of which 12 evaluated the test performance of newer or classical laboratory markers of iron status in predicting a response to intravenous iron treatment. Most studies enrolled only adult HD CKD patients, though a few examined adult PD and ND CKD patients. Only one study enrolled pediatric CKD patients. Although the reviewed studies evaluated many newer markers, such as CHr, %HYPO, RetHe, sTfR, hepcidin, and ZPP, the majority assessed CHr or %HYPO among adult HD CKD patients.

Based on our analysis, we concluded that there is a low level of evidence that both CHr and %HYPO have a similar or better overall test accuracy compared with classical markers (TSAT or ferritin) to predict a response to IV iron treatment (as the reference standard for iron deficiency). In addition, data suggest that CHr (with cutoff values of <27 or <28 pg) and %HYPO (with cutoof values of >6% or >10%) have better sensitivities and specificities to predict “functional” iron deficiency than classical markers (TSAT <20 or ferritin <100 ng/mL). Across studies, there exists a high degree of heterogeneity in the test comparisons, definitions for the reference standard (a response to IV iron treatment), iron status of the study populations (assessed by TSAT or ferritin), and background treatment across studies. This heterogeneity may limit the comparability of findings across studies.

A response to IV iron treatment is considered by many clinicians as the reference method for diagnosing iron deficiency. The most commonly used definition for a response to IV iron treatment was an increase in hemoglobin (Hb) concentration ≥1 g/dL; however, a consensus does not yet exist. We found no uniform regimen of IV iron in terms of dosage, duration, or iron formulation across these studies. The potential effects of IV iron treatment regimen on the test performance of newer or classical laboratory markers of iron status remain unknown.

For Key Question 3 (the impact of managing iron status based on newer laboratory biomarkers, either alone or in addition to older laboratory biomarkers, on intermediate outcomes compared with managing iron status based on older laboratory biomarkers alone), we identified only two short-term RCTs (4 and 6 months), enrolling a total of 354 adult HD CKD patients. Although both (one conducted in the U.S. and one in Japan) compared intermediate outcomes of iron management guided by CHr with those of iron management guided by classical markers of iron status (TSAT and/or ferritin), the two RCTs employed different protocols for initiating intravenous iron therapy and anemia management, which affect the applicability of their findings.

We concluded that there is a low level of evidence for a reduction in the number of iron status tests and resulting intravenous iron treatments (a post-hoc intermediate outcome) administered to patients whose iron management was guided by CHr compared with those guided by TSAT or ferritin. Both RCTs reported that Hct remained in the targeted ranges (an indication for the adequacy of anemia management) throughout the study period in all randomized arms, though the Hct target was higher in the U.S. trial than the Japanese trial. Only the Japanese trial specifically monitored the adverse events associated with study medication; no differences in the hospitalization or infection rates between the two iron management groups were reported.

For Key Question 4 (factors affecting the performance or clinical utility of newer markers of iron status), we included three studies (1 RCT and 2 prospective cohorts) as well as relevant data from all 27 studies included in Key Questions 2. Nevertheless, we found insufficient evidence to draw any conclusions, as only single studies or indirect comparisons across studies provided data on the potential impacts of some factors (i.e., interactions between iron and ESA treatment, route of iron administration, and treatment regimen) on the test performance of newer or classical laboratory markers of iron status.

### Findings in Relationship to What Is Already Known

Our findings are consistent with the recommendations in the Kidney Disease Outcome Quality Initiative (KDOQI) and the National Institute for Health and Clinical Excellence (NICE) guidelines for anemia management in CKD.5,16 The guidelines recommend that the initial assessment of iron deficiency anemia include ferritin to assess iron stores, and serum TSAT or CHr (KDOQI) or %HYPO (NICE) to assess adequacy of iron for erythropoiesis.5,16 We found that there is a low level of evidence that both CHr and %HYPO have a similar or better overall test accuracy compared with classical markers (TSAT or ferritin) to predict a response to IV iron treatment among HD CKD patients. In addition, data suggest that CHr (with cutoff values of <27 or <28 pg) and %HYPO (with cutoff values of >6% or >10%) have better sensitivities and specificities to predict “functional” iron deficiency than classical markers (TSAT <20% or ferritin <100 ng/mL). Together, these findings suggest that CHr or %HYPO can be used to monitor iron deficiency in placement of the classical markers among HD CKD patients receiving erythropoietin.

Our confidence in the totality of evidence, however, was limited by a high degree of heterogeneity and the large potential risk of bias in the body of literature (see “Limitation of the Evidence Base” for more details). Many important questions remain unanswered, such as the test performance of newer markers of iron status as an add-on to older markers, and the factors that might affect the test performance or clinical utility of laboratory markers of iron status.

We identified one study showing an improvement in test performance by using a combination of laboratory biomarkers, such as % HYPO >6 with TSAT≤20%, %HYPO >6% with CHr ≤29 pg, and % HYPO >6 with ZPP >52 μmol/mol.61 However, there are potentially endless test combinations to be evaluated, and without a widely accepted definition of reference standard for the diagnosis of iron deficiency in the context of CKD, new studies are unlikely to significantly contribute to what is already known, or change existing clinical practice.

### Applicability and Implications for Clinical and Policy Decisionmaking

We assessed the applicability of the included studies by organizing them according to each patient population of interest, that is, nondialysis patients with stage 3, 4, or 5 CKD, patients with CKD undergoing HD or PD, or patients with a kidney transplant. We evaluated studies of pediatric, adult, and elderly adults separately. Among all the studies included in our review, not one enrolled patients with a kidney transplant or elderly adults exclusively. Only one small study enrolled pediatric CKD patients (16 pediatric PD CKD patients and 11 pediatric HD CKD patients; both groups were analyzed separately). A majority of this review’s findings are thus applicable to only adult HD CKD patients.

The available data are limited due to a high degree of heterogeneity, and are at high risk of bias, limiting their utility in informing clinical practice. However, some clinical implications can be drawn.

We identified two RCTs that compared intermediate outcomes of iron management guided by CHr with those of iron management guided by classical markers of iron status (TSAT and/or ferritin).66,70 These two trials (one conducted in the U.S. and one in Japan) employed different protocols for initiating IV iron therapy and anemia management. Specifically, the epoetin dose adjustment schedule was more frequent in the U.S. trial (every 2 weeks)70 as compared with the Japanese trial (twice per month, 3 days after the previous HD therapy).66 The U.S. trial also used much higher doses of epoetin than the Japanese trial at baseline (12,232 vs. 4121 IU/week), and the Hct target was higher as well (between 33 and 36 percent, and 29.5 and 32.5 percent, respectively). The protocols for initiating IV iron therapy also differed between the two trials. These differences may reflect disparities in the healthcare systems of their respective countries, and should be considered as part of clinical decisionmaking.

Also worth noting is a trend in decreasing ESA doses and Hb levels in the U.S.71 This trend began after the publication of the Correction of Hemoglobin and Outcomes in Renal Insufficiency (CHOIR) study in 2006, which demonstrated increased mortality among patients treated with ESAs to higher target Hb levels.72 None of the included studies in the U.S. were conducted after 2006, which may indicate that the literature does not reflect the current paradigm of anemia management.

Considering our findings with respect to test performance of newer markers versus classical markers together, we can conclude that no single test (using either newer or classical markers) was adequate to determine iron status. Most studies did not show adequate predictive ability (defined as LR+ ≥10 and LR− ≤10) of the marker’s test result (Figures 4 and 5). Classical markers of iron status (ferritin and TSAT) are widely available but have poor sensitivity and specificity. On the other hand, although CHr and %HYPO may have better test performance, neither test is widely available. It should also be noted that test results are invalid for %HYPO when blood samples are stored, as sample storage causes RBC swelling and an incorrect estimation of hypochromic RBCs. This drawback can be prevented by assessing %HYPO immediately after the blood draw. In this context, the site of the blood draw has to be attached to the laboratory setting. This limitation should be weighed when considering the use of %HYPO for assessing iron status.

## Limitations of the Evidence Base

The available data are very limited due to a high degree of heterogeneity. Many definitions of a response to IV iron treatment as the reference standard for iron deficiency were used across studies. Moreover, there is a lack of a uniform regimen of intravenous iron treatment in terms of dosage, iron formulation, treatment frequency, and followup duration for the iron challenge test (to define a response) across studies.

Many studies included in our review were rated as being at a high risk of bias, limiting their utility in informing clinical practice. Detailed quality appraisals of the included studies are described in Appendix E. In brief, because the demographic details of study populations, including racial breakdown and comorbid conditions, were often not reported, there are potentially several types of biases in the included studies. For example, selection bias could occur if patients were not recruited consecutively. A related source of bias in this context is spectrum bias, in which the reported sensitivity and specificity may be exaggerated in populations with increased disease severity. Incorporation bias is often difficult to eliminate, because the result from the index test is used to determine who will receive iron treatment. Some measures recommended to maximize the quality of test interpretation include repeat testing, targeted followup of false positives, and blinding of the diagnosis or test group to diminish the likelihood of misclassification bias. Such safeguards, however, were not reported in the reviewed studies.

## Research Gaps

The most directly applicable study designs for clinical decisionmaking would be studies that compare two or more iron and anemia management strategies, follow the patients through decisions and treatments, and then report on patient outcomes. However, none of the comparative studies identified in this review were of such a design. In truth, it is unlikely such studies can be conducted, due to the high patient and resource requirements. Typically, the assessment of diagnostic tests typically follows the Fryback approach,73 progressing from the establishment of technical and clinical validity, to the assessment of test impact on clinicians’ diagnostic thinking and therapeutic decisionmaking, as well as clinical outcomes. Finally, a global assessment of the test from a societal perspective can be performed. Thus, we suggest that future research address the gaps that we identified for each of the component questions in this review. We also identified several cross-cutting methodological issues that affected all of the Key Questions, and that should be addressed. Ultimately, when a reference standard of iron deficiency is finally established, and test performance data are sufficient and reliable, decision analysis could be used to assess how using combinations of different markers to guide iron management strategies might influence clinical outcomes.

A summary of the research gaps we identified, as well as our suggestions for future research, are provided in Table 22.

Table 22 Research gaps and suggestions for future research

Key Question | Research Gaps | Suggestions for Future Research
Key Question 2. What is the diagnostic test accuracy of newer markers of iron status as a replacement for or an add-on to classical laboratory markers? | Insufficient evidence for the test performance of newer markers of iron status as an add-on to older markers | - It is important to use an independent reference standard when assessing the test performance. See “Cross-cutting issues” for the research gaps for establishing a reference standard for iron deficiency.
Key Question 2. What is the diagnostic test accuracy of newer markers of iron status as a replacement for or an add-on to classical laboratory markers? | Many existing studies are at a high risk of bias, limiting their utility in informing clinical practice | - General principles for the design of studies of diagnostic tests include the use of an appropriate reference standard, adequate description of the index and reference tests, blinded interpretation of test results, and independence of the index and reference standard tests.74; - Studies assessing diagnostic accuracy should instead aim to enroll patients representative of the spectrum of disease typically seen in clinical practice.; - Future studies should provide details about the study base and sampling methods.
Key Question 3. What is the impact of managing iron status based on newer laboratory biomarkers either alone or in addition to older laboratory biomarkers on intermediate outcomes? | There is no uniform iron management algorithms across studies | - Future observational studies should assess the outcomes of different iron management algorithms or test-and-treat protocols, considering differences in CKD populations, clinical settings, and potential harms or burden to the patients.; - Assessing impact of the most promising iron management algorithms on both intermediate and patient outcomes through prospective observational studies or RCTs.
Key Question 4. What factors affect the test performance and clinical utility of newer markers of iron status? | Insufficient evidence to draw conclusions regarding factors that may affect the test performance or clinical utility of laboratory markers of iron status | - Future studies are need to evaluated the following factors, suggested by the experts:; ○ Biological variation in diagnostic indices; ○ Use of different diagnostic reference standards; ○ Type of dialysis (i.e., peritoneal or hemodialysis); ○ Patient subgroups (i.e., age, sex, comorbid conditions, erythropoiesis-stimulating agent resistance, protein energy malnutrition secondary to an inflammatory state, hemoglobinopathies [e.g., thalessemia and sickle cell anemia]); ○ Route of iron administration (i.e., oral or intravenous); ○ Treatment regimen (i.e., repletion or continuous treatment); ○ Interactions between treatments (i.e., patients treated with versus without ESA, patients treated with versus without iron-replacement therapy)
Key Question 4. What factors affect the test performance and clinical utility of newer markers of iron status? | Whether test performance and clinical utility of newer or classical markers of iron status vary by different CKD populations are not known | - Almost all existing studies enrolled only single CKD population (ND, HD, or PD CKD patients). Future studies should include wider CKD populations, and plan for subgroup analyses.; - Power calculations should be performed to take into account for the planed subgroup analyses.
Cross-cutting issues (for Key Question 2, 3, and 4) | There is no reference standard for determining iron deficiency in CKD patients | - A response to IV iron treatment is considered by many clinicians as the reference method for diagnosing iron deficiency but future research is needed to establish a standardized definition for appropriate CKD populations, and a standardized testing protocol specifying the regimen of IV iron challenge in terms of dosage and iron formulation and proper duration of iron challenge testing.
Cross-cutting issues (for Key Question 2, 3, and 4) | Existing studies were underpowered leading to imprecise estimates | - Future studies should be larger, ideally designed based on power calculations, to be able to reliably detect plausible effect sizes and provide precise estimates of diagnostic accuracy.75
Cross-cutting issues (for Key Question 2, 3, and 4) | There is no decision analysis to assess how using combinations of different markers to guide iron management strategies might influence clinical outcomes | - Patient outcomes of interest are:; ○ Mortality; ○ Morbidity (e.g., cardiac or liver toxicity and infection); ○ Quality of life, measured using standardized scales, including: Kidney Disease Quality of Life (KDQOL), Health Related Quality of Life (HRQOL), Medical Outcomes Study Short Form-36 (SF-36), and Pediatric Quality of Life Inventory (PQLI); ○ Adverse effects or harms associated with testing and associated treatments (e.g., test-related anxiety, adverse events secondary to venipuncture, effects of iron overload with iron treatments, and cardiovascular complications from use of erythropoietin at higher Hb levels); - For studies assessing clinical outcomes, blinding to test results to the outcome assessors is essential to avoid bias.35,74

CKD=chronic kidney disease; HD=hemodialysis; IV=intravenous; ND=nondialysis; PD=peritoneal dialysis; RCT=randomized controlled trial

## Conclusions

Combining the evidence addressing Key Questions 2, 3, and 4, we can conclude that all currently available laboratory biomarkers of iron status (either newer or classical markers) do not have an ideal predictive ability when used singly to determine iron deficiency as defined by a response to iron challenge test. Furthermore, there is insufficient evidence to determine the test performance of the combinations of newer biomarkers, or combinations of newer and classical biomarkers, for diagnosing iron deficiency. However, it may be that CHr and %HYPO have better predictive ability for a response to IV iron treatment than classical markers (TSAT <20 or ferritin <100 ng/mL) in HD CKD patients. In addition, results from two RCTs showed a reduction in the number of iron status tests and resulting IV iron treatments administered to patients whose iron management was guided by CHr compared with those guided by TSAT or ferritin. These results suggest that CHr may reduce potential harms from IV iron treatment by lowering the frequency of iron testing, although the evidence for the potential harms associated with testing or test-associated treatment is insufficient.

Nevertheless, the strength of evidence supporting these conclusions is low and there remains considerable clinical uncertainty regarding the use of newer markers in the assessment of iron status and management of iron deficiency in stages 3–5 CKD patients (both nondialysis and dialysis). In addition, factors that may affect the test performance and clinical utility of newer laboratory markers of iron status remain largely unexamined.