# Quality Criteria and Individual Study Grades

Table E-1 Quality criteri and individual study grades for Key Question 2

Author Year PMID | Prosp (y/n/NA) | Consecutive (y/n/nd) | Eligibility Defined (y/n/nd) | Pop Defined (y/n/nd) | Recruit Defined (y/n/nd) | Verification Bias Unlikely (y/n/nd) | Test Readers Blinded (y/n/nd) | Time Interval (y/n/nd) | No Analytic Problem (y/n) | Uncertainty (y/n) | Withdrawals Explained (y/n/nd/na) | %Data Loss | Overall Risk of Bias^a^
Baldus, 1998 [9543601] | N (cross sectional) | ND | N | N | N | Y | ND | N | Y | Y | NA | 0% | HIGH
Bhandari, 1997 [9398126] | N (cross sectional) | ND | Y | N | N | Y | ND | N | Y | N | NA | 0% | HIGH
Bhandari, 1998 [9589378] | N (cross sectional) | ND | Y | N | N | Y | ND | N | Y | N | NA | 0% | HIGH
Bovy, 2007 [17237481] | Y | N | Y | Y | Y | Y | ND | Y | Y | Y | NA | 0% | MEDIUM
Brugnara, 2006 [16999719] | N (Retrospective) | N | N | N | N | Y | ND | N | Y | N | NA | 0% | HIGH
Buttarello, 2010 [20472854] | y | ND | Y | N | N | Y | ND | Y | Y | Y | Y | 14% | MEDIUM
Chuang, 2003 [12543894] | Y | ND | Y | Y | N | Y | ND | N | Unclear | Y | NA | 0% | HIGH
Cullen, 1999 [10193816] | N (cross sectional) | Y | Y | Y | Y | N | ND | N | N | N | N | 30% | HIGH
Daschner, 1999 [10543327] | N (cross sectional) | ND | N | Y | N | Y | ND | N | Y | N | NA | 0% | HIGH
Domrongkitchaiporn, 1999 [10401012] | Y | N | Y | Y | N | Y | ND | Y | Y | N | Y | 8.7% | MEDIUM
Eguchi, 2010 [20415234] | Y | ND | Y | N | N | Unclear (n analyzed is not specified) | ND | ND | N (multiple sampling from same patient) | N | N | ND | HIGH
Fishbane, 1995 [7872320] | Y | N | Y | N | N | Y | ND | Y | N (incorporation bias) | N | Y | 19% | HIGH
Fishbane, 1997 [9211366] | Y | N | Y | N | N | Y | ND | ND | Y | N | Y | 36% | HIGH
Fusaro, 2005 [15772926] | N (cross sectional) | Y | Y | Y | N | Y | ND | N | Y | Y | NA | 0% | MEDIUM
Gupta, 2003 [15025343] | ND | ND | Y | N | N | Y | ND | N | Y | N | NA | 0% | HIGH
Hukic, 2010 [21246919] | Y | N | Y | N | N | Y | ND | N | Y | Y | N | 0% | MEDIUM
Kaneko, 2003 [12631092] | Y | NA | Y | Y | Y | Y | N | Y | Y | N | Y | 8% | MEDIUM
Kim, 2008 [18190467] | N (cross sectional) | ND | Y | Y | N | Y | ND | N | Y | N | NA | 0% | MEDIUM
Matuszkiewicz-Rowinska, 2003 [14682204] | N (cross sectional) | Y | Y | Y | N | Y | ND | Y | Y | Y | NA | 0% | MEDIUM
Mitsuiki, 2003 [14586744] | N (Retrospective) | ND | Y | Y | N | Y | ND | Y | Y | Y | NA | 0% | MEDIUM
Mittman, 1997 [9398141] | Y | ND | Y | Y | N | Y | ND | Y | Y | N | N | 0% | MEDIUM
Miwa, 2010 [19624802] | N (cross sectional) | N | Y | Y | N | Y | ND | N | N (multiple sampling from same patient) | N | NA | 29% | HIGH
Silva, 1998 [9794562] | Y | N | Y | Y | N | Y | ND | Y | N (incorporation bias) | N | Y | 40% | HIGH
Tessitore, 2001 [11427634] | ND | N | Y | N | N | Y | ND | N | Y | Y | NA | 0% | HIGH
Tessitore, 2010 [20538788] | Y | ND | Y | Y | Y | Y | ND | Y | Y | Y | Y | 0% | LOW
Tsuchiya, 2003 [12608554] | N (cross sectional) | ND | Y | Y | N | Y | ND | N | Y | Y | NA | 0% | MEDIUM
Van Wyck, 2005 [16316362] | Y | Y | Y | Y | N | Y | ND | Y | N | N | Y | 14% | MEDIUM

N = No; NA = not applicable; ND = not described; Y= Yes

a Criteria derived from QUADAS 36

Table E-2 Quality criteria and individual study grades for Key Question 3

Author Year PMID | Sequence Generation [Y, N, Unclear] | Allocation Concealment [Y, N, Unclear] | Blinding of Participants, Personnel and Outcome Assessors [Y, N, Unclear] | Incomplete Outcome Data [Y, N, Unclear] | Free of Selective Outcome Reporting [Y, N, Unclear] | Overall Quality^a^
Fishbane, 2001 [11737617] | Unclear | Unclear | Y | N | N | MEDIUM
Kaneko, 2003 [12631092] | Unclear | Unclear | N | N | N | MEDIUM

KQ = Key Question; N = No; Y= Yes

a Criteria derived from Cochrane risk of bias tool for intervention studies37

Table E-3 Quality criteria and individual study grades for Key Question 4

Author Year PMID | Prosp (y/n/NA) | Consecutive (y/n/nd) | Eligibility Defined (y/n/nd) | Pop Defined (y/n/nd) | Recruit Defined (y/n/nd) | Verification Bias unlikely (y/n/nd) | Test Readers Blinded (y/n/nd) | Time Interval (y/n/nd) | No Analytic Problem (y/n) | Uncertainty (y/n) | Withdrawals Explained (y/n/nd/na) | %Data Loss | Overall Risk of Bias
Ahluwalia, 1997 [9328369] | Y | ND | Y | Y | N | Y | ND | Y | Y | N | Y | 10.8% | MEDIUM
Singh, 2007 [17396118] | Y | Y | Y | Y | Y | Y | ND | N | Y | N | N | 28% | MEDIUM

N = No; NA = not applicable; ND = not described; Y= Yes

a Criteria derived from QUADAS36