# Excluded Studies

Of the 694 articles obtained for full-text screening, 30 were included and 664 were excluded on double, independent full-text screening because they did not meet one or more of the PICO criteria for a particular key questions. The two most common reasons for rejection were: (1) no diagnostic outcomes reported (studies reported only correlations between markers or the measurements of levels of markers before and after treatment); (2) no comparative data for the outcomes of management strategies where treatment decisions were guided by test results (newer versus classical markers). The 664 excluded references are listed below, in alphabetic order of first author’s surname, along with the reason for exclusion for each.

1 [No authors listed]. Serum ferritin concentrations after intravenous iron-dextran. Lancet. 1982;1(8279):1017-8. May. 1. Not biomarkers of interest—older markers only (KQ2). [pmid: 6122828].
2 Abbas EE, Afioni N, Al WJ, Bakr MA, Dham R, Donia A, Droubi N, Khidir E, Mathew CM, Mitwali AH, Naga S, Pingle A, Rashed A, Roshdy A, Shaheen F, Shaibani B, Shaibani FM, Shaker DS, Sheiban A, Solieman M. The new rHuEPO alpha (epotin) in the management of anemia of end-stage renal disease in patients on maintenance hemodialysis. Transplant Proc. 2004;36(6):1805-11. Jul–Aug. Single arm Tx cohort (KQ3). [pmid: 15350482].
3 Acharya VN, Sinha DK, Almeida AF, Pathare AV. Effect of low dose recombinant human omega erythropoietin (rHuEPO) on anaemia in patients on hemodialysis. J Assoc Physicians India. 1995;43(8):539-42. Aug. Single arm treatment cohort and analytic validity data for older markers only. [pmid: 8772973].
4 Adachi Y, Nishio A. N-terminal pro-brain natriuretic peptide in prevalent peritoneal dialysis patients. Adv Perit Dial. 2008;24:75-8. Not a biomarker of interest (N-terminal BNP). [pmid: 18986006].
5 Agarwal AK, Silver MR, Reed JE, Dhingra RK, Liu W, Varma N, Stehman-Breen C. An open-label study of darbepoetin alfa administered once monthly for the maintenance of haemoglobin concentrations in patients with chronic kidney disease not receiving dialysis. J Intern Med. 2006;260(6):577-85. Dec. Single arm Tx cohort (KQ3). [pmid: 17116009].
6 Agarwal R, Davis JL, Hamburger RJ. A trial of two iron-dextran infusion regimens in chronic hemodialysis patients. Clin Nephrol. 2000;54(2):105-11. Aug. Only older markers studied in terms of analytic validity data. [pmid: 10968685].
7 Agarwal R, Leehey DJ, Olsen SM, Dahl NV. Proteinuria induced by parenteral iron in chronic kidney disease--a comparative randomized controlled trial. Clin J Am Soc Nephrol. 2011;6(1):114-21. Jan. Not test-directed Tx. [pmid: 20876669].
8 Agarwal R, Rizkala AR, Bastani B, Kaskas MO, Leehey DJ, Besarab A. A randomized controlled trial of oral versus intravenous iron in chronic kidney disease. Am J Nephrol. 2006;26(5):445-54. Analytic validity data only (KQ2). [pmid: 17035697].
9 Agarwal R, Vasavada N, Sachs NG, Chase S. Oxidative stress and renal injury with intravenous iron in patients with chronic kidney disease. Kidney Int. 2004;65(6):2279-89. Jun. Not test-directed Tx. [pmid: 15149341].
10 Aggarwal HK, Nand N, Singh S, Singh M, Hemant, Kaushik G. Comparison of oral versus intravenous iron therapy in predialysis patients of chronic renal failure receiving recombinant human erythropoietin. J Assoc Physicians India. 2003;51:170-4. Feb. Treatment not based on markers and anlaytic validity data for only older markers. [pmid: 12725261].
11 Aggarwal HK, Tziviskou E, Bellizzi V, Khandelwal M, Moupas L, Bargman JM, Jassal SV, Oreopoulos DG. Prolonged administration over six hours of large doses of intravenous iron saccharate (500 mg) prevents severe adverse reactions in peritoneal dialysis patients. Perit Dial Int. 2002;22(5):636-7. Sep–Oct. Treatment no based on biomarker. [pmid: 12455582].
12 Ahluwalia N, Lammi-Keefe CJ, Bendel RB, Morse EE, Beard JL, Haley NR. Iron deficiency and anemia of chronic disease in elderly women: a discriminant-analysis approach for differentiation. Am J Clin Nutr. 1995;61(3):590-6. Mar. Population group not of interest. [pmid: 7872225].
13 Ahsan N, Groff JA, Waybill MA. Efficacy of bolus intravenous iron dextran treatment in peritoneal dialysis patients receiving recombinant human erythropoietin. Adv Perit Dial. 1996;12:161-6. N<10, Single arm treatment cohort, analytic validity data for older markers only. [pmid: 8865893].
14 Ahsan N. Infusion of total dose iron versus oral iron supplementation in ambulatory peritoneal dialysis patients: a prospective, cross-over trial. Adv Perit Dial. 2000;16:80-4. Analytic validity data for only older markers studied. [pmid: 11045266].
15 Ahsan N. Intravenous infusion of total dose iron is superior to oral iron in treatment of anemia in peritoneal dialysis patients: a single center comparative study. J Am Soc Nephrol. 1998;9(4):664-8. Apr. Comparison of Different cutoffs. [pmid: 9555669].
16 Ahsan N. ITDI is the preferred treatment for iron supplementation in rHuEpo-treated anemic PD patients. Adv Perit Dial. 1998;14:228-31. Treatment based only on single marker and analytic validity data for only older markers studied. [pmid: 10649730].
17 Akcicek F, Ozkahya M, Cirit M, Ok E, Unsal A, Toz H, Celik A, Atabay G, Basci A. The efficiency of fractionated parenteral iron treatment in CAPD patients. Adv Perit Dial. 1997;13:109-12. not test-directed Tx (KQ3). [pmid: 9360661].
18 Akhmedkhanov SS, Shamov RI. Characteristics of the outcomes of different clinical forms of iron deficiency anemia and various aspects of its ambulatory treatment. [Russian]. Sov Med. 1991;(9):73-5. Article in russian; appears to be analytical validity data only; the google translate was not clear;. [pmid: 1798932].
19 Albertazzi A, Di LL, Daniele F, Battistel V, Colombi L. Efficacy and tolerability of recombinant human erythropoietin treatment in pre-dialysis patients: results of a multicenter study. Int J Artif Organs. 1998;21(1):12-8. Jan. Analytic validity data for only older markers studied. [pmid: 9554820].
20 Albitar S, Meulders Q, Hammoud H, Soutif C, Bouvier P, Pollini J. Subcutaneous versus intravenous administration of erythropoietin improves its efficiency for the treatment of anaemia in haemodialysis patients. Nephrol Dial Transplant. Suppl 6. 1995;10:40-3. Analytic validity data only for older markers. [pmid: 8524493].
21 Ali M, Rigolosi R, Fayemi AO, Braun EV, Frascino J, Singer R. Failure of serum ferritin levels to predict bone-marrow iron content after intravenous iron-dextran therapy. Lancet. 1982;1(8273):652-5. Mar. 20. Analytic validity data only for older markers. [pmid: 6121967].
22 Aljama P, Ward MK, Pierides AM, Eastham EJ, Ellis HA, Feest TG, Conceicao S, Kerr DN. Serum ferritin concentration: a reliable guide to iron overload in uremic and hemodialyzed patients. Clin Nephrol. 1978;10(3):101-4. Sep. Analytic validity data for older markers only. [pmid: 699405].
23 Allegra V, Mengozzi G, Martimbianco L, Vasile A. Long-term monitoring of iron stores in renal transplant recipients. Nephron. 1990;55(4):440-1. Not biomarkers of interest—older markers only & Analytical validity data only (KQ2). [pmid: 2392202].
24 Allegra V, Mengozzi G, Spulzaro P, Tenti M, Amendolagine F, Vasile A. Serum ferritin in subjects with chronic renal insufficiency undergoing hemodialytic treatment. [Italian]. Minerva Nefrol. 1983;30(1):33-42. Jan–Mar. Article in Italian; Not biomarkers of interest—older markers only & Analytical validity data only (KQ2). [pmid: 6843884].
25 Allegra V, Mengozzi G, Vasile A. Iron deficiency in maintenance hemodialysis patients: assessment of diagnosis criteria and of three different iron treatments. Nephron. 1991;57(2):175-82. Treatment fixed and not based on biomarker and analytic validity data for only older markers studied in terms of response or non response to treatment. [pmid: 1902285].
26 Al-Shohaib S, Shaker DS, Ghaedi BB, Alyarim M, Emara S, Behairy M. The hematopoietic effect of Epotin (recombinant human erythropoietin-alpha) on maintenance hemodialysis end-stage kidney disease patients. Transplant Proc. 2010;42(3):753-9. Apr. Single arm Tx cohort (KQ3). [pmid: 20430164].
27 Altintepe L, Kurtoglu E, Tonbul Z, Yeksan M, Yildiz A, Turk S. Lower erythropoietin and iron supplementation are required in hemodialysis patients with hepatitis C virus infection. Clin Nephrol. 2004;61(5):347-51. May. Analytic validity data for only older markers studied. [pmid: 15182130].
28 Alvo M, Elgueta L, Aragon H, Cotera A. Correction of anemia in hemodialysis, effect of intravenous iron without erythropoietin. [Spanish]. Rev Med Chil. 2002;130(8):865-8. Aug. Single arm treatment cohort and only one biomarker studied with no comparison. [pmid: 12360794].
29 Ammirati AL, Watanabe R, Aoqui C, Draibe SA, Carvalho AB, Abensur H, Drumond SS, Moreira J, Bevilacqua JL, Silva AC, Tatsch F, Canziani ME. Hemoglobin levels in hemodialysis patients treated with epoetin: a Brazilian experience. [Portuguese]. Rev Assoc Med Bras. 2010;56(2):209-13. Mar–Apr. Single arm Tx cohort (KQ3); Portugese article. [pmid: 20498997].
30 Amon O, Altrogge H, Kemper M, Strehlau J, Muller-Wiefel DE. Increased need of erythropoietin during peritonitis in children on continuous peritoneal dialysis. Adv Perit Dial. 1994;10:318-20. Only one biomarker of interest studied in terms of change in mean value after treatment. [pmid: 7999857].
31 Anastassiades EG, Howarth D, Howarth J, Shanks D, Waters HM, Hyde K, Geary CG, Yin JA, Gokal R. Monitoring of iron requirements in renal patients on erythropoietin. Nephrol Dial Transplant. 1993;8(9):846-53. Analytic validity data for older markers only. [pmid: 8255518].
32 Andre JL, Deschenes G, Boudailliez B, Broux F, Fischbach M, Gagnadoux MF, Horen B, Lahoche-Manucci A, Macher MA, Roussel B, Tsimaratos M, Loirat C. Darbepoetin, effective treatment of anaemia in paediatric patients with chronic renal failure. Pediatr Nephrol. 2007;22(5):708-14. May. Single arm Tx cohorts (KQ3). [pmid: 17216497].
33 Anirban G, Kohli HS, Jha V, Gupta KL, Sakhuja V. The comparative safety of various intravenous iron preparations in chronic kidney disease patients. Ren Fail. 2008;30(6):629-38. Not test-directed treatment, Tx was fixed. [pmid: 18661414].
34 Anker SD, Colet JC, Filippatos G, Willenheimer R, Dickstein K, Drexler H, Luscher TF, Mori C, von Eisenhart RB, Pocock S, Poole-Wilson PA, Ponikowski P. FAIR-HF committees and investigators. Rationale and design of Ferinject assessment in patients with IRon deficiency and chronic Heart Failure (FAIR-HF) study: a randomized, placebo-controlled study of intravenous iron supplementation in patients with and without anaemia. Eur J Heart Fail. 2009;11(11):1084-91. Nov. Not CKD patients. [pmid: 19875408].
35 Anraku M, Kitamura K, Shintomo R, Takeuchi K, Ikeda H, Nagano J, Ko T, Mera K, Tomita K, Otagiri M. Effect of intravenous iron administration frequency on AOPP and inflammatory biomarkers in chronic hemodialysis patients: a pilot study. Clin Biochem. 2008;41(14–15):1168-74. Oct. Not test-directed treatment, Tx was fixed. [pmid: 18692036].
36 Antonov S, T’rkolev N, Chal’kova G, Kuleva V. Study of iron depot in patients on periodic hemodialysis by determination of serum ferritin. [Bulgarian]. Vutr Boles. 1982;21(5):34-42. Article in Bulgarian; Not biomarkers of interest—older markers only (KQ2). [pmid: 7164404].
37 Anuradha S, Singh NP, Agarwal SK. Total dose infusion iron dextran therapy in predialysis chronic renal failure patients. Ren Fail. 2002;24(3):307-13. May. Single arm Tx cohort (KQ3); no Dx information. [pmid: 12166697].
38 Arabul M, Gullulu M, Yilmaz Y, Eren MA, Baran B, Gul CB, Kocamaz G, Dilek K. Influence of erythropoietin therapy on serum prohepcidin levels in dialysis patients. Med Sci Monit. 2009;15(11):CR583-7. Nov. Analytic validity data only. [pmid: 19865058].
39 Arndt U, Kaltwasser JP, Gottschalk R, Hoelzer D, Moller B. Correction of iron-deficient erythropoiesis in the treatment of anemia of chronic disease with recombinant human erythropoietin. Ann Hematol. 2005;84(3):159-66. Mar. Non CKD-patients. [pmid: 15565327].
40 Asanuma M, Taguchi C, Uesaka H, Kumagai T, Seino K, Hosokawa H, Yamauchi F, Fujishima M, Murai K, Ishida Y. Discrepancy between the percentage of hypochromic erythrocytes and the reticulocyte hemoglobin content in hemodialysis patients with recombinant human erythropoietin therapy. Lab Hematol. 2005;11(2):124-30. Sample size <10. [pmid: 16024336].
41 Ashby DR, Gale DP, Busbridge M, Murphy KG, Duncan ND, Cairns TD, Taube DH, Bloom SR, Tam FW, Chapman RS, Maxwell PH, Choi P. Plasma hepcidin levels are elevated but responsive to erythropoietin therapy in renal disease. Kidney Int. 2009;75(9):976-81. May. Analytic validity data only (for KQ2). [pmid: 19212416].
42 Aucella F, Vigilante M, Scalzulli P, Musto P, Prencipe M, Valente GL, Carotenuto M, Stallone C. Synergistic effect of desferrioxamine and recombinant erythropoietin on erythroid precursor proliferation in chronic renal failure. Nephrol Dial Transplant. 1999;14(5):1171-5. May. Single arm Tx cohort (KQ3). [pmid: 10344357].
43 Auerbach M, Winchester J, Wahab A, Richards K, McGinley M, Hall F, Anderson J, Briefel G. A randomized trial of three iron dextran infusion methods for anemia in EPO-treated dialysis patients. Am J Kidney Dis. 1998;31(1):81-6. Jan. No comparison between biomarkers and treatment is fixed. [pmid: 9428456].
44 Aviles B, Coronel F, Perez-Garcia R, Marcelli D, Orlandini G, Ayala JA, Rentero R. Anemia management in haemodialysis. EuCliD database in Spain. [Spanish]. Nefrologia. 2002;22(6):555-63. Treatment not based on markers and only one biomarker studied with no comparison. [pmid: 12516289].
45 Baiardi P, Piazza V, Montagna G, Mazzoleni MC. Use of statistical classifiers as support tools for the diagnosis of iron-deficiency anemia in patients on chronic hemodialysis. Stud Health Technol Inform. 1997;43 Pt B:666-70. sensitivity and specificity comparison only between older markers. [pmid: 10179750].
46 Bailie GR, Frankenfield DL, Prowant BF, McClellan W, Rocco MV. Erythropoietin and iron use in peritoneal dialysis patients. Report from the 1997 HCFA end-stage renal disease core indicators project. Am J Kidney Dis. 1999;33(6):1187-9. Jun. Single arm Tx cohort (KQ3). [pmid: 10352214].
47 Bailie GR, Plitnick R, Eisele G, Clement C, Rasmussen R. Experience with subcutaneous erythropoietin in CAPD patients. Adv Perit Dial. 1991;7:292-5. Single arm treatment cohort and analytic validity data for older markers only. [pmid: 1680449].
48 Baillie FJ, Morrison AE, Fergus I. Soluble transferrin receptor: a discriminating assay for iron deficiency. Clin Lab Haematol. 2003;25(6):353-7. Dec. <10 pts with CKD in ACD group. [pmid: 14641138].
49 Baker LR, Cattell WR, Child JA, Savdie E. Iron therapy in maintenance haemodialysis. Clin Sci Mol Med Suppl. 1975;48(6):529-32. Jun. Single marker studied and treatment is not based on marker. [pmid: 1056283].
50 Bakkaloglu SA, Ekim M, Tumer N, Akar N, Uysal Z. Soluble transferrin receptor is not a reliable marker of iron deficiency in pediatric CAPD patients. Perit Dial Int. 2002;22(5):621-5. Sep–Oct. Only Analytic validity data (KQ2). [pmid: 12455576].
51 Baldus M, Salopek S, Moller M, Schliesser J, Klooker P, Reddig J, Gansert U, Brass H. Experience with zinc protoporphyrin as a marker of endogenous iron availability in chronic haemodialysis patients. Nephrol Dial Transplant. 1996;11(3):486-91. Mar. Analytic validity data only (KQ2). [pmid: 8710158].
52 Barosi G, Merlo C, Palestra P, Liberato NL, Guarnone R, Di DF, Piazza V, Salvadeo A. Variations in erythropoiesis and serum ferritin during erythropoietin therapy for anaemia of end-stage renal disease. Acta Haematol. 1993;90(1):13-8. Analytic validity data only (KQ2). [pmid: 8237268].
53 Barraclough KA, Noble E, Leary D, Brown F, Hawley CM, Campbell SB, Isbel NM, Mudge DW, van Eps CL, Sturtevant JM, Johnson DW. Rationale and design of the oral HEMe iron polypeptide Against Treatment with Oral Controlled Release Iron Tablets trial for the correction of anaemia in peritoneal dialysis patients (HEMATOCRIT trial). BMC Nephrol. 2009;10:20. Not test-directed treatment, Tx was fixed. [pmid: 19635169].
54 Barrios Y, Espinoza M, Baron MA. Pro-hepcidin, its relation with indicators of iron metabolism and of inflammation in patients hemodialyzed treated or not with recombinant erythropoietin. [Spanish]. Nutr Hosp. 2010;25(4):555-60. Jul–Aug. Analytic validity data only (for KQ2). [pmid: 20694291].
55 Barton JC, Barton EH, Bertoli LF, Gothard CH, Sherrer JS. Intravenous iron dextran therapy in patients with iron deficiency and normal renal function who failed to respond to or did not tolerate oral iron supplementation. Am J Med. 2000;109(1):27-32. Jul. Non CKD patients. [pmid: 10936475].
56 Bastani B, Jain A, Pandurangan G. Incidence of side-effects associated with high-dose ferric gluconate in patients with severe chronic renal failure. Nephrology. 2003;8(1):8-10. Feb. Single arm Tx cohort (KQ3). [pmid: 15012743].
57 Beallo R, Dallman PR, Schoenfeld PY, Humphreys MH. Serum ferritin and iron deficiency in patients on chronic hemodialysis. Trans Am Soc Artif Intern Organs. 1976;22:73-9. Only older markers studied. [pmid: 951893].
58 Bedani PL, Cecchetti E, Gilli P. Effectiveness of subcutaneous low-dose erythropoietin in patients with chronic renal failure despite functional iron deficiency. Nephron. 1995;71(4):459-60. Population <10 and analytic validity data for older markers only. [pmid: 8587628].
59 Beerenhout C, Bekers O, Kooman JP, Van der Sande FM, Leunissen KM. A comparison between the soluble transferrin receptor, transferrin saturation and serum ferritin as markers of iron state in hemodialysis patients. Nephron. 2002;92(1):32-5. Sep. Analytic validity data only (KQ2). [pmid: 12187081].
60 Beguin Y, Loo M, R’Zik S, Sautois B, Lejeune F, Rorive G, Fillet G. Early prediction of response to recombinant human erythropoietin in patients with the anemia of renal failure by serum transferrin receptor and fibrinogen. Blood. 1993;82(7):2010-6. Oct. 1. Analytic validity data only (KQ2). [pmid: 8400253].
61 Beguin Y, Loo M, R’Zik S, Sautois B, Lejeune F, Rorive G, Fillet G. Quantitative assessment of erythropoiesis in haemodialysis patients demonstrates gradual expansion of erythroblasts during constant treatment with recombinant human erythropoietin. Br J Haematol. 1995;89(1):17-23. Jan. Analytic validity data only (KQ2). [pmid: 7833259].
62 Bell JD, Kincaid WR, Morgan RG, Bunce H, Alperin JB, Sarles HE, Remmers AR. Serum ferritin assay and bone-marrow iron stores in patients on maintenance hemodialysis. Kidney Int. 1980;17(2):237-41. Feb. Not a biomarker of inoterest (KQ2)—only older biomarkers evaluated. [pmid: 7382271].
63 Bergmann M, Grutzmacher P, Heuser J, Kaltwasser JP. Iron metabolism under rEPO therapy in patients on maintenance hemodialysis. Int J Artif Organs. 1990;13(2):109-12. Feb. Analytic validity data only for older markers. [pmid: 2347653].
64 Besarab A, Amin N, Ahsan M, Vogel SE, Zazuwa G, Frinak S, Zazra JJ, Anandan JV, Gupta A. Optimization of epoetin therapy with intravenous iron therapy in hemodialysis patients. J Am Soc Nephrol. 2000;11(3):530-8. Mar. Comparison of Different cutoffs. [pmid: 10703677].
65 Besarab A, Kaiser JW, Frinak S. A study of parenteral iron regimens in hemodialysis patients. Am J Kidney Dis. 1999;34(1):21-8. Jul. Analytic validity data only (for KQ2); No test-directed Tx (KQ3). [pmid: 10401011].
66 Beshara S, Barany P, Gutierrez A, Wikstrom B. Swedish Investigators Group. Varying intervals of subcutaneous epoetin alfa in hemodialysis patients. JN, J. nephrol. 2004;17(4):525-30. Jul–Aug. Analytic validty data only for older markers. [pmid: 15372414].
67 Bezwoda WR, Derman DP, Bothwell TH, MacPhail AP, Torrance JD, Milne FJ, Meyers AM, Levin J. Iron absorption in patients on regular dialysis therapy. Nephron. 1981;28(6):289-93. Not biomarkers of interest—older markers only & Analytical validity data only (KQ2). [pmid: 7312083].
68 Bhandari S, Brownjohn A, Turney J. Effective utilization of erythropoietin with intravenous iron therapy. J Clin Pharm Ther. 1998;23(1):73-8. Feb. Single arm Tx cohort (KQ3). [pmid: 9756115].
69 Bhandari S, Brownjohn AM, Turney JH. Response of mean reticulocyte haemoglobin content to intravenous iron therapy in haemodialysis patients. Nephrol Dial Transplant. 1998;13(12):3276-7. Dec. Single arm study with same treatment provision. Analytic validity data only (KQ2). [pmid: 9870516].
70 Bhandari S, Owda AK, Kendall RG, Moran N, Norfolk DR, Brownjohn AM, Turney JH. Red cell ferritin, a marker of iron deficiency in hemodialysis patients. Ren Fail. 1997;19(6):771-80. Nov. Not a biomarker of inoterest (KQ2)—red cell ferritin is not of inoterest. [pmid: 9415934].
71 Bhowmik D, Modi G, Ray D, Gupta S, Agarwal SK, Tiwari SC, Dash SC. Total dose iron infusion: safety and efficacy in predialysis patients. Ren Fail. 2000;22(1):39-43. Jan. Single arm Tx cohort (KQ3); No Dx information. [pmid: 10718279].
72 Bhuiyan FK, Rashid HU, Ahmed S, Alam MR. Comparative study of two different dosages of erythropoietin in respect of response to anemia in patients with ESRD on MHD Bangladesh. Renal Journal. 2004;23(2):42-51. Analytic validity data for older markers only.
73 Birgegard G, Nilsson P, Wide L. Regulation of iron therapy by S-ferritin estimations in patients on chronic hemodialysis. Scand J Urol Nephrol. 1981;15(1):69-72. Only older markers studied in terms of analytic validity. [pmid: 7244567].
74 Blaustein DA, Schwenk MH, Chattopadhyay J, Singh H, Daoui R, Gadh R, Avram MM. The safety and efficacy of an accelerated iron sucrose dosing regimen in patients with chronic kidney disease. Kidney Int Suppl. 2003;(87):S72-7. Nov. Treatment is not dependent on biomarker. Only older markers compared in terms of analytic validity. [pmid: 14531777].
75 Blumberg AB, Marti HR, Graber CG. Serum ferritin and bone marrow iron in patients undergoing continuous ambulatory peritoneal dialysis. JAMA. 1983;250(24):3317-9. Dec. 23–30. Analytic validity data for older markers only. [pmid: 6645029].
76 Bock A, Herkner KR. Reticulocyte maturity pattern analysis as a predictive marker of erythropoiesis in paediatrics. Part II: Pilot study for clinical application. Clin Lab Haematol. 1994;16(4):343-8. Dec. Population subgroup is non CKD. [pmid: 7537640].
77 Bock HA, Hirt-Minkowski P, Brunisholz M, Keusch G, Rey S, von AB. Swiss EFIXNES ti. Darbepoetin alpha in lower-than-equimolar doses maintains haemoglobin levels in stable haemodialysis patients converting from epoetin alpha/beta. Nephrol Dial Transplant. 2008;23(1):301-8. Jan. Single arm treatment cohort. Only older markers studied in terms of change in mean values. [pmid: 17890745].
78 Bolanos L, Castro P, Falcon TG, Mouzo R, Varela JM. Continuous intravenous sodium ferric gluconate improves efficacy in the maintenance phase of EPOrHu administration in hemodialysis patients. Am J Nephrol. 2002;22(1):67-72. Jan–Feb. Analytic validity data only (KQ2). [pmid: 11919405].
79 Bolignano D, Coppolino G, Romeo A, De PL, Buemi A, Lacquaniti A, Nicocia G, Lombardi L, Buemi M. Neutrophil gelatinase-associated lipocalin (NGAL) reflects iron status in haemodialysis patients. Nephrol Dial Transplant. 2009;24(11):3398-403. Nov. Not a biomarker of interest. [pmid: 19549696].
80 Bommer J, Samtleben W, Koch KM, Baldamus CA, Grutzmacher P, Scigalla P. Variations of recombinant human erythropoietin application in hemodialysis patients. Contrib Nephrol. discussion 156–8. 1989;76:149-56. Single arm treatment cohort. Treatment not based on any biomarker. [pmid: 2684517].
81 Borawski J, Mazerska M, Pawlak K, Mysliwiec M. Ketanserin lowers erythropoietin concentration in hemodialyzed patients treated with the hormone. J Cardiovasc Pharmacol. 1995;26(4):621-6. Oct. Not test-directed Tx; No Dx information. [pmid: 8569225].
82 Bosticardo GM, Arnoletti F, Dapiran D, Zola P, Maneglia M, Avalle U, Giacchino F. Assessment of reticulocyte hemoglobin content as a guide for iron supplementation in hemodialyzed patients. [Italian]. Minerva Urol Nefrol. 2000;52(3):143-5. Sep. Analytic validity data only (KQ2). [pmid: 11227365].
83 Bovy C, Krzesinski JM, Gothot A, Beguin Y. Impact of erythropoietic activity on red cell parameters in chronic renal failure patients. Haematologica. 2004;89(6):748-9. Jun. N<10; No Dx information. [pmid: 15194543].
84 Bovy C, Tsobo C, Crapanzano L, Rorive G, Beguin Y, Albert A, Paulus JM. Factors determining the percentage of hypochromic red blood cells in hemodialysis patients. Kidney Int. 1999;56(3):1113-9. Sep. Analytic validity data only (KQ2). [pmid: 10469381].
85 Bowe D. IV iron therapy and anemia management in patients on hemodialysis: benefits of a revised CQI strategy. Nephrol Nurs J. 394. quiz 378–9. 2008;35(4):371-7. Jul–Aug. Single arm Tx cohort ; No Dx information. [pmid: 18782999].
86 Bradbury BD, Critchlow CW, Weir MR, Stewart R, Krishnan M, Hakim RH. Impact of elevated C-reactive protein levels on erythropoiesis- stimulating agent (ESA) dose and responsiveness in hemodialysis patients. Nephrol Dial Transplant. 2009;24(3):919-25. Mar. No Dx information; Not a biomarker of interest. [pmid: 18840893].
87 Bradbury BD, Danese MD, Gleeson M, Critchlow CW. Effect of Epoetin alfa dose changes on hemoglobin and mortality in hemodialysis patients with hemoglobin levels persistently below 11 g/dL. Clin J Am Soc Nephrol. 2009;4(3):630-7. Mar. Not test-directed treatment, Tx was fixed. [pmid: 19261826].
88 Bratescu LO, Barsan L, Munteanu D, Stancu S, Mircescu G. Is hepcidin-25 a clinically relevant parameter for the iron status in hemodialysis patients?. J Ren Nutr. 5 Suppl. 2010;20:S77-83. Sep. Analytic validity data only (for KQ2). [pmid: 20797577].
89 Braun J, Hammerschmidt M, Schreiber M, Heidler R, Horl WH. Is zinc protoporphyrin an indicator of iron-deficient erythropoiesis in maintenance haemodialysis patients?. Nephrol Dial Transplant. 1996;11(3):492-7. Mar. Analytic validity data only (KQ2). [pmid: 8671820].
90 Braun J, Lindner K, Schreiber M, Heidler RA, Horl WH. Percentage of hypochromic red blood cells as predictor of erythropoietic and iron response after i.v. iron supplementation in maintenance haemodialysis patients. Nephrol Dial Transplant. 1997;12(6):1173-81. Jun. Single arm study. [pmid: 9198047].
91 Bren A, Arnol M, Kandus A, Varl J, Oblak M, Lindic J, Pajek J, Knap B, Kovac D, Mlinsek G, Buturovic-Ponikvar J. Treatment of anemia with epoetin in kidney transplant recipients. Therap Apher Dial. 2011;15(3):257-60. Jun. Single arm Tx cohort (KQ3); no Dx information. [pmid: 21624072].
92 Brimble KS, Rabbat CG, McKenna P, Lambert K, Carlisle EJ. Protocolized anemia management with erythropoietin in hemodialysis patients: a randomized controlled trial. J Am Soc Nephrol. 2003;14(10):2654-61. Oct. Even though it is test-directed Tx, the tests used to direct Tx are the same in both arms. [pmid: 14514745].
93 Brown RD, Benfatto J, Gibson J, Kronenberg H. Red cell ferritin and iron stores in patients with chronic disease. Eur J Haematol. 1988;40(2):136-41. Feb. Non CKD population. [pmid: 3345827].
94 Brozovich B, Cattell WR, Cottrall MF, Gwyther MM, McMillan JM, Malpas JS, Salsbury A, Trott NG. Iron metabolism in patients undergoing regular dialysis therapy. Br Med J. 1971;1(5751):695-8. Mar. 27. Not a biomarker of inoterest (KQ2)—only older biomarkers evaluated. [pmid: 5551242].
95 Brunati C, Piperno A, Guastoni C, Perrino ML, Civati G, Teatini U, Perego A, Fiorelli G, Minetti L. Erythrocyte ferritin in patients on chronic hemodialysis treatment. Nephron. 1990;54(3):219-23. Not biomarkers of interest—older markers only & Analytical validity data only (KQ2). [pmid: 2314539].
96 bska-Slizien A, Rutkowski B, Niemierko J, Jankowska-Gan E, Golebiewska-Zurkowska G, Kabata J, Manitius A. Subcutaneous administration of recombinant human erythropoietin (R-EPO) in the treatment of anemia in predialysis patients with chronic renal failure. [Polish]. Pol Arch Med Wewn. 1991;85(6):334-40. Jun. Analytical validity data only (KQ2). [pmid: 1896396].
97 Busbridge M, Griffiths C, Ashby D, Gale D, Jayantha A, Sanwaiya A, Chapman RS. Development of a novel immunoassay for the iron regulatory peptide hepcidin. Br J Biomed Sci. 2009;66(3):150-7. Not a diagnostic study. [pmid: 19839227].
98 Bush B. IV iron administration in a peritoneal dialysis clinic. Nephrol Nurs J. 2004;31(4):447-8. Jul–Aug. Q&A article about IV iron in PD pts. [pmid: 15453239].
99 Campos A, Garin EH. Therapy of renal anemia in children and adolescents with recombinant human erythropoietin (rHuEPO). Clin Pediatr (Phila). 1992;31(2):94-9. Feb. No comparison between biomarkers. Sibgle arm treatment cohort. [pmid: 1544282].
100 Canavese C, Bergamo D, Ciccone G, Burdese M, Maddalena E, Barbieri S, Thea A, Fop F. Low-dose continuous iron therapy leads to a positive iron balance and decreased serum transferrin levels in chronic haemodialysis patients. Nephrol Dial Transplant. 2004;19(6):1564-70. Jun. Single arm Tx cohorts. [pmid: 15004263].
101 Canavese C, Bergamo D, Ciccone G, Longo F, Fop F, Thea A, Martina G, Piga A. Validation of serum ferritin values by magnetic susceptometry in predicting iron overload in dialysis patients. Kidney Int. 2004;65(3):1091-8. Mar. SQUID is used as a gold standard versus Ferritin; used in evaluating hepatic iron excess not iron deficiency (KQ2). [pmid: 14871430].
102 Canavese C, Grill A, Decostanzi E, Maddalena E, Barbieri S, Martina G, Fop F, Buglione E, Grechi D, David O, Saitta M, Piccoli G. Limited value of zinc protoporphyrin as a marker of iron status in chronic hemodialysis patients. Clin Nephrol. 2000;53(1):42-7. Jan. Analytic validity data (KQ2). [pmid: 10661481].
103 Cantaro S, Piva E. Hematological and iron parameters to predict mortality in ESRD. [Italian]. G. ITAL. NEFROL. Suppl 31. 2005;22:S135-9. Jan–Feb. Single arm Tx cohort (KQ3); no Dx information. [pmid: 15786388].
104 Caramelo C, Soto C, Neira F, Lopez MD, Jimenez S, Albalate M, de OR, Llamas P, Deudero JJ. Reticulocyte response after immediate withdrawal of recombinant human erythropoietin in chronic hemodialysis patients. [Spanish]. Nefrologia. 2004;24(4):351-6. single arm, fixed treatment. [pmid: 15455495].
105 Caravaca F, Vagace JM, Aparicio A, Groiss J, Pizarro JL, Alonso N, Garcia MC, Arrobas M, Cubero J, Esparrago J. Assessment of iron status by erythrocyte ferritin in uremic patients with or without recombinant human erythropoietin therapy. Am J Kidney Dis. 1992;20(3):249-54. Sep. Sensitivity comparison of older and newer biomarker which is not enlisted in the protocol. Rest analytic validity data only (KQ2). Newer marker erythrocyte ferritin. [pmid: 1519605].
106 Carrera F, Lok CE, de FA, Locatelli F, Mann JF, Canaud B, Kerr PG, Macdougall IC, Besarab A, Villa G, Kazes I, Van VB, Jolly S, Beyer U, Dougherty FC. PATRONUS I. Maintenance treatment of renal anaemia in haemodialysis patients with methoxy polyethylene glycol-epoetin beta versus darbepoetin alfa administered monthly: a randomized comparative trial. Nephrol Dial Transplant. 2010;25(12):4009-17. Dec. Not test-directed treatment, Tx was fixed. [pmid: 20522670].
107 Carter RA, Hawkins JB, Robinson BH. Iron metabolism in the anaemia of chronic renal failure. Effects of dialysis and of parenteral iron. Br Med J. 1969;3(5664):206-10. Jul. 26. Not a biomarker of interest; Single arm Tx cohort (KQ3). [pmid: 5792610].
108 Caruso U. Effects of L-carnitine on anemia in aged hemodialysis patients treated with recombinant human erythropoietin: A pilot study Dialysis and Transplantation. 1998;27(8):498-506. Not an intervention of interest- N-carnitine.
109 Cavill I. Iron status as measured by serum ferritin: the marker and its limitations. Am J Kidney Dis. Suppl 2. 1999;34(4):S12-7. Oct. Narrative review. [pmid: 10516370].
110 Celada A, Busset R, Gutierrez J, Martinez JL, Herreros V. Comparative study of transferrin measurement and total iron binding capacity (author’s transl). [Spanish]. Sangre (Barc). 1981;26(6):1073-82. Not biomarkers of interest—older markers only (KQ2). [pmid: 7342334].
111 Cermak J, Gregora E, Lachmanova J, Brabec V. Iron stores in patients with chronic kidney failure treated with recombinant human erythropoietin. [Czech]. Vnitr Lek. 1994;40(3):174-8. Mar. N<10. [pmid: 8184571].
112 Chandler G, Harchowal J, Macdougall IC. Intravenous iron sucrose: establishing a safe dose. Am J Kidney Dis. 2001;38(5):988-91. Nov. Only one biomarker studied. [pmid: 11684551].
113 Chang CH, Chang CC, Chiang SS. Reduction in erythropoietin doses by the use of chronic intravenous iron supplementation in iron-replete hemodialysis patients. Clin Nephrol. 2002;57(2):136-41. Feb. Only older markers compared in terms of analytic validity. [pmid: 11863124].
114 Chang J, Bird R, Clague A, Carter A. Clinical utility of serum soluble transferrin receptor levels and comparison with bone marrow iron stores as an index for iron-deficient erythropoiesis in a heterogeneous group of patients. Pathology. 2007;39(3):349-53. Jun. Non-CKD patienots. [pmid: 17558864].
115 Charytan C, Goldfarb-Rumyantzev A, Wang YF, Schwenk MH, Spinowitz BS. Effect of angiotensin-converting enzyme inhibitors on response to erythropoietin therapy in chronic dialysis patients. Am J Nephrol. 1998;18(6):498-503. Only older markers studied in terms of mean values across 2 treatment groups. [pmid: 9845824].
116 Charytan C, Levin N, Al-Saloum M, Hafeez T, Gagnon S, Van Wyck DB. Efficacy and safety of iron sucrose for iron deficiency in patients with dialysis-associated anemia: North American clinical trial. Am J Kidney Dis. 2001;37(2):300-7. Feb. Dx information for older markers only; Single arm Tx cohort (KQ3). [pmid: 11157370].
117 Charytan C, Qunibi W, Bailie GR. Venofer Clinical Studies Group. Comparison of intravenous iron sucrose to oral iron in the treatment of anemic patients with chronic kidney disease not on dialysis. Nephron. 2005;100(3):c55-62. Treatment not based on markers and analytic validity data for only older studied. [pmid: 15824508].
118 Chen YC, Hung SC, Tarng DC. Association between transferrin receptor-ferritin index and conventional measures of iron responsiveness in hemodialysis patients. Am J Kidney Dis. 2006;47(6):1036-44. Jun. TfR-ferritin Index is a combination of a new and old marker. [pmid: 16731299].
119 Chiang WC, Tsai TJ, Chen YM, Lin SL, Hsieh BS. Serum soluble transferrin receptor reflects erythropoiesis but not iron availability in erythropoietin-treated chronic hemodialysis patients. Clin Nephrol. 2002;58(5):363-9. Nov. Analytic validity data only (KQ2). [pmid: 12425487].
120 Chinnappa S, Bhandari S. Influence of intravenous iron therapy on novel markers of iron deficiency. Int J Artif Organs. 2010;33(5):297-301. May. Anlytic validity looked at for KQ2. [pmid: 20593351].
121 Choi JW. Combination index of soluble transferrin receptor and mean corpuscular hemoglobin for evaluating iron deficiency in end-stage renal disease. Ann Hematol. 2007;86(1):75-7. Jan. TfR-ferritin Index is a combination of a new and old marker. [pmid: 17013644].
122 Choi JW. Combination of serum transferrin receptor and red cell distribution width for assessing anemia in patients with chronic diseases. Ann Clin Lab Sci. 2006;36(3):356-8. Non CKD-patients. [pmid: 16951280].
123 Choukroun G, Deray G, Glotz D, Lebranchu Y, Dussol B, Bourbigot B, Lefrancois N, Cassuto-Viguier E, Toupance O, Hacen C, Lang P, Mazouz H, Martinez F. Incidence and management of anemia in renal transplantation: an observational-French study. [French]. Nephrol Ther. 2008;4(7):575-83. Dec. No Dx information; Single arm Tx cohort (KQ3). [pmid: 18672417].
124 Christensen DJ. Differentiation of iron deficiency and the anemia of chronic disease. J. FAM. PRACT. 1985;20(1):35-9. Jan. Non CKD population and PPV for older markers only. [pmid: 3965599].
125 Coladonato JA, Frankenfield DL, Reddan DN, Klassen PS, Szczech LA, Johnson CA, Owen WF. Trends in anemia management among US hemodialysis patients. J Am Soc Nephrol. 2002;13(5):1288-95. May. Biomarkers assesed in terms of different ranges of hematocrit values without any comparison with each other. [pmid: 11961017].
126 Corazza F, Bergmann P, Dratwa M, Guns M, Fondu P. Responsiveness to recombinant erythropoietin therapy in end-stage renal disease. An analysis of the predictive value of several biological measurements, including circulating erythroid progenitors. Nephrol Dial Transplant. 1992;7(4):311-7. Only older markers studied in terms of mean values as per response to treatment. [pmid: 1317521].
127 Costa E, Pereira BJ, Rocha-Pereira P, Rocha S, Reis F, Castro E, Teixeira F, Miranda V, do Sameiro FM, Loureiro A, Quintanilha A, Belo L, Santos-Silva A. Role of prohepcidin, inflammatory markers and iron status in resistance to rhEPO therapy in hemodialysis patients. Am J Nephrol. 2008;28(4):677-83. Analytical validity data only (KQ2). [pmid: 18354252].
128 Costa E, Swinkels DW, Laarakkers CM, Rocha-Pereira P, Rocha S, Reis F, Teixeira F, Miranda V, do Sameiro FM, Loureiro A, Quintanilha A, Belo L, Santos-Silva A. Hepcidin serum levels and resistance to recombinant human erythropoietin therapy in haemodialysis patients. Acta Haematol. 2009;122(4):226-9. Analytic validity data only (KQ2). [pmid: 19887781].
129 Covic A, Mircescu G. The safety and efficacy of intravenous ferric carboxymaltose in anaemic patients undergoing haemodialysis: a multi-centre, open-label, clinical study. Nephrol Dial Transplant. 2010;25(8):2722-30. Aug. Single arm Tx cohort (KQ3). [pmid: 20190247].
130 Coyne D. Challenging the boundaries of anemia management: a balanced approach to i.v. iron and EPO therapy. Kidney Int Suppl. 2006;(101):S1-3. May. Narrative review. [pmid: 16830698].
131 Coyne D. IV sodium ferric gluconate complex is effective in treating anemic hemodialysis patients with elevated ferritin: final results of the DRIVE Study. [abstract TH-FC043]. Journal of the American Society of Nephrology. Abstracts. 2006;17:9A.
132 Coyne DW, Kapoian T, Suki W, Singh AK, Moran JE, Dahl NV, Rizkala AR. DRIVE Study Group. Ferric gluconate is highly efficacious in anemic hemodialysis patients with high serum ferritin and low transferrin saturation: results of the Dialysis Patients’ Response to IV Iron with Elevated Ferritin (DRIVE) Study. J Am Soc Nephrol. 2007;18(3):975-84. Mar. Not test-directed Tx; Tx remained the same in both arms. [pmid: 17267740].
133 Coyne DW, Sims A, Bingel B. Results of an anemia management program to reduce high epoetin doses by targeted use of i.v. ferric gluconate. Nephrol Nurs J. 2008;35(6):583-7. Nov–Dec. Single arm Tx cohort ; No Dx information. [pmid: 19260610].
134 Crary SE, Hall K, Buchanan GR. Intravenous iron sucrose for children with iron deficiency failing to respond to oral iron therapy. Pediatr Blood Cancer. 2011;56(4):615-9. Apr. non CKD-patienots. [pmid: 21298748].
135 Dahdah K, Patrie JT, Bolton WK. Intravenous iron dextran treatment in predialysis patients with chronic renal failure. Am J Kidney Dis. 2000;36(4):775-82. Oct. Not test-directed Tx (KQ3). [pmid: 11007680].
136 Das GA, Abbi A. High serum transferrin receptor level in anemia of chronic disorders indicates coexistent iron deficiency. Am J Hematol. 2003;72(3):158-61. Mar. Population non CKD. [pmid: 12605386].
137 David O, Grillo A, Ceoloni B, Cavallo F, Podda G, Biancotti PP, Bergamo D, Canavese C. Analysis of red cell parameters on the Sysmex XE 2100 and ADVIA 120 in iron deficiency and in uraemic chronic disease. Scand J Clin Lab Invest. 2006;66(2):113-20. Analytic validity data only (for KQ2). [pmid: 16537244].
138 De FL, Olivieri O, Girelli D, Lupo A, Bernich P, Corrocher R. Red blood cell cation transports in uraemic anaemia: evidence for an increased K/Cl co-transport activity. Effects of dialysis and erythropoietin treatment. Eur J Clin Invest. 1995;25(10):762-8. Oct. No biomarker studied. [pmid: 8557063].
139 de Jong GM, Kolsters G, Offerman JJ. Erythrocyte indices during treatment with human recombinant erythropoietin in dialysis patients. Nephrol Dial Transplant. 1990;5(1):77-8. Single arm treatment cohort and only one marker studied. [pmid: 2109289].
140 de la Serna FJ, Praga M, Gilsanz F, Rodicio JL, Ruilope LM, Alcazar JM. Improvement in the erythropoiesis of chronic haemodialysis patients with desferrioxamine. Lancet. 1988;1(8593):1009-11. May. 7. N<10 in one treatment arm and analytic validity data only (KQ2). [pmid: 2896866].
141 De NL, Conte G, Chiodini P, Cianciaruso B, Pota A, Bellizzi V, Tirino G, Avino D, Catapano F, Minutolo R. Stability of target hemoglobin levels during the first year of epoetin treatment in patients with chronic kidney disease. Clin J Am Soc Nephrol. 2007;2(5):938-46. Sep. n Dx information; Single arm Tx cohort (KQ3). [pmid: 17724278].
142 de P, Ricci G, Perini L, Malacarne F, Vedovato M, Guerra G, Dapporto M, Gilli P. The determination of plasma transferrin receptor as good index of erythropoietic activity in renal anemia and after renal transplantation. Nephron. 1996;72(4):552-6. Treatment fixed and analytic validity data only for one newer marker. [pmid: 8730420].
143 De PT, Giordano M, Palumbo F, Bellantuono R, Messina G, Colella V, Caringella AD. Clinical experience with darbepoietin alfa (NESP) in children undergoing hemodialysis. Pediatr Nephrol. 2004;19(3):337-40. Mar. Single arm Tx cohorts; N<10 (KQ3). [pmid: 14745634].
144 De SG, Lameire N, Dhondt A, Van LA, Van der GJ, Duym P, Vanholder R. The haematopoietic effect of recombinant human erythropoietin in haemodialysis is independent of the mode of administration (i.v. or s.c.). Nephrol Dial Transplant. 1998;13(7):1770-5. Jul. Not test-directed Tx (KQ3). [pmid: 9681726].
145 de Vecchi AF, Novembrino C, Lonati S, Ippolito S, Bamonti F. Two different modalities of iron gluconate i.v. administration: effects on iron, oxidative and inflammatory status in peritoneal dialysis patients. Nephrol Dial Transplant. 2007;22(6):1709-13. Jun. not test-directed Tx. [pmid: 17298995].
146 Deaver K, Bennington L. Adjusting i.v. iron and EPO doses in patients on hemodialysis prior to continuing surgery: can we protect our patients education from iron-deficiency anemia?. Nephrol Nurs J. quiz 438. 2006;33(4):430-7. Jul–Aug. Narrative review. [pmid: 17002001].
147 Debska-Slizien A, Biedunkiewicz B, Rutkowski B. Effect of human recombinant erythropoietin (r-EPO) on behavior of iron status parameters in patients with chronic renal failure treated with dialysis. [Polish]. Pol Arch Med Wewn. 1994;92(3):207-15. Sep. n<10 in one arm. [pmid: 7808929].
148 Debska-Slizien A, Owczarzak A, Lysiak-Szydlowska W, Rutkowski B. Erythrocyte metabolism during renal anemia treatment with recombinant human erythropoietin. Int J Artif Organs. 2004;27(11):935-42. Nov. Analytic validity data for older markers only. [pmid: 15636050].
149 DeVita MV, Frumkin D, Mittal S, Kamran A, Fishbane S, Michelis MF. Targeting higher ferritin concentrations with intravenous iron dextran lowers erythropoietin requirement in hemodialysis patients. Clin Nephrol. 2003;60(5):335-40. Nov. Only one biomarker present. [pmid: 14640239].
150 Dimitrakov D, Kumchev E, Tllkian E. Study of the effect of recombinant erythropoietin on renal anaemia in predialysis patients with chronic renal failure. Folia Med (Plovdiv). 1994;36(3):31-6. N<10, single arm treatment cohort and analytic validity data for older markers only. [pmid: 8566900].
151 Disney A, Jersey PD, Kirkland G, Mantha M, Charlesworth JA, Gallagher M, Harris D, Gock H, Mangos GJ, Macmillan J, Liu W, Viswalingam A. Darbepoetin alfa administered monthly maintains haemoglobin concentrations in patients with chronic kidney disease not receiving dialysis: a multicentre, open-label, Australian study. Nephrology. 2007;12(1):95-101. Feb. Single arm Tx cohort (KQ3). [pmid: 17295668].
152 Dittrich E, Schillinger M, Sunder-Plassmann G, Horl WH, Vychytil A. Efficacy of a low-dose intravenous iron sucrose regimen in peritoneal dialysis patients. Perit Dial Int. 2002;22(1):60-6. Jan–Feb. n Dx information; Single arm Tx cohort (KQ3). [pmid: 11929146].
153 Donnelly SM, Ali MA, Churchill DN. Bioavailability of iron in hemodialysis patients treated with erythropoietin: evidence for the inhibitory role of aluminum. Am J Kidney Dis. 1990;16(5):447-51. Nov. Tretament is fixed and analytic validity data only (KQ2). [pmid: 2239935].
154 Donnelly SM, Posen GA, Ali MA. Oral iron absorption in hemodialysis patients treated with erythropoietin. Clin Invest Med. 1991;14(4):271-6. Aug. N<10 and analytic validity data only for older markers. [pmid: 1782724].
155 Drueke TB, Locatelli F, Clyne N, Eckardt KU, Macdougall IC, Tsakiris D, Burger HU, Scherhag A. CREATE I. Normalization of hemoglobin level in patients with chronic kidney disease and anemia. N Engl J Med. 2006;355(20):2071-84. Nov. 16. Not test-directed Tx based on our tests of interest. [pmid: 17108342].
156 Duclos J. Parenteral iron and folic acid in patients on chronic hemodialysis: requirements, monitoring, and effective use. [Spanish]. Rev Med Chil. 1991;119(7):778-84. Jul. Treatment is fixed and analytic validity data (KQ2). [pmid: 1844753].
157 Dunea G, Swagel MA, Bodiwala U, Arruda JA. Intra-dialytic oral iron therapy. Int J Artif Organs. 1994;17(5):261-4. May. Treatment not based on biomarkers. Only older markers studied in terms of analytic validity data. [pmid: 7960194].
158 Dyras P, Pietrzyk JA, Sancewicz-Pach K, Lenik J. Clinical and metabolic effects of erythropoietin administration in hemodialyzed children. [Polish]. Przegl Lek. 1996;53(11):793-6. Treatment is not based on biomarker and no biomarker comparison present. [pmid: 9173441].
159 Edwards MS, Pegrum GD, Curtis JR. Iron therapy in patients on maintenance haemodialysis. Lancet. 1970;2(7671):491-3. Sep. 5. Only one biomarker of interest studied. [pmid: 4194939].
160 Eleftheriadis T, Kartsios C, Liakopoulos V, Antoniadi G, Ditsa M, Papadopoulos C, Anifandis G, Skirta A, Markala D, Stefanidis I. Does hepcidin affect erythropoiesis in hemodialysis patients?. Acta Haematol. 2006;116(4):238-44. Marker prohepcidin is not enlisted in the protocol and rest analytic data for older markers only. [pmid: 17119323].
161 El-Khatib M, Duncan HJ, Kant KS. Role of C-reactive protein, reticulocyte haemoglobin content and inflammatory markers in iron and erythropoietin administration in dialysis patients. Nephrology. 2006;11(5):400-4. Oct. No Dx data. [pmid: 17014552].
162 Ellis D. Serum ferritin compared with other indices of iron status in children and teenagers undergoing maintenance hemodialysis. Clin Chem. 1979;25(5):741-4. May. Not a biomarker of inoterest (KQ2)—only older biomarkers evaluated. [pmid: 436243].
163 el-Reshaid K, Johny KV, Hakim A, Kamel H, Sebeta A, Hourani H, Kanyike FB. Erythropoietin treatment in haemodialysis patients with iron overload. Acta Haematol. 1994;91(3):130-5. Analytic validity data for only older markers studied. [pmid: 8091934].
164 Eschbach JW, Cook JD, Finch CA. Iron absorption in chronic renal disease. Clin Sci. 1970;38(2):191-6. Feb. N<10 in one group and only older markers studied in terms of mean values in different groups. [pmid: 5416149].
165 Eschbach JW, Cook JD, Scribner BH, Finch CA. Iron balance in hemodialysis patients. Ann Intern Med. 1977;87(6):710-3. Dec. Not a biomarker of inoterest (KQ2)—only older biomarkers evaluated; Analytic validity data only (KQ2). [pmid: 931207].
166 Eschbach JW, Funk D, Adamson J, Kuhn I, Scribner BH, Finch CA. Erythropoiesis in patients with renal failure undergoing chronic dialysis. N Engl J Med. 1967;276(12):653-8. Mar. 23. Analytic validity data for only older markers studied. [pmid: 6018456].
167 Eschbach JW, Varma A, Stivelman JC. Is it time for a paradigm shift? Is erythropoietin deficiency still the main cause of renal anaemia?. Nephrol Dial Transplant. Suppl 5. 2002;17:2-7. No comparison of biomarkers and treatment not based on markers. [pmid: 12091599].
168 Escribano L, Quereda C, Matesanz R, Cesar J, Steegman JL, Orofino L, Losada M, Odriozola J, Navarro JL, Ortuno J. Preliminary results of a prospective therapeutic programme aimed to control anaemia in a newly created dialysis unit (author’s transl). [Spanish]. Sangre (Barc). 1980;25(5B):697-705. Only one biomarker of interest is studied and treatment is also depended on same marker. [pmid: 7466552].
169 Escribano ML, Sanz GA, Garcia de Bustos JM, Sanchez SL, Torre CA, Martinez AJ, Gomez FP, Selgas GR, Martin VJ. The treatment of anemia in patients with terminal renal insufficiency in haemodialysis. Working hypothesis and preliminary results (author’s transl). [Spanish]. Sangre (Barc). 1980;25(5B):688-96. Not biomarkers of interest—older markers only & Analytical validity data only (KQ2). [pmid: 7466551].
170 Evers JE. Iron-poly (sorbitol-gluconic acid) complex and iron-dextran in the treatment of severe iron deficiency anaemia. Scand J Haematol Suppl. 1977;32:279-85. Non CKD population. [pmid: 341283].
171 Faich G, Strobos J. Sodium ferric gluconate complex in sucrose: safer intravenous iron therapy than iron dextrans. [Review] [20 refs]. Am J Kidney Dis. 1999;33(3):464-70. Mar. n Dx information; Single arm Tx cohort—postmarket analysis of IV iron (KQ3). [pmid: 10070910].
172 Fang YW, Chang CH. Subcutaneous administration of darbepoetin alfa effectively maintains hemoglobin concentrations at extended dose intervals in peritoneal dialysis patients. Perit Dial Int. 2009;29(2):199-203. Mar–Apr. Single arm Tx cohort ; No Dx information. [pmid: 19293358].
173 Fenwick S, Peebles G. Total dose infusion of intravenous iron in patients with chronic kidney disease receiving haemodialysis. J ren care. 2011;37(1):47-51. Mar. Single arm Tx cohort (KQ3). [pmid: 21288317].
174 Fernandez-Gallego J, Martin MA, Alonso A, Toledo R. Treatment with low doses of intravenous iron does not modify hemoglobin nor the erythropoietin dosage. [Spanish]. Nefrologia. 2006;26(1):143-4. Single arm Tx cohort (KQ3). [pmid: 16649439].
175 Fernandez-Gallego J, Martin MA, Sujan S, Vega E. Treatment with intravenous iron and ferritin level. [Spanish]. Nefrologia. 2010;30(3):371-2. Article in Spanish. [pmid: 20514109].
176 Fernandez-Gallego J, Ramos B, Ruiz A, Contreras J, Alvarez BG, Lopez de NE. Study of various factors that could have an impact on the treatment with erythropoietin of hemodialysis anemia. [Spanish]. Nefrologia. 2000;20(2):164-70. Mar–Apr. Single arm Tx cohort (KQ3); no Dx information. [pmid: 10853198].
177 Fernandez-Rodriguez AM, Guindeo-Casasus MC, Molero-Labarta T, Dominguez-Cabrera C, Hortal C, Perez-Borges P, Vega-Diaz N, Saavedra-Santana P, Palop-Cubillo L. Diagnosis of iron deficiency in chronic renal failure. Am J Kidney Dis. 1999;34(3):508-13. Sep. Dx ROC analysis (KQ2), newer marker erythrocyte ferritin. [pmid: 10469862].
178 Ferrari P, Kulkarni H, Dheda S, Betti S, Harrison C, St Pierre TG, Olynyk JK. Serum iron markers are inadequate for guiding iron repletion in chronic kidney disease. Clin J Am Soc Nephrol. 2011;6(1):77-83. Jan. Single arm one-time Fe Tx study; No Dx information. [pmid: 20876673].
179 Fischer MA, Morris CA, Winkelmayer WC, Avorn J. Nononcologic use of human recombinant erythropoietin therapy in hospitalized patients. Arch Intern Med. 2007;167(8):840-6. Apr. 23. Not a population of interest; Not test-directed Tx. [pmid: 17452549].
180 Fishbane S, Berns JS. Hemoglobin cycling in hemodialysis patients treated with recombinant human erythropoietin. Kidney Int. 2005;68(3):1337-43. Sep. No Dx information; Not test-directed Tx. [pmid: 16105069].
181 Fishbane S, Frei GL, Maesaka J. Reduction in recombinant human erythropoietin doses by the use of chronic intravenous iron supplementation. Am J Kidney Dis. 1995;26(1):41-6. Jul. not test-directed Tx. [pmid: 7611266].
182 Fishbane S, Kowalski EA, Imbriano LJ, Maesaka JK. The evaluation of iron status in hemodialysis patients. J Am Soc Nephrol. 1996;7(12):2654-7. Dec. Not biomarkers of interest. [pmid: 8989744].
183 Fishbane S, Lynn RI. The efficacy of iron dextran for the treatment of iron deficiency in hemodialysis patients. Clin Nephrol. 1995;44(4):238-40. Oct. Single arm treatment cohort and no comparison between older markers. [pmid: 8575123].
184 Fishbane S, Ungureanu VD, Maesaka JK, Kaupke CJ, Lim V, Wish J. The safety of intravenous iron dextran in hemodialysis patients. Am J Kidney Dis. 1996;28(4):529-34. Oct. Single arm Tx cohort (KQ3). [pmid: 8840942].
185 Fishbane S. Intravenous infusion of total dose iron in peritoneal dialysis patients: a critical appraisal. Am J Kidney Dis. discussion 1088–90. 1998;32(6):1086-8. Dec. narrative review of another paper (Ahsan; J AM Soc Nephrol 1998). [pmid: 9856530].
186 Fishbane S. Iron treatment: impact of safety issues. Am J Kidney Dis. Suppl 4. 1998;32(6):S152-6. Dec. Narrative review. [pmid: 9892383].
187 Fleming LW, Saleem AK, Goodall HB, Stewart WK. Bone marrow iron and plasma ferritin in dialysed patients given intravenous iron-dextran. Clin Lab Haematol. 1984;6(1):23-31. Analytic validity data only (KQ2). [pmid: 6734097].
188 Folkert VW, Michael B, Agarwal R, Coyne DW, Dahl N, Myirski P, Warnock DG. Ferrlecit Publication Committee. Chronic use of sodium ferric gluconate complex in hemodialysis patients: safety of higher-dose (> or =250 mg) administration. Am J Kidney Dis. 2003;41(3):651-7. Mar. not test-directed Tx. [pmid: 12612989].
189 Folkert VW. Intravenous iron therapy in chronic kidney disease and peritoneal dialysis patients. Nephrol Nurs J. 584. 2003;30(5):571-6. Oct. Narrative review. [pmid: 14621635].
190 Fong TP, Smith EC, Thomas W, Westerman MP. Diagnostic significance of bone marrow biopsy in chronic renal disease. Nephron. 1974;12(2):81-93. Only older markers compared in terms of mean values across 2 diffferent groups. [pmid: 4837747].
191 Ford BA, Coyne DW, Eby CS, Scott MG. Variability of ferritin measurements in chronic kidney disease; implications for iron management. Kidney Int. 2009;75(1):104-10. Jan. Analytic validity data only (for KQ2). [pmid: 18843257].
192 Ford BA, Eby CS, Scott MG, Coyne DW. Intra-individual variability in serum hepcidin precludes its use as a marker of iron status in hemodialysis patients. Kidney Int. 2010;78(8):769-73. Oct. Analytic validity data only (for KQ2). [pmid: 20668427].
193 Formanowicz D, Pietrzak I, Wiktorowicz K. Transferrin microheterogeneity in patients treated by maintenance haemodialysis. [Polish]. Przegl Lek. 2007;64(7–8):483-8. Variants in transferrin studied. [pmid: 18409349].
194 Frankenfield D, Johnson CA, Wish JB, Rocco MV, Madore F, Owen WF. Anemia management of adult hemodialysis patients in the US results: from the 1997 ESRD Core Indicators Project. Kidney Int. 2000;57(2):578-89. Feb. Single arm Tx cohort (KQ3). [pmid: 10652035].
195 Frankenfield DL, Neu AM, Warady BA, Fivush BA, Johnson CA, Brem AS. Anemia in pediatric hemodialysis patients: results from the 2001 ESRD Clinical Performance Measures Project. Kidney Int. 2003;64(3):1120-4. Sep. Single arm Tx cohort (KQ3). [pmid: 12911565].
196 Frifelt JJ, Tvedegaard E, Bruun K, Steffensen G, Cintin C, Breddam M, Dominguez H, Jorgensen JD. Efficacy of recombinant human erythropoietin administered subcutaneously to CAPD patients once weekly. Perit Dial Int. 1996;16(6):594-8. Nov–Dec. Not test-directed Tx. [pmid: 8981527].
197 Fudin R, Jaichenko J, Shostak A, Bennett M, Gotloib L. Correction of uremic iron deficiency anemia in hemodialyzed patients: a prospective study. Nephron. 1998;79(3):299-305. Analytic validity data for only older markers studied. [pmid: 9678430].
198 Furuland H, Linde T, Ahlmen J, Christensson A, Strombom U, Danielson BG. A randomized controlled trial of haemoglobin normalization with epoetin alfa in pre-dialysis and dialysis patients. Nephrol Dial Transplant. 2003;18(2):353-61. Feb. Not test-directed Tx. [pmid: 12543892].
199 Galliford JW, Malasana R, Farrington K. Switching from subcutaneous to intravenous erythropoietin alpha in haemodialysis patients requires a major dose increase. Nephrol Dial Transplant. 2005;20(9):1956-62. Sep. Single arm study. Change in levels of older markers studied. [pmid: 15930017].
200 Ganz T, Olbina G, Girelli D, Nemeth E, Westerman M. Immunoassay for human serum hepcidin. Blood. 2008;112(10):4292-7. Nov. 15. Non CKD patients. Analytic validity data (KQ2). [pmid: 18689548].
201 Garzia M, Di MA, Ferraro E, Tazza L, Rossi E, Luciani G, Zini G. Reticulocyte hemoglobin equivalent: an indicator of reduced iron availability in chronic kidney diseases during erythropoietin therapy. Lab Hematol. 2007;13(1):6-11. Not a biomarker of inoterest; CHr was used as the reference gold-standard test. Newer marker Ret HE. [pmid: 17353176].
202 Gascon A, Belvis JJ, Berisa F, Iglesias E, Estopinan V, Teruel JL. Nandrolone decanoate is a good alternative for the treatment of anemia in elderly male patients on hemodialysis. Geriatr Nephrol Urol. 1999;9(2):67-72. No comparison between biomarkers. Mean values of only older markers studied in two different groups of treatment. [pmid: 10518249].
203 Gasparyan AM, Scherba MM, Tkatchuck WN, Gurin BI, Zykin DB. Changes of iron metabolism in renal diseases. Int Urol Nephrol. 1971;3(2):159-63. No comparison between biomakers. [pmid: 5154513].
204 Gastaldello K, Vereerstraeten A, Nzame-Nze T, Vanherweghem JL, Tielemans C. Resistance to erythropoietin in iron-overloaded haemodialysis patients can be overcome by ascorbic acid administration. Nephrol Dial Transplant. Suppl 6. 1995;10:44-7. N<10 and analytic validity data only for older markers. [pmid: 8524494].
205 Gaweda AE, Goldsmith LJ, Brier ME, Aronoff GR. Iron, inflammation, dialysis adequacy, nutritional status, and hyperparathyroidism modify erythropoietic response. Clin J Am Soc Nephrol. 2010;5(4):576-81. Apr. Single arm treatment cohort. [pmid: 20110344].
206 Gentil MA, Perez-Valdivia MA, Lopez-Mendoza M, Ortega F, Arias M, Gomez-Alamillo C, Campistol JM. ARES Study Group. Factor deficiency in the anemia of renal transplant patients with grade III–IV chronic kidney disease: baseline results of the ARES Study. Transplant Proc. 2008;40(9):2922-4. Nov. Mean values of older markers studied. [pmid: 19010148].
207 Giordano A, Arrigo G, Lavarda F, Colasanti G, Petrini C. Comparison of two iron gluconate treatment modalities in chronic hemodialysis patients: results of a randomized trial. JN, J. nephrol. 2005;18(2):181-7. Mar–Apr. Analytic validity data only (KQ2). New marker HRF is used. [pmid: 15931646].
208 Goch J, Birgegard G, Danielson BG, Wikstrom B. Treatment of erythropoietin-resistant anaemia with desferrioxamine in patients on haemofiltration. Eur J Haematol. 1995;55(2):73-7. Aug. N<10; single arm treatment cohort and analytic validity data for older markers only. [pmid: 7628592].
209 Gokal R, Millard PR, Weatherall DJ, Callender ST, Ledingham JG, Oliver DO. Iron metabolism in haemodialysis patients. A study of the management of iron therapy and overload. Q J Med. 1979;48(191):369-91. Jul. Analytic validity data for older markers only. [pmid: 542584].
210 Goldwasser P, Koutelos T, Abraham S, Avram MM. Serum ferritin, hematocrit and mean corpuscular volume in hemodialysis. Nephron. 1994;67(1):30-5. Only one biomarker studied. [pmid: 8052364].
211 Gotloib L, Silverberg D, Fudin R, Shostak A. Iron deficiency is a common cause of anemia in chronic kidney disease and can often be corrected with intravenous iron. JN, J. nephrol. 2006;19(2):161-7. Mar–Apr. Analytic validity data only for older markers and single arm treatment cohort. [pmid: 16736414].
212 Greenbaum LA, Pan CG, Caley C, Nelson T, Sheth KJ. Intravenous iron dextran and erythropoietin use in pediatric hemodialysis patients. Pediatr Nephrol. 2000;14(10–11):908-11. Sep. Changes in mean values of older markers only studied over the course of therapy and treatment not based on markers. [pmid: 10975297].
213 Grimmelt AC, Cohen CD, Fehr T, Serra AL, Wuethrich RP. Safety and tolerability of ferric carboxymaltose (FCM) for treatment of iron deficiency in patients with chronic kidney disease and in kidney transplant recipients. Clin Nephrol. 2009;71(2):125-9. Feb. No biomarker studied and treatment is fixed. [pmid: 19203504].
214 Grzegorzewska AE, ntczak-Jedrzejczak D, Mariak I. Polyglucose dialysis solution influences serum iron parameters. Adv Perit Dial. 2000;16:73-9. Analytic validity data only for older markers. [pmid: 11045265].
215 Gudim VI, Eremenko LL, Ivanova VS, Gnatiuk AG, Kotel’nikov VM, Diageleva OA, Tokarev I, Kozinets GI, Miterev I. Regulation of erythropoiesis in patients with iron deficiency anemia. [Russian]. Gematol Transfuziol. 1991;36(7):3-5. Jul. Not biomarkers of interest—older biomarkers only. [pmid: 1936885].
216 Guizar JM, Gutierrez MJ, Sanchez G, Kornhauser C. Single weekly dose of recombinant erythropoietin in children with chronic renal insufficiency. [Spanish]. Rev Invest Clin. 1996;48(3):173-7. May–Jun. Single arm treatment cohort and no comparison between markers. [pmid: 8966377].
217 Gupta A, Amin NB, Besarab A, Vogel SE, Divine GW, Yee J, Anandan JV. Dialysate iron therapy: infusion of soluble ferric pyrophosphate via the dialysate during hemodialysis. Kidney Int. 1999;55(5):1891-8. May. Comparison of mean values of older markers only pre and post treatment. [pmid: 10231452].
218 Hackeng CM, Beerenhout CM, Hermans M, Van der Kuy PH, Van der DH Van, Dieijen-Visser MP, Hamulyak K, Van der Sande FM, Leunissen KM, Kooman JP. The relationship between reticulocyte hemoglobin content with C-reactive protein and conventional iron parameters in dialysis patients. JN, J. nephrol. 2004;17(1):107-11. Jan–Feb. Analytical validity data only (KQ2). [pmid: 15151266].
219 Haddad A, Abbadi R, Marji A. Use of iron sucrose in dialysis patients sensitive to iron dextran. Saudi J Kidney Dis Transpl. 2009;20(2):208-11. Mar. Mean values of older markers measured before and after treatment. [pmid: 19237805].
220 Halitchi CI, Munteanu M, Brumariu O. Factors influencing responsiveness to treatment in children with renal anemia in end stage renal disease. [Romanian]. Rev Med Chir Soc Med Nat Iasi. 2008;112(1):94-9. Jan–Mar. Analytic validity data for older markers only. [pmid: 18677909].
221 Hanif E, Ayyub M, Anwar M, Ali W, Bashir M. Evaluation of serum transferrin receptor concentration in diagnosing and differentiating iron deficiency anaemia from anaemia of chronic disorders. JPMA J Pak Med Assoc. 2005;55(1):13-6. Jan. Non CKD patients. [pmid: 15816689].
222 Harant Z, Goldberger JV. Treatment of anemia in the aged: a common problem and challenge. J Am Geriatr Soc. 1975;23(3):127-31. Mar. Anemia prevalence study. [pmid: 1112962].
223 Harmankaya O, Eran A. Low-dose intravenous iron administration in chronic hemodialysis patients treated with recombinant human erythropoietin. Ren Fail. 2002;24(2):245-7. Mar. Changes in mean values of older markers only studied over the course of therapy and treatment not based on markers. [pmid: 12071600].
224 Hasegawa M, Kawamura N, Koide S, Murase M, Asano S, Toba T, Kushimoto H, Murakami K, Tomita M, Hasegawa H, Shikano M, Mizuno M, Funahashi N, Kawashima S, Sugiyama S. Evaluation of reticulocyte hemoglobin content, percentage of hypochromic red blood cells, and ratio of serum transferrin receptor level/serum iron level as markers of iron-deficiency erythropoiesis in patients undergoing hemodialysis. [Japanese]. Nippon Jinzo Gakkai Shi. 2002;44(5):453-63. Language other than english. [pmid: 12216478].
225 Hasuike Y, Nonoguchi H, Tokuyama M, Ohue M, Nagai T, Yahiro M, Nanami M, Otaki Y, Nakanishi T. Serum ferritin predicts prognosis in hemodialysis patients: the Nishinomiya study. Clin Exp Nephrol. 2010;14(4):349-55. Aug. Not a biomarker of interest. [pmid: 20467772].
226 Heilmann FE, Loew H, Muller H, Michael C. Diagnosis and therapy of iron deficiency in long-term dialysis patients. [German]. Verh Dtsch Ges Inn Med. 1974;80:679-81. Not biomarkers of interest—older biomarkers only. [pmid: 4217994].
227 Hertel J, Locay H, Scarlata D, Jackson L, Prathikanti R, Audhya P. Darbepoetin alfa administered every other week maintains hemoglobin levels over 52 weeks in patients with chronic kidney disease converting from once-weekly recombinant human erythropoietin: results from simplify the treatment of anemia with Aranesp (STAAR). Am J Nephrol. 2006;26(2):149-56. Single arm Tx cohort (KQ3); No Dx information. [pmid: 16636531].
228 Hertel JE, Locay HR, Scarlata DS, Prathikanti R, Audhya PK. Darbepoetin alfa administration to achieve and maintain target hemoglobin levels for 1 year in patients with chronic kidney disease. Mayo Clin Proc. 2006;81(9):1188-94. Sep. Single arm treatment cohort. Change in mean values of only older markers studied. [pmid: 16970215].
229 Hirai T, Sugiya N, Nakashima A, Takasugi N, Yorioka N. Switching from epoetin alpha to darbepoetin alpha in Japanese hemodialysis patients: dose conversion ratio. Nephron. 2009;111(2):c81-6. Single arm Tx cohort (KQ3); No Dx information. [pmid: 19088483].
230 Hiramatsu M, Kubota M, Iwasaki M, Akizawa T, Koshikawa S. Study Group. Darbepoetin alfa (KRN321) administered intravenously once monthly maintains hemoglobin levels in peritoneal dialysis patients. Therap Apher Dial. 2008;12(1):19-27. Feb. Single arm study. Changes in mean levels of only older markers studied. [pmid: 18257808].
231 Hobbs DJ, Schwartz AB, Gracely E, Kapoian T, Rizkala AR. DRIVE Study Group. Volatility of elevated serum ferritin in anemic hemodialysis patients. JN, J. nephrol. 2009;22(4):553-60. Jul–Aug. Study addresses ferritin volatility, not test-directed Tx. [pmid: 19662612].
232 Hofmann V, Descoeudres C, Montandon A, Galeazzi RL, Straub PW. Serum ferritin in renal insufficiency, hemodialysis and kidney transplantation. [German]. Schweiz Med Wochenschr. 1978;108(47):1835-8. Nov. 25. Analytic validity data for only older markers studied. [pmid: 362527].
233 Hollands JM, Foote EF, Rodriguez A, Rothschild J, Young S. Safety of high-dose iron sucrose infusion in hospitalized patients with chronic kidney disease. Am J Health-Syst Pharm. 2006;63(8):731-4. Apr. 15. No comparison between biomarkers. Just the data gathered at baseline. [pmid: 16595812].
234 Horl WH, Dreyling K, Steinhauer HB, Engelhardt R, Schollmeyer P. Iron status of dialysis patients under rhuEPO therapy. Contrib Nephrol. 1990;87:78-86. Only one biomarker of interest studied in terms of analytic validity. Also a newer marker erythrocyte ferritin is used. [pmid: 2093543].
235 Horl WH, Holzer H, Mayer GJ, Osterreichische AS. Treatment of renal anemia with darbepoetin alfa: results of an Austrian multicenter study. [German]. Wien Klin Wochenschr. 2002;114(23–24):967-71. Dec. 30. No biomarker comparison and treatment is not based on biomarker. [pmid: 12635463].
236 Hou CC, Wu SC, Wu SC, Yang WC, Huang TP, Ng YY. Serum transferrin receptor concentration is not indicative of erythropoietic activity in chronic hemodialysis patients with poor response to recombinant human erythropoietin. Chung Hua I Hsueh Tsa Chih (Taipei). 1998;61(8):456-62. Aug. Analytical validity data only (KQ2). [pmid: 9745161].
237 Hsu CY, McCulloch CE, Curhan GC. Iron status and hemoglobin level in chronic renal insufficiency. J Am Soc Nephrol. 2002;13(11):2783-6. Nov. Relationship of Hb with older markers studied with no comparison between newer versus older. [pmid: 12397050].
238 Hsu SP, Chiang CK, Chien CT, Hung KY. Plasma prohepcidin positively correlates with hematocrit in chronic hemodialysis patients. Blood Purif. 2006;24(3):311-6. Biomarker not of interest. Analytic validity data only (KQ2). [pmid: 16479095].
239 Hughes RT, Cotes PM, Pippard MJ, Stevens JM, Oliver DO, Winearls CG, Royston JP. Subcutaneous administration of recombinant human erythropoietin to subjects on continuous ambulatory peritoneal dialysis: an erythrokinetic assessment. Br J Haematol. 1990;75(2):268-73. Jun. Not biomarkers of interest—older markers only & Analytical validity data only (KQ2). [pmid: 2372513].
240 Hunderi OH. Iron requirements of hemodialysis patients. Serum ferritin as an indicator. [Norwegian]. Tidsskr Nor Laegeforen. 1986;106(9):738-40. Apr. 10. Not biomarkers of interest—older markers only & Analytical validity data only (KQ2). [pmid: 3705034].
241 Hussain R. Experience of iron saccharate supplementation in haemodialysis patients treated with erythropoietin. Nephrology. 1998;4(1–2):105-108. Not test-directed Tx (KQ3).
242 Hutchinson FN, Jones WJ. A cost-effectiveness analysis of anemia screening before erythropoietin in patients with end-stage renal disease. Am J Kidney Dis. 1997;29(5):651-7. May. Cost effectiveness analysis done. [pmid: 9159297].
243 Ibrahim HN, Foley RN, Zhang R, Gilbertson DT, Collins AJ. Parenteral iron use: possible contribution to exceeding target hemoglobin in hemodialysis patients. Clin J Am Soc Nephrol. 2009;4(3):623-9. Mar. Treatment not based on biomarker. [pmid: 19211669].
244 Icardi A, Sacco P, Salvatore F, Romano U. Long-term intravenous epoetin-alpha/darbepoetin-alpha ratio in iron-replete hemodialysis patients. JN, J. nephrol. 2007;20(1):73-9. Jan–Feb. Analytic validity data for older markers only and treatment is fixed. [pmid: 17347977].
245 Ifudu O, Feldman J, Friedman EA. The intensity of hemodialysis and the response to erythropoietin in patients with end-stage renal disease. N Engl J Med. 1996;334(7):420-5. Feb. 15. Only one biomarker studied and treatment is not based on biomarker. [pmid: 8552143].
246 Ifudu O, Friedman EA. Effect of increased hemodialysis dose on endogenous erythropoietin production in end-stage renal disease. Nephron. 1998;79(1):50-4. Single arm treatment cohort and only one biomarker studied. [pmid: 9609462].
247 Ifudu O, Uribarri J, Rajwani I, Vlacich V, Reydel K, Delosreyes G, Friedman EA. Gender modulates responsiveness to recombinant erythropoietin. Am J Kidney Dis. 2001;38(3):518-22. Sep. No comparison between biomarkers and treatment is not based on any biomarker. [pmid: 11532683].
248 Irving MJ, Craig JC, Gallagher M, McDonald S, Polkinghorne KR, Walker RG, Roger SD. Implementing iron management clinical practice guidelines in patients with chronic kidney disease having dialysis. Med J Aust. 2006;185(6):310-4. Sep. 18. No Dx information, no test-directed Tx. [pmid: 16999671].
249 Iseki K, Fujimi S, Onoyama K, Fujishima M. An evaluation of serum ferritin determination in chronic hemodialysis patients with persistent low serum iron concentration. Miner Electrolyte Metab. 1988;14(5):257-61. Not test-directed Tx (KQ3). [pmid: 3173263].
250 Jacobs A. Serum ferritin. Birth Defects Orig Artic Ser. 1976;12(8):97-103. Narrative review. [pmid: 1009237].
251 Jacobs C, Frei D, Perkins AC. Results of the European Survey on Anaemia Management 2003 (ESAM 2003): current status of anaemia management in dialysis patients, factors affecting epoetin dosage and changes in anaemia management over the last 5 years. Nephrol Dial Transplant. Suppl 3. 2005;20:iii3-24. May. Single arm Tx cohorts (KQ3). [pmid: 15824128].
252 Jain S, Narayan S, Chandra J, Sharma S, Jain S, Malhan P. Evaluation of serum transferrin receptor and sTfR ferritin indices in diagnosing and differentiating iron deficiency anemia from anemia of chronic disease. Indian J Pediatr. 2010;77(2):179-83. Feb. Not CKD patients. [pmid: 20091370].
253 Jairam A, Das R, Aggarwal PK, Kohli HS, Gupta KL, Sakhuja V, Jha V. Iron status, inflammation and hepcidin in ESRD patients: The confounding role of intravenous iron therapy. Indian J. Nephrol. 2010;20(3):125-31. Jul. Analytical validity data only (KQ2). [pmid: 21072151].
254 Jameson S, Killander A, Wadman B. Iron deficiency anaemia and ‘normal’ bone marrow haemosiderin. Blut. 1971;23(2):61-8. Aug. Case study( n<10). [pmid: 5569946].
255 Janicka L, Ksiazek A, Baranowicz I, Bednarek-Skublewska A, Mierzicki P, Ksiazek P. Subcutaneous r-HuEPO therapy in CAPD patients: dose determination and clinical experience. Int Urol Nephrol. 1998;30(1):91-7. Single arm treatment cohort and no comparison between biomarkers. [pmid: 9569119].
256 Javier AM. Weekly administration of high-dose sodium ferric gluconate is safe and effective in peritoneal dialysis patients. Nephrol Nurs J. 2002;29(2):183-6. Apr. N<10; Not biomarkers of interest—older biomarkers only(KQ2); Not test-directed Tx (KQ3). [pmid: 11997953].
257 John GT, Chandy M, Thomas PP, Shastry JC, Jacob CK. Iron stores in patients on haemodialysis after renal transplantation. Natl Med J India. 1993;6(3):108-10. May–Jun. Single arm Tx cohort (KQ3); No Dx information. [pmid: 8329987].
258 Johnson CA, Rosowski E, Zimmerman SW. A prospective open-label study evaluating the efficacy and adverse reactions of the use of Niferex-150 in ESRD patients receiving EPOGEN. Adv Perit Dial. 1992;8:444-7. Single arm Tx cohort (KQ3); No Dx information. [pmid: 1361844].
259 Johnson DW, Herzig KA, Gissane R, Campbell SB, Hawley CM, Isbel NM. A prospective crossover trial comparing intermittent intravenous and continuous oral iron supplements in peritoneal dialysis patients. Nephrol Dial Transplant. 2001;16(9):1879-84. Sep. Change in mean values of older markers studied and treatment is not based on biomarker. [pmid: 11522873].
260 Johnson DW, Herzig KA, Gissane R, Campbell SB, Hawley CM, Isbel NM. Oral versus intravenous iron supplementation in peritoneal dialysis patients. Perit Dial Int. Suppl 3. 2001;21:S231-5. Narrative Review. [pmid: 11887827].
261 Jonckheere S, Dierick J, Vanhouteghem H, Devleeschouwer M, Stove V. Erythrocyte indices in the assessment of iron status in dialysis-dependent patients with end-stage renal disease on continuous erythropoietin receptor activator versus epoetin beta therapy. Acta Haematol. 2010;124(1):27-33. No comparison between biomarkers influencing treatments. [pmid: 20606413].
262 Jones CH, Richardson D, Ayers S, Newstead CG, Will EJ, Davison AM. Percentage hypochromic red cells and the response to intravenous iron therapy in anaemic haemodialysis patients. Nephrol Dial Transplant. 1998;13(11):2873-6. Nov. Analytic validity data only (for KQ2). [pmid: 9829493].
263 Jones-Burton C, Seliger SL, Brown J, Stackiewicz L, Hsu VD, Fink JC. Racial variations in erythropoietic response to epoetin alfa in chronic kidney disease and the impact of smoking. Nephrol Dial Transplant. 2005;20(12):2739-45. Dec. Mean values of only older biomarkers studied in different groups. [pmid: 16188897].
264 Jontosohn R, Junkers K, Muller H, Heinze V, Kluthe R. Serum transferrin, protein intake, and iron metabolism in regular hemodialysis patients (author’s transl). [German]. Klin Wochenschr. 1974;52(8):398-9. Apr. 15. Not biomarkers of interest—older biomarkers only(KQ2); Not test-directed Tx (KQ3). [pmid: 4212813].
265 Joosten E, Van LR, Billen J, Blanckaert N, Fabri R, Pelemans W. Serum transferrin receptor in the evaluation of the iron status in elderly hospitalized patients with anemia. Am J Hematol. 2002;69(1):1-6. Jan. Non CKD-patients. [pmid: 11835323].
266 Joosten E, Vander EB, Billen J. Small-dose oral iron absorption test in anaemic and non-anaemic elderly hospitalized patients. Eur J Haematol. 1997;58(2):99-103. Feb. Non CKD patients. [pmid: 9111590].
267 Junca J, Fernandez-Aviles F, Oriol A, Navarro JT, Milla F, Sancho JM, Feliu E. The usefulness of the serum transferrin receptor in detecting iron deficiency in the anemia of chronic disorders. Haematologica. 1998;83(8):676-80. Aug. Non CKD-patients. [pmid: 9793248].
268 Junkers K, Jontofsohn R, Klein G, Heinze V. Parenteral iron substitution for the therapy of anemia in patients under chronic hemodialysis. [German]. Med Welt. 1973;24(25):1042-4. Jun. 22. Not biomarkers of interest—older biomarkers only(KQ2); Single arm Tx cohort (KQ3). [pmid: 4756334].
269 Kadota K, Kamata K, Kobayashi Y, Kagaya H, Shimada S, Yoshimoto-Furuie K, Echizen H. Nomogram for individualizing supplementary iron doses during erythropoietin therapy in haemodialysis patients. J Clin Pharm Ther. 2002;27(2):111-9. Apr. Single arm Tx cohort (KQ3). [pmid: 11975695].
270 Kalantar-Zadeh K, Don BR, Rodriguez RA, Humphreys MH. Serum ferritin is a marker of morbidity and mortality in hemodialysis patients. Am J Kidney Dis. 2001;37(3):564-72. Mar. Only older markers compared in terms of Odds Ratios for predicting risk of death. [pmid: 11228181].
271 Kalantar-Zadeh K, Hoffken B, Wunsch H, Fink H, Kleiner M, Luft FC. Diagnosis of iron deficiency anemia in renal failure patients during the post-erythropoietin era. Am J Kidney Dis. 1995;26(2):292-9. Aug. Not a biomarker of interest; only older markers used. [pmid: 7645533].
272 Kalantar-Zadeh K, Luft FC, Humphreys MH. Moderately high serum ferritin concentration is not a sign of iron overload in dialysis patients. Kidney Int. 1999;56(2):758-9. Aug. editorial. Comparison only between 2 older markers in terms of analytic validity data. [pmid: 10432420].
273 Kalantar-Zadeh K, Regidor DL, McAllister CJ, Michael B, Warnock DG. Time-dependent associations between iron and mortality in hemodialysis patients. J Am Soc Nephrol. 2005;16(10):3070-80. Oct. No Dx information; Not test-directed Tx. [pmid: 16033854].
274 Kalantar-Zadeh K, Rodriguez RA, Humphreys MH. Association between serum ferritin and measures of inflammation, nutrition and iron in haemodialysis patients. Nephrol Dial Transplant. 2004;19(1):141-9. Jan. Single arm Tx cohort. [pmid: 14671049].
275 Kalinowski M, Poplawski A, Kaliszewski Z, Juzwiuk J. Effect of deferoxamine on erythropoiesis in patients hemodialyzed for chronic renal insufficiency treated with erythropoietin. [Polish]. Pol Merkuriusz Lek. 1996;1(4):232-4. Oct. N<10; Single arm Tx cohort (KQ3); No Dx information. [pmid: 9156931].
276 Kaltwasser JP, Werner E, Bechstein PB, Koch KM. The evaluation of serum ferritin as a measure for the body iron store in comparison with other methods. [German]. Verh Dtsch Ges Inn Med. 1977;83:1135-8. Apr. 17–21. Not biomarkers of interest—older biomarkers only. [pmid: 611806].
277 Kao HH, Chen KS, Tsai CJ, Lee CC, Chang HY. Clinical characteristic of parenteral iron supplementation in hemodialysis patients receiving erythropoietin therapy. Chang Gung Med J. 2000;23(10):608-13. Oct. Not test-directed Tx (KQ3). [pmid: 11126152].
278 Kapoian T, O’Mara NB, Singh AK, Moran J, Rizkala AR, Geronemus R, Kopelman RC, Dahl NV, Coyne DW. Ferric gluconate reduces epoetin requirements in hemodialysis patients with elevated ferritin. J Am Soc Nephrol. 2008;19(2):372-9. Feb. Treatment fixed. Only older markers studied with no comparison with newer ones. [pmid: 18216316].
279 Kapoian T. Sodium ferric gluconate complex reduces epoetin doses in epoetin-resistant hemodialysis patients with elevated ferritin: preliminary results of the DRIVE-II study. [abstract no: F-PO671]. No source- cochran. Mean levels of only older markers monitored during treatment and treatment is not dependent on biomarker.
280 Kaskel FJ. Safety and efficacy of sodium ferric gluconate complex in iron-deficient pediatric hemodialysis patients. Nat clin pract nephrol. 2006;2(5):244-5. May. Not test-directed Tx (KQ3). [pmid: 16932433].
281 Kato A, Hamada M, Suzuki T, Maruyama T, Maruyama Y, Hishida A. Effect of weekly or successive iron supplementation on erythropoietin doses in patients receiving hemodialysis. Nephron. 2001;89(1):110-2. Sep. [pmid: 11528242].
282 Kato A, Tsuji T, Luo J, Sakao Y, Yasuda H, Hishida A. Association of prohepcidin and hepcidin-25 with erythropoietin response and ferritin in hemodialysis patients. Am J Nephrol. 2008;28(1):115-21. Analytical validity data only (KQ2). [pmid: 17943020].
283 Kato J, Kobune M, Kohgo Y, Fujikawa K, Takimoto R, Torimoto Y, Ito Y, Bessho M, Hotta T, Hikawa A, Fujii T, Punnonen K, Niitsu Y. Ratio of transferrin (Tf) to Tf-receptor complex in circulation differs depending on Tf iron saturation. Clin Chem. 2002;48(1):181-3. Jan. No Dx information. [pmid: 11751556].
284 Kaufman JS, Reda DJ, Fye CL, Goldfarb DS, Henderson WG, Kleinman JG, Vaamonde CA. Department of Veterans Affairs Cooperative Study Group on Erythropoietin in Hemodialysis Patients. Diagnostic value of iron indices in hemodialysis patients receiving epoetin. Kidney Int. 2001;60(1):300-8. Jul. Not biomarkers of interest; Only SF & TSAT examined (KQ2). [pmid: 11422765].
285 Kaupke CJ, Kim S, Vaziri ND. Effect of erythrocyte mass on arterial blood pressure in dialysis patients receiving maintenance erythropoietin therapy. J Am Soc Nephrol. 1994;4(11):1874-8. May. Changes in mean values of older markers studied pre and post treatment. [pmid: 7919137].
286 Kendall RG, Jeffries R, Cavill I, Norfolk DR. Relationship between endogenous erythropoietin levels, reticulocyte count, and reticulocyte RNA distribution. A study of anemic patients with and without renal failure. Ann N Y Acad Sci. 1994;718:353-5. Apr. 15. Not a biomarker of interest. [pmid: 7514381].
287 Kessler M, Landais P, Canivet E, Yver L, Bataille P, Brillet G, Commenges B, Kone S. Is the management of anemia in hemodialysis patients improving in France? Results of the DiaNE study. [French]. Nephrol Ther. 2009;5(2):114-21. Apr. Single arm Tx cohort, no Dx information (French). [pmid: 19042175].
288 Keven K, Kutlay S, Nergizoglu G, Erturk S. Randomized, crossover study of the effect of vitamin C on EPO response in hemodialysis patients. Am J Kidney Dis. 2003;41(6):1233-9. Jun. Not test-directed Tx. [pmid: 12776276].
289 Kim JK, Park BS, Park MJ, Choi W, Ma SK, Nah MY, Yeum CH, Jung K, Lee SC, Kim SW, Kim NH, Kang YJ, Choi KC. The predictive parameters of erythropoietin hyporesponsiveness in patients on continuous ambulatory peritoneal dialysis. Korean J Intern Med. 2001;16(2):110-7. Jun. Single arm Tx cohort (KQ3). [pmid: 11590897].
290 Kirschbaum B. Serial ferritin concentrations in hemodialysis patients receiving intravenous iron. Clin Nephrol. 2002;57(6):452-6. Jun. Not biomarkers of interest—older markers. [pmid: 12078949].
291 Kleinman KS, Schweitzer SU, Perdue ST, Bleifer KH, Abels RI. The use of recombinant human erythropoietin in the correction of anemia in predialysis patients and its effect on renal function: a double-blind, placebo-controlled trial. Am J Kidney Dis. 1989;14(6):486-95. Dec. Not biomarkers of interest—older biomarkers only. [pmid: 2688405].
292 Knight TG, Ryan K, Schaefer CP, D’Sylva L, Durden ED. Clinical and economic outcomes in Medicare beneficiaries with stage 3 or stage 4 chronic kidney disease and anemia: the role of intravenous iron therapy. J Manage Care Pharm. 2010;16(8):605-15. Oct. Treatment not based on biomarker. [pmid: 20866165].
293 Kohn H, Wider G, Zazgornik J, Zimmermann E, Mostbeck A, Bayer PM. Value of serum ferritin for determination of body iron stores in patients on chronic haemodialysis and after kidney transplantation. Ric Clin Lab. 1980;10(1):127-32. Jan–Mar. Not biomarkers of interest—older biomarkers only. [pmid: 7008151].
294 Kooistra MP, Marx JJ. The absorption of iron is disturbed in recombinant human erythropoietin-treated peritoneal dialysis patients. Nephrol Dial Transplant. 1998;13(10):2578-82. Oct. Single arm Tx cohort (KQ3). [pmid: 9794563].
295 Kooistra MP, Niemantsverdriet EC, van EA, Mol-Beermann NM, Struyvenberg A, Marx JJ. Iron absorption in erythropoietin-treated haemodialysis patients: effects of iron availability, inflammation and aluminium. Nephrol Dial Transplant. 1998;13(1):82-8. Jan. Analytic validity data (KQ2). [pmid: 9481720].
296 Kooistra MP, van EA, Struyvenberg A, Marx JJ. Iron metabolism in patients with the anaemia of end-stage renal disease during treatment with recombinant human erythropoietin. Br J Haematol. 1991;79(4):634-9. Dec. Analytical validity data only (KQ2). [pmid: 1772785].
297 Kopelman RC, Smith L, Peoples L, Biesecker R, Rizkala AR. Functional iron deficiency in hemodialysis patients with high ferritin. Hemodial. int. 2007;11(2):238-46. Apr. Comparison of Different cutoffs. [pmid: 17403177].
298 Kosch M, Bahner U, Bettger H, Matzkies F, Teschner M, Schaefer RM. A randomized, controlled parallel-group trial on efficacy and safety of iron sucrose (Venofer) vs iron gluconate (Ferrlecit) in haemodialysis patients treated with rHuEpo. Nephrol Dial Transplant. 2001;16(6):1239-44. Jun. Analytic validity data only (KQ2). [pmid: 11390726].
299 Kovesdy CP, Estrada W, Ahmadzadeh S, Kalantar-Zadeh K. Association of markers of iron stores with outcomes in patients with nondialysis-dependent chronic kidney disease. Clin J Am Soc Nephrol. 2009;4(2):435-41. Feb. Only older markers compared to each other while looking at their association with mortality. [pmid: 19118116].
300 Kozlovskaia LV, Milovanov I, Nikolaev AI, Milovanova LI. Erythropoetin and iron preparations in the treatment of anemia in patients with chronic kidney disease of stage III–IV in systemic diseases. [Russian]. Ter Arkh. 2007;79(6):30-4. Not test-directed Tx (KQ3). [pmid: 17684963].
301 Krause JR, Stolc V. Serum ferritin and bone marrow biopsy iron stores. II. Correlation with low serum iron and Fe/TIBC ratio less than 15%. Am J Clin Pathol. 1980;74(4):461-4. Oct. Not biomarkers of interest—older markers only (KQ2). [pmid: 7424828].
302 Ksiazek A, Majdan M, Jaroszynski A, Swatowski A, Krzywicka A, Kolibska E, Gotner S, Kosicki A, Piaseczny W, Sokalski A. Erythropoietin treatment in patients on maintenance haemodialysis in dialysis centers of South-East region of Poland--present state. Ann Univ Mariae Curie Sklodowska [Med]. Suppl 3. 1994;48:1-7. Single arm Tx cohort (KQ3); No Dx information. [pmid: 8192527].
303 Ksiazek. Iron metabolism in patients treated with erythropoietin. [Polish]. Przegl Lek. 85. 52(3):1995. Not biomarkers of interest—older biomarkers only. [pmid: 7644679].
304 Kuiper-Kramer EP, Coenen JL, Huisman CM, Abbes A, van RJ, van Eijk HG. Relationship between soluble transferrin receptors in serum and membrane-bound transferrin receptors. Acta Haematol. 1998;99(1):8-11. Non-CKD patients. [pmid: 9490571].
305 Kuiper-Kramer EP, Huisman CM, van RJ, van Eijk HG. Analytical and clinical implications of soluble transferrin receptors in serum. Eur J Clin Chem Clin Biochem. 1996;34(8):645-9. Aug. Non-CKD patients. [pmid: 8877341].
306 Kulaksiz H, Gehrke SG, Janetzko A, Rost D, Bruckner T, Kallinowski B, Stremmel W. Pro-hepcidin: expression and cell specific localisation in the liver and its regulation in hereditary haemochromatosis, chronic renal insufficiency, and renal anaemia. Gut. 2004;53(5):735-43. May. Experimental lab study. [pmid: 15082594].
307 Kuo CC, Lee CT, Chuang CH, Su Y, Chen JB. Recombinant human erythropoietin independence in chronic hemodialysis patients: clinical features, iron homeostasis and erythropoiesis. Clin Nephrol. 2005;63(2):92-7. Feb. Analytical validity data only (KQ2); Logistic regression only looks at r-HuEPO independence, not iron deficiency. [pmid: 15730050].
308 Kurihara I, Saito T, Nakayama K, Sato H. Intravenous low-dose iron administration in hemodialysis patients treated with erythropoietin. Nephron. 1998;80(3):369-70. Nov. Single arm Tx cohort (KQ3); Not biomarkers of interest—older markers only (KQ2). [pmid: 9807056].
309 Kwan JT, Pratt RD. Epoetin Delta Study Group. Epoetin delta, erythropoietin produced in a human cell line, in the management of anaemia in predialysis chronic kidney disease patients. Curr Med Res Opin. 2007;23(2):307-11. Feb. Not test-directed Tx. [pmid: 17288685].
310 Labonia W, Rubio D, Arias C. Melatonin corrects reticuloendothelial blockade and iron status in haemodialysed patients. Nephrology. 2005;10(6):583-7. Dec. Single arm treatment cohort. Change in mean values of only older markers studied pre and post treatment. [pmid: 16354241].
311 Laman CA, Silverstein SB, Rodgers GM. Parenteral iron therapy: a single institution’s experience over a 5-year period. J. Natl. Compr. Cancer Netw. 2005;3(6):791-5. Nov. Single arm Tx cohort (KQ3); No Dx information; CKD patients—N<10. [pmid: 16316614].
312 Lausevic M, Nesic V, Jovanovic N, Stojimirovic B. Anemia in peritoneal dialysis patients. [Serbian]. Srp Arh Celok Lek. 2006;134(3–4):133-7. Mar–Apr. Single arm Tx cohort (KQ3); No Dx information. [pmid: 16915754].
313 Lazarus JM, Hakim RM, Newell J. Recombinant human erythropoietin and phlebotomy in the treatment of iron overload in chronic hemodialysis patients. Am J Kidney Dis. 1990;16(2):101-8. Aug. N<10; Single arm Tx cohort (KQ3); Not biomarkers of interest—older biomarkers only & Analytical validity data only (KQ2). [pmid: 2382644].
314 Leijn E, Monnens LA, Cornelissen EA. Intravenous iron supplementation in children on hemodialysis. JN, J. nephrol. 2004;17(3):423-6. May–Jun. Comparison of Different cutoffs. [pmid: 15365964].
315 Leikis MJ, Kent AB, Becker GJ, McMahon LP. Haemoglobin response to subcutaneous versus intravenous epoetin alfa administration in iron-replete haemodialysis patients. Nephrology. 2004;9(3):153-60. Jun. Not test-directed Tx. [pmid: 15189176].
316 Lenga I, Lok C, Marticorena R, Hunter J, Dacouris N, Goldstein M. Role of oral iron in the management of long-term hemodialysis patients. Clin J Am Soc Nephrol. 2007;2(4):688-93. Jul. Treatment fixed and not based on biomarkers. No biomarker comparison. [pmid: 17699483].
317 Leu MI, Shih LY, Huang MJ. Serum ferritin and bone marrow iron in patient on maintenance hemodialysis. Taiwan I Hsueh Hui Tsa Chih. 1981;80(8):804-14. Aug. Not biomarkers of interest—older biomarkers only. [pmid: 6947063].
318 Li H, Rose MJ, Tran L, Zhang J, Miranda LP, James CA, Sasu BJ. Development of a method for the sensitive and quantitative determination of hepcidin in human serum using LC-MS/MS. J Pharmacol Toxicol Methods. 2009;59(3):171-80. May–Jun. Only newer biomarker discussed. In vitro study?. [pmid: 19258043].
319 Li H, Wang SX. Intravenous iron sucrose in maintenance dialysis patients with renal anemia: a clinical study. [Chinese]. Chung Hua I Hsueh Tsa Chih. 2009;89(7):457-62. Feb. 24. Not test-directed Tx (KQ3). [pmid: 19567093].
320 Li H, Wang SX. Intravenous iron sucrose in Chinese hemodialysis patients with renal anemia. Blood Purif. 2008;26(2):151-6. Analytic validity data only for older markers. [pmid: 18212498].
321 Li H, Wang SX. Intravenous iron sucrose in peritoneal dialysis patients with renal anemia. Perit Dial Int. 2008;28(2):149-54. Mar–Apr. Changes in mean values of older markers studied pre and post treatment. [pmid: 18332450].
322 Li S, Foley RN, Gilbertson DT, Liu J, Collins AJ. Clinical factors associated with achieving K/DOQI hemoglobin targets in hemodialysis patients. Int Urol Nephrol. 2003;35(3):399-405. Treatment not based on biomarker. [pmid: 15160548].
323 Lin CL, Hsu PY, Yang HY, Huang CC. Low dose intravenous ascorbic acid for erythropoietin-hyporesponsive anemia in diabetic hemodialysis patients with iron overload. Ren Fail. 2003;25(3):445-53. May. Change in mean values of only older markers after the treatment is studied. [pmid: 12803508].
324 Lin JL, Chang MY, Tan DT, Leu ML. Short-term small-dose intravenous iron trial to detect functional iron deficiency in dialysis patients. Am J Nephrol. 2001;21(2):91-7. Mar–Apr. Sensitivity and specificity comparison between older markers only. [pmid: 11359015].
325 Linde T, Furuland H, Wikstrom B. Effect of switching from subcutaneous to intravenous administration of epoetin-alpha in haemodialysis patients: results from a Swedish multicentre survey. Scand J Urol Nephrol. 2005;39(4):329-33. Changes in mean values of older markers studied pre and post treatment. [pmid: 16118109].
326 Ling B, Walczyk M, Agarwal A, Carroll W, Liu W, Brenner R. Darbepoetin alfa administered once monthly maintains hemoglobin concentrations in patients with chronic kidney disease. Clin Nephrol. 2005;63(5):327-34. May. Single arm Tx cohort (KQ3); No Dx information. [pmid: 15909591].
327 Lipschitz DA, Cook JD, Finch CA. A clinical evaluation of serum ferritin as an index of iron stores. N Engl J Med. 1974;290(22):1213-6. May. 30. Non CKD patients and analytic validity data only between older markers. [pmid: 4825851].
328 Lisochenko NM, Idel’son LI. Comparative evaluation of orferon with other iron preparations in iron deficiency anemias. [Russian]. Vrach Delo. 1973;5:20-2. May. Not biomarkers of interest—older markers;. [pmid: 4757724].
329 Liu CC, Haiu KT, Tsai HJ, Lam KK. Red cell distribution width in the detection of iron deficiency in maintenance hemodialysis patients. Changgeng Yi Xue Za Zhi. 1990;13(4):268-73. Dec. [pmid: 2282563].
330 Locatelli F, Covic A, Macdougall IC, Wiecek A. ORAMA Study Group. ORAMA: a study to investigate EBPG impact on renal anaemia—design and baseline data. JN, J. nephrol. 2008;21(4):592-603. Jul–Aug. Treatment not based on biomarker. [pmid: 18651551].
331 Locatelli F, Villa G, Messa P, Filippini A, Cannella G, De FG, Naso A, Rossi E, Formica M, Lombardi L, Rotolo U, Conte F. Efficacy and safety of once-weekly intravenous epoetin alfa in maintaining hemoglobin levels in hemodialysis patients. JN, J. nephrol. 2008;21(3):412-20. May–Jun. Treatment not based on biomarker and population group not of interest. [pmid: 18587731].
332 Lockner D, Paul C. Clinical trial of a new intramuscular iron preparation in iron deficiency anaemia. Scand J Haematol Suppl. 1977;32:288-95. Non CKD patients and single arm treatment cohort. [pmid: 341284].
333 Lopez-Gomez JM, Portoles JM, Aljama P. Factors that condition the response to erythropoietin in patients on hemodialysis and their relation to mortality. Kidney Int Suppl. 2008;(111):S75-81. Dec. [pmid: 19034333].
334 Lorenzo JD, Rodriguez MM, Martin SS, Romo JM. Assessment of erythropoiesis activity during hemodialysis therapy by soluble transferrin receptor levels and ferrokinetic measurements. Am J Kidney Dis. 2001;37(3):550-6. Mar. Analytic validity data only (KQ2). [pmid: 11228179].
335 Low CL, Bailie GR, Eisele G. Sensitivity and specificity of transferrin saturation and serum ferritin as markers of iron status after intravenous iron dextran in hemodialysis patients. Ren Fail. 1997;19(6):781-8. Nov. Sensitivity and specificty comparison between older markers only. [pmid: 9415935].
336 Ludat K, Paulitschke M, Riedel E, Hampl H. Complete correction of renal anemia by recombinant human erythropoietin. Clin Nephrol. 1 Suppl. 2000;53:S42-9. Feb. Only one biomarker studied. [pmid: 10746805].
337 Lui SF, Wong KC, Li PK, Lai KN. Once weekly versus twice weekly subcutaneous administration of recombinant human erythropoietin in haemodialysis patients. Am J Nephrol. 1992;12(1–2):55-60. Not test-directed Tx (KQ3). [pmid: 1415366].
338 Lynn KL, Mitchell TR, Shepperd J. Red cell indices and iron stores in patients undergoing haemodialysis. Br Med J (Clin Res Ed). 1981;282(6282):2096. Jun. 27. Analytic validity data only for older markers. [pmid: 6788217].
339 Lynn KL, Mitchell TR, Shepperd J. Serum ferritin concentration in patients receiving maintenance hemodialysis. Clin Nephrol. 1980;14(3):124-7. Sep. Only one biomarker studied. [pmid: 7418278].
340 Macdougall IC, Cavill I, Hulme B, Bain B, McGregor E, McKay P, Sanders E, Coles GA, Williams JD. Detection of functional iron deficiency during erythropoietin treatment: a new approach. BMJ. 1992;304(6821):225-6. Jan. 25. Analytic validity data only (for KQ2). [pmid: 1739797].
341 Macdougall IC, Chandler G, Elston O, Harchowal J. Beneficial effects of adopting an aggressive intravenous iron policy in a hemodialysis unit. Am J Kidney Dis. Suppl 2. 1999;34(4):S40-6. Oct. Single arm Tx cohort (KQ3); No Dx information. [pmid: 10516375].
342 Macdougall IC, Hutton RD, Cavill I, Coles GA, Williams JD. Poor response to treatment of renal anaemia with erythropoietin corrected by iron given intravenously. BMJ. 1989;299(6692):157-8. Jul. 15. case series; N<10. [pmid: 2504356].
343 Macdougall IC, Tucker B, Thompson J, Tomson CR, Baker LR, Raine AE. A randomized controlled study of iron supplementation in patients treated with erythropoietin. Kidney Int. 1996;50(5):1694-9. Nov. Not test-directed Tx (KQ3); Not biomarkers of interest—older markers only. [pmid: 8914038].
344 Macdougall IC. What is the most appropriate strategy to monitor functional iron deficiency in the dialysed patient on rhEPO therapy? Merits of percentage hypochromic red cells as a marker of functional iron deficiency. Nephrol Dial Transplant. 1998;13(4):847-9. Apr. Narrative review. [pmid: 9568837].
345 Maconi M, Cavalca L, Danise P, Cardarelli F, Brini M. Erythrocyte and reticulocyte indices in iron deficiency in chronic kidney disease: comparison of two methods. Scand J Clin Lab Invest. 2009;69(3):365-70. Only newer markers compared. [pmid: 19125368].
346 Madhan KK, Chamberlain M, Anderson E. Anaemia in patients with chronic kidney disease: management with epoetin beta in primary care setting in New Zealand. Nephrology. 2008;13(5):428-32. Oct. Single arm Tx cohort (KQ3); Not biomarkers of interest—older markers only. [pmid: 18331435].
347 Madore F, Lowrie EG, Brugnara C, Lew NL, Lazarus JM, Bridges K, Owen WF. Anemia in hemodialysis patients: variables affecting this outcome predictor. J Am Soc Nephrol. 1997;8(12):1921-9. Dec. Single arm Tx cohort (KQ3); Not biomarkers of interest—older markers only. [pmid: 9402095].
348 Mafra D, Cuppari L, Favaro DI, Cozzolino SM. Zinc levels after iron supplementation in patients with chronic kidney disease. J Ren Nutr. 2004;14(3):164-9. Jul. Analytical validity data only (KQ2); Single arm Tx cohort (KQ3). [pmid: 15232795].
349 Magid E, Hilden M. Ferrokinetics in patients suffering from chronic renal disease and anaemia. Scand J Haematol. 1967;4(1):33-45. Not biomarkers of interest—ferrokinetic parameters (KQ2). [pmid: 6031893].
350 Majdan M, Ksiazek A, Koziol M, Spasiewicz D, Swatowski A, Solski J. Comparison of plasma erythropoietin concentrations and iron status in hemodialyzed patients not requiring and requiring rHuEpo therapy. Nephron. 1996;73(3):425-9. Comparison of mean values of older markers in different groups. [pmid: 8832602].
351 Malovrh M, Hojs N, Premru V. The influence of need-based, continuous, low-dose iron replacement on hemoglobin levels in hemodialysis patients treated with erythropoiesis-stimulating agents. Artif Organs. 2011;35(1):63-8. Jan. Single arm cohort subject to treatment at two different periods but using common markers. [pmid: 20618233].
352 Malovrh M, Premru V. Subcutaneous compared with intravenous epoetin treatment in patients on hemodialysis: one center study. Therap Apher Dial. 2005;9(3):233-6. Jun. Not test-directed Tx (KQ3). [pmid: 15966996].
353 Malyszko J, Malyszko JS, Hryszko T, Pawlak K, Mysliwiec M. Is hepcidin a link between anemia, inflammation and liver function in hemodialyzed patients?. Am J Nephrol. 2005;25(6):586-90. Nov–Dec. Analytical validity data only (KQ2). [pmid: 16254410].
354 Malyszko J, Malyszko JS, Kozminski P, Koc-Zorawska E, Mysliwiec M, Macdougall I. Possible relationship between neutrophil gelatinase-associated lipocalin, hepcidin, and inflammation in haemodialysed patients. Nephron. 2010;115(4):c268-75. Analytical validity data only (KQ2). [pmid: 20424477].
355 Malyszko J, Malyszko JS, Kozminski P, Mysliwiec M. Type of renal replacement therapy and residual renal function may affect prohepcidin and hepcidin. Ren Fail. 2009;31(10):876-83. Analytic validity data only (KQ2). [pmid: 20030521].
356 Malyszko J, Malyszko JS, Mysliwiec M. Hyporesponsiveness to erythropoietin therapy in hemodialyzed patients: potential role of prohepcidin, hepcidin, and inflammation. Ren Fail. 2009;31(7):544-8. Only mean values of older and newer markers given for two different groups given as per ESA response. [pmid: 19839848].
357 Malyszko J, Malyszko JS, Mysliwiec M. Serum prohepcidin and hepcidin in hemodialyzed patients undergoing iron therapy. Kidney Blood Press Res. 2009;32(4):235-8. Analytic validity data only (KQ2). [pmid: 19713706].
358 Malyszko J, Malyszko JS, Pawlak K, Drozdowska-Rams L, Brzosko S, Mysliwiec M. Hepcidin is linked to anemia and inflammation in peritoneal dialysis patients. Perit Dial Int. 2008;28(4):418-21. Jul–Aug. Analytic validity data only (KQ2). [pmid: 18556388].
359 Malyszko J, Malyszko JS, Pawlak K, Mysliwiec M. Hepcidin, an acute-phase protein and a marker of inflammation in kidney transplant recipients with and without coronary artery disease. Transplant Proc. 2006;38(9):2895-8. Nov. Analytic validity data only (for KQ2). [pmid: 17112858].
360 Malyszko J, Malyszko JS, Pawlak K, Mysliwiec M. Hepcidin, iron status, and renal function in chronic renal failure, kidney transplantation, and hemodialysis. Am J Hematol. 2006;81(11):832-7. Nov. Analytic validity data only (for KQ2). [pmid: 16929540].
361 Marco Franco JE, Alarcon ZA, Morey MA, Piza BC, Bestard PJ, Mairata BS, Galmes LA, Dalmau DM. Serum ferritin in hemodialysis. I. Study in populations treated with iron or untreated. [Spanish]. Rev Clin Esp. 1981;163(6):403-6. Dec. 31. Analytic validity data for older markers only. [pmid: 7342203].
362 Marisavljevic D, Djukanovic L, Lezajic V. The effect of recombinant human erythropoietin on erythrocyte lines in patients with anemia and chronic renal insufficiency. [Serbian]. Srp Arh Celok Lek. 1992;120(9–10):281-5. Sep–Oct. most likely reject. No native language screener to confirm. [pmid: 1306020].
363 Markovic M, Majkic-Singh N, Subota V. Usefulness of soluble transferrin receptor and ferritin in iron deficiency and chronic disease. Scand J Clin Lab Invest. 2005;65(7):571-6. Non CKD-patients. [pmid: 16271988].
364 Markowitz GS, Kahn GA, Feingold RE, Coco M, Lynn RI. An evaluation of the effectiveness of oral iron therapy in hemodialysis patients receiving recombinant human erythropoietin. Clin Nephrol. 1997;48(1):34-40. Jul. Comparison of Different cutoffs. [pmid: 9247776].
365 Markus HS. Diagnostic investigations in the elderly: the clinical usefulness of serum iron and transferrin measurements in the diagnosis of iron deficiency anaemia. An audit. Br J Clin Pract. 1989;43(12):451-3. Dec. Non CKD patients and comparison between only older markers. [pmid: 2611108].
366 Mars RL, Moles K, Pope K, Hargrove P. Use of bolus intraperitoneal iron dextran in continuous ambulatory peritoneal dialysis or continuous cyclic peritoneal dialysis patients receiving recombinant human erythropoietin. Adv Perit Dial. 1999;15:60-4. Analytical validity data only (KQ2); Single arm Tx cohort (KQ3). [pmid: 10682073].
367 Mathieu CM, Teta D, Lotscher N, Golshayan D, Gabutti L, Kiss D, Martin PY, Burnier M. Optimal and continuous anaemia control in a cohort of dialysis patients in Switzerland. BMC Nephrol. 2008;9:16. Analytical validity data only (KQ2); Single arm Tx cohort (KQ3). [pmid: 19077225].
368 McClellan WM, Frankenfield DL, Wish JB, Rocco MV, Johnson CA, Owen WF. End-Stage Renal Disease Core Indicators Work Group. Subcutaneous erythropoietin results in lower dose and equivalent hematocrit levels among adult hemodialysis patients: Results from the 1998 End-. Stage Renal Disease Core Indicators Project. Am J Kidney Dis. 2001;37(5):E36. May. Single arm Tx cohort (KQ3); Not biomarkers of interest—older markers only. [pmid: 11325701].
369 McDonald SP, Marshall MR, Kerr PG, Russ GR. Erythropoietic agents, iron and hemoglobin--What happens beyond the trial setting: observational data from the ANZDATA registry. Hemodial. int. 2004;8(3):257-64. Jul. 1. Single arm Tx cohort (KQ3); Not biomarkers of interest—older markers only. [pmid: 19379425].
370 McMahon LP, Kent AB, Kerr PG, Healy H, Irish AB, Cooper B, Kark A, Roger SD. Maintenance of elevated versus physiological iron indices in non-anaemic patients with chronic kidney disease: a randomized controlled trial. Nephrol Dial Transplant. 2010;25(3):920-6. Mar. Treatment is not based on biomarker. Analytic validity (correlations) seen between 2 older markers only. [pmid: 19906658].
371 Mehta BC, Patel JC. Recurrence of iron deficiency anemia after total dose iron-dextran therapy. Indian J Med Sci. 1970;24(4):196-9. Apr. Case series; N<10; Crosssectional study; Not biomarkers of interest—older markers only. [pmid: 5505596].
372 Michael B, Coyne DW, Folkert VW, Dahl NV, Warnock DG. Ferrlecit Publication Committee. Sodium ferric gluconate complex in haemodialysis patients: a prospective evaluation of long-term safety. Nephrol Dial Transplant. 2004;19(6):1576-80. Jun. Single arm Tx cohort (KQ3); No Dx information. [pmid: 15034152].
373 Miguel Carrasco JA, Alcocer FH, Caridad MA, Lozano RL, Giner SR, Caparros PJ, Rosalen AR. Response to 2 methods of parenteral administration of iron in patients in periodical hemodialysis. [Spanish]. Rev Clin Esp. 1979;153(2):117-20. Apr. 30. Not test-directed Tx (KQ3). [pmid: 482675].
374 Miller HJ, Hu J, Valentine JK, Gable PS. Efficacy and tolerability of intravenous ferric gluconate in the treatment of iron deficiency anemia in patients without kidney disease. Arch Intern Med. 2007;167(12):1327-8. Jun. 25. Single arm Tx cohort (KQ3); Non CKD patients. [pmid: 17592108].
375 Milman N, Bangsboll S, Pedersen NS, Visfeldt J. Serum ferritin in non-dialysis patients with chronic renal failure: relation to bone marrow iron stores. Scand J Haematol. 1983;30(4):337-44. Apr. Not biomarkers of interest—older markers only & Analytical validity data only (KQ2). [pmid: 6857149].
376 Milman N, Christensen TE, Pedersen NS, Visfeldt J. Serum ferritin and bone marrow iron in non-dialysis, peritoneal dialysis and hemodialysis patients with chronic renal failure. Acta Med Scand. 1980;207(3):201-5. Not biomarkers of interest—older markers only & Analytical validity data only (KQ2). [pmid: 7368987].
377 Milman N. Iron absorption measured by whole body counting and the relation to marrow iron stores in chronic uremia. Clin Nephrol. 1982;17(2):77-81. Feb. Not biomarkers of interest—older markers only & Analytical validity data only (KQ2). [pmid: 6802544].
378 Milman N. Iron therapy in patients undergoing maintenance hemodialysis. Acta Med Scand. 1976;200(4):315-9. Analytical validity data only (KQ2); Single arm Tx cohort (KQ3). [pmid: 983800].
379 Milman N. Plasma transferrin and the relation to iron status in patients with chronic uremia. Clin Nephrol. 1981;16(6):314-20. Dec. Not biomarkers of interest—older markers only & Analytical validity data only (KQ2). [pmid: 6172227].
380 Milutinovic S, Trkulja V. Reduced responsiveness to epoetin at re-exposure after prolonged epoetin-free period in anemic hemodialysis patients with end-stage renal disease. Croat Med J. 2006;47(3):424-32. Jun. Not test-directed Tx. [pmid: 16758521].
381 Mirahmadi KS, Paul WL, Winer RL, bir-Vaziri N, Byer B, Gorman JT, Rosen SM. Serum ferritin level. Determinant of iron requirement in hemodialysis patients. JAMA. 1977;238(7):601-3. Aug. 15. Analytic validity data for older markers only. [pmid: 577960].
382 Mirahmadi MK, Vaziri ND. Value of serum ferritin determination in hemodialysis patients. Int J Artif Organs. 1980;3(6):318-9. Nov. review. [pmid: 7461867].
383 Mitsuiki K, Harada A, Miyata Y. Reticulocyte hemoglobin content in hemodialysis patients with acute infection. Clin Exp Nephrol. 2004;8(3):257-62. Sep. Analytic validity data only (for KQ2). [pmid: 15480904].
384 Mizuguchi T, Minakuchi J, Kawahara K, Kawashima S, Hikawa A, Nomata Y. Serum transferrin receptor level as an index of the response to erythropoietin therapy for anemia in pre-dialysis patients with chronic renal failure. [Japanese]. Nippon Jinzo Gakkai Shi. 1997;39(5):497-502. Jul. Appears to be Analytical validity data only (KQ2); Japanese article. [pmid: 9283215].
385 Mombelloni S, Movilli E, Pizzocolo G, Ravelli M, Mombelloni A, Campanini M, Cancarini G, Ascari L, Albertini A, Maiorca R. Determination of serum ferritin in hemodialyzed patients. [Italian]. Minerva Nefrol. 1981;28(3):303-9. Jul–Sep. Not biomarkers of interest—older markers only & Analytical validity data only (KQ2). [pmid: 7329607].
386 Moore LW, Smith SO, Winsett RP, Acchiardo SR, Gaber AO. Factors affecting erythropoietin production and correction of anemia in kidney transplant recipients. Clin Transplant. 1994;8(4):358-64. Aug. Comparison of Different cutoffs. [pmid: 7949539].
387 Moran J. IV sodium ferric gluconate complex is safe in patients with elevanted ferritin and low TSAT: final safety results of the DRIVE Study. [abstract no: F-PO685]. Journal of the American Society of Nephrology. Abstracts. 2006;17:482A.
388 Moreb J, Popovtzer MM, Friedlaender MM, Konijn AM, Hershko C. Evaluation of iron status in patients on chronic hemodialysis: relative usefulness of bone marrow hemosiderin, serum ferritin, transferrin saturation, mean corpuscular volume and red cell protoporphyrin. Nephron. 1983;35(3):196-200. Analytic validity data only (KQ2). [pmid: 6633760].
389 Moreno F, Sanz-Guajardo D, Lopez-Gomez JM, Jofre R, Valderrabano F. Increasing the hematocrit has a beneficial effect on quality of life and is safe in selected hemodialysis patients. Spanish Cooperative Renal Patients Quality of Life Study Group of the Spanish Society of Nephrology. J Am Soc Nephrol. 2000;11(2):335-42. Feb. Single arm Tx cohort (KQ3); No Dx information. [pmid: 10665941].
390 Morgan HE, Gautam M, Geary DF. Maintenance intravenous iron therapy in pediatric hemodialysis patients. Pediatr Nephrol. 2001;16(10):779-83. Oct. Single arm Tx cohort (KQ3); No Dx information. [pmid: 11605781].
391 Morgan HE, Holt RC, Jones CA, Judd BA. Intravenous iron treatment in paediatric chronic kidney disease patients not on erythropoietin. Pediatr Nephrol. 2007;22(11):1963-5. Nov. N<10; Single arm Tx cohort (KQ3); No Dx information. [pmid: 17704954].
392 Morgan T, Innes M, Ribush N. The management of the anaemia of patients on chronic haemodialysis. Med J Aust. 1972;1(17):848-52. Apr. 22. Analytic validity data for older markers only. [pmid: 5026057].
393 Morris KP, Watson S, Reid MM, Hamilton PJ, Coulthard MG. Assessing iron status in children with chronic renal failure on erythropoietin: which measurements should we use?. Pediatr Nephrol. 1994;8(1):51-6. Feb. N<10; Single arm Tx cohort (KQ3); Analytical validity data only (KQ2). [pmid: 8142226].
394 Mortelmans AK, Duym P, Vandenbroucke J, De SR, Dhondt A, Lesaffer G, Verwimp H, Vanholder R. Intradialytic parenteral nutrition in malnourished hemodialysis patients: a prospective long-term study. JPEN J Parenter Enteral Nutr. 1999;23(2):90-5. Mar–Apr. Not an intervention of interest; Single arm Tx cohort (KQ3); No Dx information. [pmid: 10081999].
395 Movilli E, Cancarini GC, Vizzardi V, Camerini C, Brunori G, Cassamali S, Maiorca R. Epoetin requirement does not depend on dialysis dose when Kt/N > 1.33 in patients on regular dialysis treatment with cellulosic membranes and adequate iron stores. JN, J. nephrol. 2003;16(4):546-51. Jul–Aug. Not biomarkers of interest—older biomarkers only. [pmid: 14696757].
396 Movilli E, Cancarini GC, Zani R, Camerini C, Sandrini M, Maiorca R. Adequacy of dialysis reduces the doses of recombinant erythropoietin independently from the use of biocompatible membranes in haemodialysis patients. Nephrol Dial Transplant. 2001;16(1):111-4. Jan. Not biomarkers of interest—older biomarkers only. [pmid: 11209002].
397 Mudge DW, Tan KS, Miles R, Johnson DW, Campbell SB, Hawley CM, Isbel NM, van Eps CL, Nicol DL. Intravenous versus oral iron supplementation for correction of post-transplant anaemia in renal transplant patients. BMC Nephrol. 2009;10:14. Not-test directed Tx (KQ3); Study protocol only. [pmid: 19500381].
398 Muirhead N, Cattran DC, Zaltzman J, Jindal K, First MR, Boucher A, Keown PA, Munch LC, Wong C. Safety and efficacy of recombinant human erythropoietin in correcting the anemia of patients with chronic renal allograft dysfunction. J Am Soc Nephrol. 1994;5(5):1216-22. Nov. Single arm Tx cohort (KQ3); Not biomarkers of interest—older biomarkers only. [pmid: 7873732].
399 Muller HA, Schneider H, Hovelborn U, Streicher E. Ferritin: a reliable indicator of iron supplementation in patients on chronic hemodialysis/hemofiltration treatment?. Artif Organs. 1981;5(2):168-74. May. Only one biomarker studied. [pmid: 7271530].
400 Muller-Wiefel DE, Brendlein F, Ehrlich J, Brandeis WE, Scharer K. Serum ferritin in children with disorders of iron balance. [German]. Helv Paediatr Acta. 1982;37(3):245-56. Jun. Analytic validity data only for older markers. [pmid: 7118557].
401 Muller-Wiefel DE, Waldherr R, Feist D, van KG. The assessment of iron stores in children on regular dialysis treatment. Contrib Nephrol. 1984;38:141-52. Analytic validity data for older markers only. [pmid: 6713891].
402 Muller-Wiefel DE. Renal anemia. Its diagnosis, pathogenesis, compensation and therapy in childhood. [German]. Monatsschr Kinderheilkd. 1984;132(2):72-9. Feb. No comparison between markers. [pmid: 6374430].
403 Nailescu C, Castaneda M, Del RM, Flynn JT. Iron supplementation in adolescent hemodialysis patients. Clin Nephrol. 2004;62(6):449-54. Dec. N<10; Not test-directed Tx (KQ3);. [pmid: 15630904].
404 Nakai S, Masakane I, Akiba T, Iseki K, Watanabe Y, Itami N, Kimata N, Shigematsu T, Shinoda T, Syoji T, Syoji T, Suzuki K, Tsuchida K, Nakamoto H, Hamano T, Marubayashi S, Morita O, Morozumi K, Yamagata K, Yamashita A, Wakai K, Wada A, Tsubakihara Y. Overview of regular dialysis treatment in Japan (as of 31 December 2005). Therap Apher Dial. 2007;11(6):411-41. Dec. Single arm Tx cohort (KQ3); Not biomarkers of interest—older biomarkers only. [pmid: 18028170].
405 Nakajima K, Aita N, Kimura K, Usami E, Hirano C. Serum ferritin level in hemodialysis patients (author’s transl). [Japanese]. Horumon To Rinsho. 1981;29(11):1399-402. Nov. Analytic validity data for older markers only. [pmid: 7341003].
406 Nakanishi T, Moriguchi R, Itahana R, Otaki Y, Inoue T, Takamitsu Y. Acute effect of human recombinant erythropoietin administration on soluble transferrin receptor. Nephron. 2001;89(1):119-20. Sep. Analytical validity data only (KQ2). [pmid: 11528246].
407 Navarro JF, Teruel JL, Liano F, Marcen R, Ortuno J. Effectiveness of intravenous administration of Fe-gluconate-Na complex to maintain adequate body iron stores in hemodialysis patients. Am J Nephrol. 1996;16(4):268-72. Single arm treatment cohort. Analytic validity data for older markers only. [pmid: 8739277].
408 Nelson R, Chawla M, Connolly P, LaPorte J. Ferritin as an index of bone marrow iron stores. South Med J. 1978;71(12):1482-4. Dec. Not biomarkers of interest—older biomarkers only. [pmid: 725624].
409 Ng HY, Chen HC, Pan LL, Tsai YC, Hsu KT, Liao SC, Chuang FR, Chen JB, Lee CT. Clinical interpretation of reticulocyte hemoglobin content, RET-Y, in chronic hemodialysis patients. Nephron. 2009;111(4):c247-52. Only analytic validity data (KQ2). [pmid: 19293593].
410 Nguyen TV, Wells D. Establishing maintenance doses of lV iron in anemia management to improve patient outcomes. Nephrol Nurs J. quiz 59. 2011;38(1):55-8. Jan–Feb. Single arm treatment cohort. No comparison between markers. [pmid: 21469554].
411 Nguyen TV. Comparison of serum ferritin and transferrin saturation values associated with two i.v. iron formulations in hemodialysis patients. Am J Health-Syst Pharm. 2009;66(12):1101-4. Jun. 15. Comparison between 2 older markers. [pmid: 19498125].
412 Nhan J, Jensen L, McMahon A. Evaluation of an anemia algorithm in chronic hemodialysis patients. CANNT J. 62. 73. quiz 59–61, 74–6. 2007;17(3):48-58. Jul–Sep. review of anemia tx algorithms. [pmid: 17944348].
413 Nicholas JC. A study of the response of elderly patients with end-stage renal disease to epoetin alfa or beta. Drugs Aging. 2004;21(3):187-201. Single arm Tx cohort (KQ3); No Dx information. [pmid: 14979736].
414 Nikolaev AI, Klepikov PV, Lashutin SV, Kondakhchan MA, Rogov VA, Trofimova EI. Individual differences in the efficacy of Recormon in patients with terminal kidney failure. The role of iron deficiency. [Russian]. Ter Arkh. 1993;65(6):45-8. Treatment fixed and not dependent on markers. [pmid: 8378849].
415 Nissenson AR, Berns JS, Sakiewicz P, Ghaddar S, Moore GM, Schleicher RB, Seligman PA. Clinical evaluation of heme iron polypeptide: sustaining a response to rHuEPO in hemodialysis patients. Am J Kidney Dis. 2003;42(2):325-30. Aug. Not-test directed Tx (KQ3); Not biomarkers of interest—older biomarkers only. [pmid: 12900815].
416 Nissenson AR, Lindsay RM, Swan S, Seligman P, Strobos J. Sodium ferric gluconate complex in sucrose is safe and effective in hemodialysis patients: North American Clinical Trial. Am J Kidney Dis. 1999;33(3):471-82. Mar. Not test-directed Tx. [pmid: 10070911].
417 Nurko S, Spirko R, Law A, Dennis VW. Dosing intervals and hemoglobin control in patients with chronic kidney disease and anemia treated with epoetin alfa or darbepoetin alfa: a retrospective cohort study. Clin Ther. 2007;29(9):2010-21. Sep. Single arm Tx cohort (KQ3); No Dx information. [pmid: 18035200].
418 Nurnuansuwan S, Leelahavanichkul A, Pansin P, Eiam-Ong S. Intravenous iron administration during the maintenance period in erythropoietin-treated hemodialysis patients: a simple and effective method. J Med Assoc Thai. Suppl 4. 2005;88:S184-8. Sep. Single arm Tx cohort (KQ3); No Dx information. [pmid: 16623026].
419 Nuwayri-Salti N, Jabre F, Daouk M, Sa’ab G, Salem Z. Hematologic parameters and iron stores in patients on hemodialysis for chronic renal failure. Clin Nephrol. 1992;38(2):101-4. Aug. Single arm Tx cohort (KQ3); Analytical validity data only (KQ2). [pmid: 1516277].
420 Nuwayri-Salti N, Jabre F, Sa’ab G, Daouk M, Salem Z. Monocyte ferritin as a possible index of bone marrow iron stores in patients on chronic hemodialysis. Nephron. 1990;54(1):7-11. Not biomarkers of interest—older markers only & Analytical validity data only (KQ2). [pmid: 2296347].
421 Ogi M, Horiuchi T, Abe R, Wakabayashi M, Wakabayashi T. Comparison of intravenous ascorbic acid versus intravenous iron for functional iron deficiency in hemodialysis patients. [Japanese]. Nippon Jinzo Gakkai Shi. 2004;46(8):804-9. Treatment is fixed and n<10 in one treatment arm. Analytic vaidity data for older markers only. [pmid: 15645737].
422 Ohe Y, Akasaka K, Ohno Y, Kawagoe H, Kishimoto T, Sakai R, Tsujino T, Hara H, Fujita Y, Yoshida Y. Assay of erythropoietin in serum with short term enzyme linked immunosorbent assay method--the clinical significance: Part 2--:Relation to serum iron, UIBC and ferritin in renal failure and hematological disorders. [Japanese]. Rinsho Byori. 1993;41(4):463-7. Apr. No comparison between markers and part of study group is non CKD patients. [pmid: 8350509].
423 Oliveira C, Boquinhas H, Gaspar A, Adragao T, Boquinhas JM, Junior EC, Simoes J. Assessment of iron requirements during treatment of anemia with recombinant human erythropoietin in patients with chronic renal insufficiency under hemodialysis. [Portuguese]. Acta Med Port. 1992;5(7):351-7. Jul. Analytic validity data for older markers only. [pmid: 1442178].
424 Ongkingco JR, Ruley EJ, Turner ME. Use of low-dose subcutaneous recombinant human erythropoietin in end-stage renal disease: experience with children receiving continuous cycling peritoneal dialysis. Am J Kidney Dis. 1991;18(4):446-50. Oct. Single arm treatment cohort. Anlaytic validity data for older markers only. [pmid: 1928063].
425 Oosterhuis WP, van der HM, van DK, Ulenkate HJ, Volmer M, Wulkan RW. Prospective comparison of the flow chart for laboratory investigations for anaemia from the Dutch College of General Practitioners’ guideline ‘Anaemia’ with a self-developed, substantive and logistical alternative flow chart. [Dutch]. Ned Tijdschr Geneeskd. 2007;151(42):2326-32. Oct. 20. Non CKD patients. [pmid: 18064935].
426 Pai A, Raj D, McQuade C, Olp J, Hicks P, Conner T. Non-transferrin bound iron (NTBI), cytokine activation and intracellular reactive oxygen species generation in hemodialysis (HD) patients receiving iron dextran (ID) or iron sucrose (IS). [abstract no: TH-PO689]. Journal of the American Society of Nephrology. 2008;19(Abstracts Issue):263A. No comparison between biomarkers and treatment is fixed. New marker- Non transferrin bound iron.
427 Panesar A, Agarwal R. Safety and efficacy of sodium ferric gluconate complex in patients with chronic kidney disease. Am J Kidney Dis. 2002;40(5):924-31. Nov. Analytic validity data for older markers only. [pmid: 12407636].
428 Paris M, Benoit MO, Bied A, Charlier C, Pressac M, Revenant MC, Vernet M. Hemodialysis and ferritinemia. [French]. Ann Biol Clin (Paris). 1992;50(4):251-8. Only one biomarker studied. [pmid: 1456504].
429 Park G, Park CY, Jang SJ, Moon DS, Park SM, Park YJ. Soluble transferrin receptor-ferritin index and estimated body iron in iron-deficiency anemia in ‘select’ chronic diseases. Ann Hematol. 2009;88(9):913-5. Sep. Non CKD patients. Newer marker -Soluble transferrin receptor-ferritin index (sTFR-F). [pmid: 19137299].
430 Park L, Uhthoff T, Tierney M, Nadler S. Effect of an intravenous iron dextran regimen on iron stores, hemoglobin, and erythropoietin requirements in hemodialysis patients. Am J Kidney Dis. 1998;31(5):835-40. May. Single arm Tx cohort (KQ3). [pmid: 9590194].
431 Park SB, Kim HC, Lee SH, Cho WH, Park CH. Evolution of serum ferritin levels in renal transplant recipients with severe iron overload. Transplant Proc. 1994;26(4):2054-5. Aug. Only one biomarker studied and no EPO or iron treatment given. [pmid: 8066668].
432 Parker PA, Izard MW, Maher JF. Therapy of iron deficiency anemia in patients on maintenance dialysis. Nephron. 1979;23(4):181-6. Treatment fixed and analytic validity data for older markers only. [pmid: 471141].
433 Pascual J, Teruel JL, Liano F, Sureda A, Ortuno J. Intravenous Fe-gluconate-Na for iron-deficient patients on hemodialysis. Nephron. 121. 60(1):1992. Only one biomarker studied. [pmid: 1738405].
434 Pascual J, Teruel JL, Liano F, Sureda A, Ortuno J. Sodium ferric gluconate complex given intravenously for iron deficiency in hemodialysis. Clin Nephrol. 1991;35(2):87. Feb. Treatment fixed and only one biomarker studied. [pmid: 2019020].
435 Patterson P, Allon M. Prospective evaluation of an anemia treatment algorithm in hemodialysis patients. Am J Kidney Dis. 1998;32(4):635-41. Oct. Single arm Tx cohort (KQ3). [pmid: 9774126].
436 Peacock E, Lindenfeld SM. Clinical practice guidelines for maintaining adequate iron status with intravenous iron dextran in hemodialysis patients. [Review] [30 refs]. ANNA J. 1999;26(3):337-43. Jun. Narrative review. [pmid: 10633605].
437 Peskin SR. Will biomarkers bring smarter care?. Manag Care. 2008;17(11):25-8. Nov. [pmid: 19051995].
438 Peters HP, Laarakkers CM, Swinkels DW, Wetzels JF. Serum hepcidin-25 levels in patients with chronic kidney disease are independent of glomerular filtration rate. Nephrol Dial Transplant. 2010;25(3):848-53. Mar. Analytic validity data only (KQ2). [pmid: 19854845].
439 Piccoli A, Malagoli A, Komninos G, Pastori G. Subcutaneous epoetin-alpha every one, two, and three weeks in renal anemia. JN, J. nephrol. 2002;15(5):565-74. Sep–Oct. Treatment is fixed and analytic validity data for older markers only. [pmid: 12455725].
440 Piedras J, Cinta-Severo MC, Valdez K, Lupez-Karpovitch X. Soluble transferrin receptor in iron-deficient patients with and without anemia. Haematologica. 2003;88(3):348-9. Mar. non CKD-patienots. [pmid: 12651276].
441 Piedras J, Cordova MS, varez-Hernandez X, Wadgymar A, Hernandez G, Pena JC. Anemia and iron stores in patients during hemodialysis and after renal transplantation. [Spanish]. Rev Invest Clin. 1982;34(2):129-32. Apr–Jun. Analytic validity data for older markers only. [pmid: 6750733].
442 Pietrzyk JA, Dyras P, Smolnik T, Szymowska M. Effect of using recombinant human erythropoietin on the effectiveness of hemodialysis in children with terminal renal failure. [Polish]. Przegl Lek. 1992;49(1–2):61-5. No comparison between biomarkers and treatment is fixed. [pmid: 1280842].
443 Piomelli S, Brickman A, Carlos E. Rapid diagnosis of iron deficiency by measurement of free erythrocyte porphyrins and hemoglobin: the FEP/hemoglobin ratio. Pediatrics. 1976;57(1):136-41. Jan. Non CKD patients. Unsaturated Iron binding capacity—newer marker?. [pmid: 1246489].
444 Piraino B, Johnston JR. The use of subcutaneous erythropoietin in CAPD patients. Clin Nephrol. 1990;33(4):200-2. Apr. Not biomarkers of interest—older markers only (KQ2). [pmid: 2350907].
445 Pizzi LT, Bunz TJ, Coyne DW, Goldfarb DS, Singh AK. Ferric gluconate treatment provides cost savings in patients with high ferritin and low transferrin saturation. Kidney Int. 2008;74(12):1588-95. Dec. Treatment not based on biomarker. Mostly a cost effectiveness study. [pmid: 19034302].
446 Pizzi LT. Economic considerations in a changing anemia environment. Am J Kidney Dis. 6 Suppl. 2008;52:S29-33. Dec. Narrative review. [pmid: 19010259].
447 Pollak VE, Lorch JA, Means RT. Unanticipated favorable effects of correcting iron deficiency in chronic hemodialysis patients. J Investig Med. 2001;49(2):173-83. Mar. Treatment is fixed and not dependent on markers. Analytic validity data for older markers only. [pmid: 11288758].
448 Pollak VE, Lorch JA, Shukla R, Satwah S. The importance of iron in long-term survival of maintenance hemodialysis patients treated with epoetin-alfa and intravenous iron: analysis of 9.5 years of prospectively collected data. BMC Nephrol. 2009;10:6. Noc omparison between markers and treatment is fixed. [pmid: 19245700].
449 Pollok M, Bommer J, Gurland HJ, Koch KM, Schoeppe W, Scigalla P, Baldamus CA. Effects of recombinant human erythropoietin treatment in end-stage renal failure patients. Results of a multicenter phase II/III study. Contrib Nephrol. discussion 212–8. 1989;76:201-11. Analytic validity data for older markers only. [pmid: 2684523].
450 Portoles J, Lopez-Gomez JM, Aljama P. Anemia management and treatment response in patients on hemodialysis: the MAR study. JN, J. nephrol. 2006;19(3):352-60. May–Jun. Treatment is fixed and no comparison of biomarkers. [pmid: 16874697].
451 Post JB, Wilkes BM, Michelis MF. Iron deficiency in patients with chronic kidney disease: potential role for intravenous iron therapy independent of erythropoietin. Int Urol Nephrol. 2006;38(3–4):719-23. Single arm Tx cohorts (KQ3). [pmid: 17106764].
452 Prakash S, Walele A, Dimkovic N, Bargman J, Vas S, Oreopoulos D. Experience with a large dose (500 mg) of intravenous iron dextran and iron saccharate in peritoneal dialysis patients. Perit Dial Int. 2001;21(3):290-5. May–Jun. Analytic validity data for older markers only. [pmid: 11475345].
453 Provenzano R, Schiller B, Rao M, Coyne D, Brenner L, Pereira BJ. Ferumoxytol as an intravenous iron replacement therapy in hemodialysis patients. Clin J Am Soc Nephrol. 2009;4(2):386-93. Feb. Treatment fixed and not based on biomarkers. Analytic validity data only (KQ2). [pmid: 19176796].
454 Przybylowski P, Malyszko J, Malyszko JS, Koc-Zorawska E, Sadowski J, Mysliwiec M. Anemia in heart and kidney allograft recipients: is there a role for hepcidin?. Transplant Proc. 2010;42(10):4255-8. Dec. Analytic validity data only (for KQ2). [pmid: 21168677].
455 Punnonen K, Irjala K, Rajamaki A. Iron-deficiency anemia is associated with high concentrations of transferrin receptor in serum. Clin Chem. 1994;40(5):774-6. May. Non CKD patients. [pmid: 7513628].
456 Punnonen K, Irjala K, Rajamaki A. Serum transferrin receptor and its ratio to serum ferritin in the diagnosis of iron deficiency. Blood. 1997;89(3):1052-7. Feb. 1. non CKD-patienots. [pmid: 9028338].
457 Pussell BA, Walker R. Australian Renal Anaemia Group. Australian haemodialysis patients on intravenous epoetin alfa or intravenous darbepoetin alfa: how do they compare?. Nephrology. 2007;12(2):126-9. Apr. Comparison of mean values of older markers in different groups. [pmid: 17371333].
458 Qunibi WY, Martinez C, Smith M, Benjamin J, Mangione A, Roger SD. A randomized controlled trial comparing intravenous ferric carboxymaltose with oral iron for treatment of iron deficiency anaemia of non-dialysis-dependent chronic kidney disease patients. Nephrol Dial Transplant. 2011;26(5):1599-607. May. Analytic validity data for older markers only. [pmid: 20929915].
459 Rafi A, Karkar A, Abdelrahman M. Monitoring iron status in end-stage renal disease patients on hemodialysis. Saudi J Kidney Dis Transpl. 2007;18(1):73-8. Mar. Analytic validity data for older markers only. [pmid: 17237895].
460 Ragab M, Mahmoud K, Ragab A. Maintenance intravenous iron sucrose therapy in children under regular hemodialysis. Journal of Medical Sciences. 2007;7(7):1112-6. Treatment is fixed and analytic validity data for older markers only.
461 Raja R, Bloom E, Goldstein M, Johnson R. Erythropoietin with oral iron in peritoneal and hemodialysis patients. A comparison in an inner city population. ASAIO J. 1993;39(3):M578-80. Jul–Sep. Comparison of mean values of only older markers in different groups. [pmid: 8268603].
462 Raja R, Bloom E, Johnson R, Goldstein M. Improved response to erythropoietin in peritoneal dialysis patients as compared to hemodialysis patients: role of iron deficiency. Adv Perit Dial. 1994;10:135-8. Not biomarkers of interest—older biomarkers only & Analytical validity data only (KQ2); Single arm Tx cohort (KQ3). [pmid: 7999811].
463 Raja R, Bloom E, Johnson R. Comparative effects of erythropoietin with oral iron in peritoneal dialysis and hemodialysis patients. Adv Perit Dial. 1993;9:177-80. Not biomarkers of interest—older biomarkers only & Analytical validity data only (KQ2); Single arm Tx cohort (KQ3). [pmid: 8105918].
464 Rajamaki A, Irjala K, Aitio A. Immunochemical determination of serum transferrin. Reference values, correlation with serum total iron-binding capacity and value in the diagnosis of iron deficiency anaemia and anaemia of chronic disorders. Scand J Haematol. 1979;23(3):227-31. Sep. non-CKD population; Not biomarkers of interest—older biomarkers only & Analytical validity data only (KQ2);. [pmid: 116362].
465 Ramirez B, Flores A, Perez F, Cordoba C, Garcia L, Vazquez G. Human recombinant erythropoietin (rHuEPO) in the treatment of anemia in patients with chronic renal failure (CRF): experience with a group of patients on chronic haemodialysis treatment. Transplant Proc. 1991;23(2):1833-4. Apr. N<10; Single arm Tx cohort (KQ3); Not biomarkers of interest—older markers only. [pmid: 2053170].
466 Rangel EB, Esposito BP, Carneiro FD, Mallet AC, Matos AC, Andreoli MC, Guimaraes-Souza NK, Santos BF. Labile plasma iron generation after intravenous iron is time-dependent and transitory in patients undergoing chronic hemodialysis. Therap Apher Dial. 2010;14(2):186-92. Apr. Single arm Tx cohort (KQ3); Not biomarkers of interest—older markers only. [pmid: 20438541].
467 Rao M, Muirhead N, Klarenbach S, Moist L, Lindsay RM. Management of anemia with quotidian hemodialysis. Am J Kidney Dis. 1 Suppl. 2003;42:18-23. Jul. Not test-directed Tx. [pmid: 12830439].
468 Rath T, Florschutz K, Kalb K, Rothenpieler U, Schletter J, Seeger W, Zinn S. Low-molecular-weight iron dextran in the management of renal anaemia in patients on haemodialysis--the IDIRA Study. Nephron. 2010;114(1):c81-8. Single arm Tx cohort (KQ3); Not biomarkers of interest—older markers only & Analytical validity data only (KQ2). [pmid: 19887827].
469 Raymond CB, Collins DM, Bernstein KN, Skwarchuk DE, Vercaigne LM. Erythropoietin-alpha dosage requirements in a provincial hemodialysis population: effect of switching from subcutaneous to intravenous administration. Nephron. 2006;102(3–4):c88-92. Single arm Tx cohort (KQ3); Not biomarkers of interest—older markers only & Analytical validity data only (KQ2). [pmid: 16282700].
470 Reed J, Charytan C, Yee J. The safety of intravenous iron sucrose use in the elderly patient. Consult Pharm. 2007;22(3):230-8. Mar. same markers for both arms;reslts presented by age group only;. [pmid: 17658969].
471 Remacha AF, Sarda MP, Parellada M, Ubeda J, Manteiga R. The role of serum transferrin receptor in the diagnosis of iron deficiency. Haematologica. 1998;83(11):963-6. Nov. non CKD-patienots. [pmid: 9864913].
472 Renoult E, Lataste A, Kessler M. Effect of iron supplementation on the incidence of erythrocytosis following renal transplantation. Transplant Proc. 1994;26(4):2043-4. Aug. Single arm Tx cohort (KQ3); Not biomarkers of interest—older markers only & Analytical validity data only (KQ2). [pmid: 8066665].
473 Richardson D, Bartlett C, Jolly H, Will EJ. Intravenous iron for CAPD populations: proactive or reactive strategies?. Nephrol Dial Transplant. 2001;16(1):115-9. Jan. Single arm Tx cohort (KQ3); Analytical validity data only (KQ2). [pmid: 11209003].
474 Richardson D, Bartlett C, Will EJ. Intervention thresholds and ceilings can determine the haemoglobin outcome distribution in a haemodialysis population. Nephrol Dial Transplant. 2000;15(12):2007-13. Dec. Even though it is test-directed Tx, the tests used to direct Tx are the same in both arms. [pmid: 11096147].
475 Richardson D, Bartlett C, Will EJ. Optimizing erythropoietin therapy in hemodialysis patients. Am J Kidney Dis. 2001;38(1):109-17. Jul. Single arm Tx cohort (KQ3). [pmid: 11431190].
476 Richardson D, Ford D, Gilg J, Williams AJ. UK Renal Registry 11th Annual Report (December 2008): Chapter 9 Haemoglobin, ferritin and erythropoietin amongst patients receiving dialysis in the UK in 2007: national and centre-specific analyses. Nephron. Suppl 1. 2009;111:c149-83. registry data—incidence of renal anemia in UK; no relevant Dx or Tx information. [pmid: 19542697].
477 Riedel MK, Morgenstern T. Iron replacement in hemodialysis patients with a normal serum ferritin level. [German]. Dtsch Med Wochenschr. 2004;129(36):1849-53. Sep. 3. Not test-directed Tx (KQ3). [pmid: 15368155].
478 Rigden SP, Montini G, Morris M, Clark KG, Haycock GB, Chantler C, Hill RC. Recombinant human erythropoietin therapy in children maintained by haemodialysis. Pediatr Nephrol. 1990;4(6):618-22. Nov. Analytic validity data for older markers only. [pmid: 2088464].
479 Rodrigues A, Ortega C, Santos L, Teixeira A, Dinis MJ, Vasconcelos I, Lacerda J, Fonseca E. Clinical utility of Beckman-Coulter Gen’s reticulocyte analysis in the study of anemia of chronic disease (ACD). Lab Hematol. 2007;13(3):85-92. Non-CKD population. [pmid: 17984039].
480 Roger SD, Cooper B. What is the practical conversion dose when changing from epoetin alfa to darbepoetin outside of clinical trials?. Nephrology. 2004;9(4):223-8. Aug. Single arm Tx cohort (KQ3); Not biomarkers of interest—older markers only & Analytical validity data only (KQ2). [pmid: 15363054].
481 Romanova LA, Lugovskaia SA, Shutov EV, Shmarov DA, Korovina VI, Gorodnicheva VF, Kozinets GI. Evaluation of changes in erythrocyte functions and iron metabolism in patients with chronic renal failure treated by peritoneal dialysis. [Russian]. Klin Lab Diagn. 33. 2001;(6):24-6. Jun. Russian; appears to be analytical validity data only (KQ2). [pmid: 11521593].
482 Romero R, Novoa D, Otero S, Alonso MC, Alonso R, Arcocha V, Arza D, Lens XM, Sanchez-Guisande D. Direct effect of deferoxamine on hemoglobin synthesis in patients on hemodialysis treated with recombinant human erythropoietin. Nephron. 1993;63(2):164-7. N<10; Single arm Tx cohort (KQ3); Not biomarkers of interest—older markers only. [pmid: 8450906].
483 Rosenlof K, Fyhrquist F, Tenhunen R. Erythropoietin, aluminium, and anaemia in patients on haemodialysis. Lancet. 1990;335(8684):247-9. Feb. 3. Single arm Tx cohort (KQ3); Analytical validity data only (KQ2). [pmid: 1967718].
484 Rosenlof K, Gronhagen-Riska C, Sovijarvi A, Honkanen E, Tikkanen I, Ekstrand A, Piirila P, Fyhrquist F. Beneficial effects of erythropoietin on haematological parameters, aerobic capacity, and body fluid composition in patients on haemodialysis. J Intern Med. 1989;226(5):311-7. Nov. Single arm Tx cohort (KQ3); Not biomarkers of interest—older markers only; Analytical validity data only (KQ2). [pmid: 2809506].
485 Rosenlof K, Kivivuori SM, Gronhagen-Riska C, Teppo AM, Slimes MA. Iron availability is transiently improved by intravenous iron medication in patients on chronic hemodialysis. Clin Nephrol. 1995;43(4):249-55. Apr. Single arm Tx cohort (KQ3); Analytical validity data only (KQ2). [pmid: 7606879].
486 Rossi E, Serventi G, Venturini A, Arisi L, Bignardi L, Garini G, Savazzi G, Cambi V. Oral and i.v. iron therapy in haemodialysis patients (author’s transl). [Italian]. Ateneo Parmense Acta Biomed. 1976;47(1):33-46. Jan–Feb. Not biomarkers of interest—older markers only & Analytical validity data only (KQ2). [pmid: 1016270].
487 Ruiz-Jaramillo ML, Guizar-Mendoza JM, Gutierrez-Navarro MJ, Dubey-Ortega LA, mador-Licona N. Intermittent versus maintenance iron therapy in children on hemodialysis: a randomized study. Pediatr Nephrol. 2004;19(1):77-81. Jan. Comparison of Different cutoffs. [pmid: 14634860].
488 Rutkowski B, bska-Slizien A, Biedunkiewicz B, Bullo B. Importance of iron status monitoring during erythropoietin treatment in uremic predialysis patients. Ann Univ Mariae Curie Sklodowska [Med]. Suppl 3. 1994;48:17-21. Single arm Tx cohort (KQ3); Analytical validity data only (KQ2). [pmid: 8192528].
489 Saito M, Tsuchiya K, Ando M, Akiba T, Nihei H. Measuring the content of reticulocyte hemoglobin (CHr) in predialysis chronic renal failure (CRF) patients. [Japanese]. Nippon Jinzo Gakkai Shi. 2003;45(5):430-8. Jul. Japanese; appears to be analytical validity data only (KQ2)—confirmed by Teruhiko. [pmid: 14509218].
490 Salahudeen AK, Fleischmann E, Ahmed A, Bower JD. Anemia and iron target realization in 1998: clinical management of anemia in 1, 639 patients on hemodialysis. ASAIO J. 2001;47(5):511-5. Sep–Oct. Single arm Tx cohort (KQ3); Not biomarkers of interest—older markers only & Analytical validity data only (KQ2). [pmid: 11575828].
491 Saltissi D, Coles GA, Napier JA, Bentley P. The hematological response to continuous ambulatory peritoneal dialysis. Clin Nephrol. 1984;22(1):21-7. Jul. Single arm Tx cohort (KQ3); Not biomarkers of interest. [pmid: 6478659].
492 Saltissi D, Sauvage D, Westhuyzen J. Comparative response to single or divided doses of parenteral iron for functional iron deficiency in hemodialysis patients receiving erythropoietin (EPO). Clin Nephrol. 1998;49(1):45-8. Jan. Not test-directed Tx (KQ3). [pmid: 9491286].
493 Sancho A, Pastor MC, Troya M, Bonal J, Bayes B, Morales-Indiano C, Lauzurica R, Romero R. Hepcidin and iron deficiency in pre-kidney transplant patients. Transplant Proc. 2009;41(6):2079-81. Jul–Aug. Only comparison of mean values between older and newer biomarkers (KQ2). [pmid: 19715836].
494 Schaefer RM, Kuerner B, Zech M, Denninger G, Borneff C, Heidland A. Treatment of the anemia of hemodialysis patients with recombinant human erythropoietin. Int J Artif Organs. 1988;11(4):249-54. Jul. Single arm Tx cohort (KQ3); Not biomarkers of interest—older markers only & Analytical validity data only (KQ2). [pmid: 3410565].
495 Scheiber-Mojdehkar B, Lutzky B, Schaufler R, Sturm B, Goldenberg H. Non-transferrin-bound iron in the serum of hemodialysis patients who receive ferric saccharate: no correlation to peroxide generation. J Am Soc Nephrol. 2004;15(6):1648-55. Jun. Single arm Tx cohort (KQ3); Not biomarkers of interest. [pmid: 15153577].
496 Schiesser D, Binet I, Tsinalis D, Dickenmann M, Keusch G, Schmidli M, Ambuhl PM, Luthi L, Wuthrich RP. Weekly low-dose treatment with intravenous iron sucrose maintains iron status and decreases epoetin requirement in iron-replete haemodialysis patients. Nephrol Dial Transplant. 2006;21(10):2841-5. Oct. Not test-directed Tx (KQ3). [pmid: 16891647].
497 Scigalla P, Bonzel KE, Bulla M, Burghard R, Dippel J, Geisert J, Leumann E, von LT, Muller-Wiefel DE, Offner G. Therapy of renal anemia with recombinant human erythropoietin in children with end-stage renal disease. Contrib Nephrol. discussion 240–1. 1989;76:227-40. Single arm Tx cohort (KQ3); No Dx information. [pmid: 2684524].
498 Seguchi C, Shima T, Misaki M, Takarada Y, Okazaki T. Serum erythropoietin concentrations and iron status in patients on chronic hemodialysis. Clin Chem. 1992;38(2):199-203. Feb. not a biomarker of inoterest. [pmid: 1541000].
499 Seguias LF, Zilleruelo G. Transferrin saturation in pediatric hemodialysis. Pediatr Nephrol. 1998;12(7):618. Sep. Single arm Tx cohort (KQ3); Not biomarkers of interest—older markers only & Analytical validity data only (KQ2). [pmid: 9761366].
500 Seligman PA, Dahl NV, Strobos J, Kimko HC, Schleicher RB, Jones M, Ducharme MP. Single-dose pharmacokinetics of sodium ferric gluconate complex in iron-deficient subjects. Pharmacotherapy. 2004;24(5):574-83. May. Non CKD patients. [pmid: 15162891].
501 Sepandj F, Jindal K, West M, Hirsch D. Economic appraisal of maintenance parenteral iron administration in treatment of anaemia in chronic haemodialysis patients. Nephrol Dial Transplant. 1996;11(2):319-22. Feb. Single arm Tx cohort (KQ3). [pmid: 8671786].
502 Serra A, Morlans M, Olmos A, Camps J, Rodriguez JA, Carreras A, Soriano B, Bartolome J, Piera L. Evaluation of iron therapy in patients in long-term haemodialysis (author’s transl). [Spanish]. Med Clin (Barc). 1982;78(8):313-7. Apr. 16. S Ferritin is used as cutoff for gp 1 & II. [pmid: 7087599].
503 Sezer MT, Akin H, Demir M, Erturk J, Aydin ZD, Savik E, Tunc N. The effect of serum albumin level on iron-induced oxidative stress in chronic renal failure patients. JN, J. nephrol. 2007;20(2):196-203. Mar–Apr. Analytic validity data only. [pmid: 17514624].
504 Sezer S, Ozdemir FN, Yakupoglu U, Arat Z, Turan M, Haberal M. Intravenous ascorbic acid administration for erythropoietin-hyporesponsive anemia in iron loaded hemodialysis patients. Artif Organs. 2002;26(4):366-70. Apr. Analytic validity data only (KQ2). [pmid: 11952508].
505 Shah H, Shukla A, Krishnan A, Pliakogiannis T, Ahmad M, Bargman JM, Oreopoulos DG. Intravenous iron does not affect the rate of decline of residual renal function in patients on peritoneal dialysis. Adv Perit Dial. 2006;22:99-103. Single arm treatment cohort and analytic validity data for older markers only. [pmid: 16983949].
506 Shahrbanoo K, Taziki O. Effect of intravenous ascorbic acid in hemodialysis patients with anemia and hyperferritinemia. Saudi J Kidney Dis Transpl. 2008;19(6):933-6. Nov. Only older markers compared with analytic validity data only (does coefficient of variation matter?). [pmid: 18974579].
507 Sharma A, Vanderhalt K, Ryan KJ, Sclafani J. Refining the approach to IV iron use in hemodialysis patients: a post-DRIVE analysis. Nephrol News Issues. 29. 35. 2010;24(4):22-6. Apr. Just one biomarker discussed (ferritin) with no comparison with another in terms of influencing treatment. [pmid: 20458992].
508 Sheashaa H, El-Husseini A, Sabry A, Hassan N, Salem A, Khalil A, El-Agroudy A, Sobh M. Parenteral iron therapy in treatment of anemia in end-stage renal disease patients: a comparative study between iron saccharate and gluconate. Nephron. 2005;99(4):c97-101. Analytic validity data for older markers only. [pmid: 15692217].
509 Shinzato T, Abe K, Furusu A, Harada T, Shinzato K, Miyazaki M, Kohno S. Serum pro-hepcidin level and iron homeostasis in Japanese dialysis patients with erythropoietin (EPO)-resistant anemia. Med Sci Monit. 2008;14(9):CR431-7. Sep. No comparison between markers. [pmid: 18758412].
510 Short AI, Winney RJ. Red cell indices and iron stores in patients undergoing haemodialysis. Br Med J (Clin Res Ed). 1981;283(6290):562. Aug. 22. Letter. [pmid: 6790077].
511 Shostka GD. Iron absorption in patients with chronic renal failure. [Russian]. Urol Nefrol (Mosk). 1987;(6):42-5. Nov–Dec. Correlations given?. [pmid: 3438949].
512 Shostka GD. Role of hemodialysis, hemorrhage and treatment of renal failure in the development of anemia. [Russian]. Ter Arkh. 1981;53(6):52-6. Not biomarkers of interest—older markers only & Analytical validity data only (KQ2). [pmid: 7281033].
513 Siga E, Aiziczon D, Diaz G. Optimizing iron therapy in hemodialysis: a prospective long term clinical study. [Spanish]. Medicina (B Aires). 2011;71(1):9-14. Analytic validity data only (KQ2). [pmid: 21296714].
514 Siimes MA, Ronnholm KA, Antikainen M, Holmberg C. Factors limiting the erythropoietin response in rapidly growing infants with congenital nephrosis on a peritoneal dialysis regimen after nephrectomy. J Pediatr. 1992;120(1):44-8. Jan. Single arm treatment cohort and analytic validity data for older markers only. [pmid: 1731023].
515 Siimes MA. Significance of serum ferritin determinations. [Finnish]. Duodecim. 1981;97(7):371-3. narrative review. [pmid: 7274110].
516 Silva FJ, Andrade S, Aguilar L, Ribeiro O, Salgadinho MA, Simoes J. Ferritin in patients under dialysis. [Portuguese]. Acta Med Port. 1986;7(1):35-9. Jan–Feb. Analytic validity data for older marker only. [pmid: 3728079].
517 Silverberg DS, Blum M, Agbaria Z, Deutsch V, Irony M, Schwartz D, Baruch R, Yachnin T, Steinbruch S, Iaina A. The effect of i.v. iron alone or in combination with low-dose erythropoietin in the rapid correction of anemia of chronic renal failure in the predialysis period. Clin Nephrol. 2001;55(3):212-9. Mar. Analytic validity data (KQ2). [pmid: 11316241].
518 Silverberg DS, Blum M, Peer G, Kaplan E, Iaina A. Intravenous ferric saccharate as an iron supplement in dialysis patients. Nephron. 1996;72(3):413-7. Analytic validity data only. [pmid: 8852489].
519 Silverberg DS, Iaina A, Peer G, Kaplan E, Levi BA, Frank N, Steinbruch S, Blum M. Intravenous iron supplementation for the treatment of the anemia of moderate to severe chronic renal failure patients not receiving dialysis. Am J Kidney Dis. 1996;27(2):234-8. Feb. Analytic validity data only. [pmid: 8659499].
520 Singh A, Patel T, Hertel J, Bernardo M, Kausz A, Brenner L. Safety of ferumoxytol in patients with anemia and CKD. Am J Kidney Dis. 2008;52(5):907-15. Nov. Only older markers studied in terms of mean values. No comparison of older with newer marker. [pmid: 18824288].
521 Singh AK, Szczech L, Tang KL, Barnhart H, Sapp S, Wolfson M, Reddan D. CHOIR I. Correction of anemia with epoetin alfa in chronic kidney disease. N Engl J Med. 2006;355(20):2085-98. Nov. 16. CHOIR study; Not test-directed Tx based on our tests of interest. [pmid: 17108343].
522 Singh H, Reed J, Noble S, Cangiano JL, Van Wyck DB. United States Iron Sucrose (Venofer) Clinical Trials Group. Effect of intravenous iron sucrose in peritoneal dialysis patients who receive erythropoiesis-stimulating agents for anemia: a randomized, controlled trial. Clin J Am Soc Nephrol. 2006;1(3):475-82. May. Not test-directed Tx. [pmid: 17699248].
523 Singh NP, Aggarwal L, Singh T, Anuradha S, Kohli R. Anaemia, iron studies and erythropoietin in patients of chronic renal failure. J Assoc Physicians India. 1999;47(3):284-90. Mar. Analytic validity data for older markers only. [pmid: 10999121].
524 Sinha S, Chiu D, Peebles G, Swoboda P, Kolakkat S, Lamerton E, Fenwick S, Bhandari S, Kalra PA. Accelerated total dose infusion of low molecular weight iron dextran is safe and efficacious in chronic kidney disease patients. QJM. 2011;104(3):221-30. Mar. Analytic validity data for older markers only. [pmid: 20956457].
525 Sinha S, Chiu DY, Peebles G, Kolakkat S, Lamerton E, Fenwick S, Kalra PA. Comparison of intravenous iron sucrose versus low-molecular-weight iron dextran in chronic kidney disease. J ren care. 2009;35(2):67-73. Jun. Analytic validity data for older markers only. [pmid: 19432851].
526 Sirover WD, Siddiqui AA, Benz RL. Beneficial hematologic effects of daily oral ascorbic acid therapy in ESRD patients with anemia and abnormal iron homeostasis: a preliminary study. Ren Fail. 2008;30(9):884-9. Only older markers studied in terms of analytic validity. [pmid: 18925528].
527 Skikne BS, Ahluwalia N, Fergusson B, Chonko A, Cook JD. Effects of erythropoietin therapy on iron absorption in chronic renal failure. J Lab Clin Med. 2000;135(6):452-8. Jun. Single arm Tx cohort (KQ3). [pmid: 10850644].
528 Sloand JA, Shelly MA, Erenstone AL, Schiff MJ, Talley TE, Dhakal MP. Safety and efficacy of total dose iron dextran administration in patients on home renal replacement therapies. Perit Dial Int. 1998;18(5):522-7. Sep–Oct. Single arm treatment cohort and analytic validity data only. [pmid: 9848632].
529 Sobota JT. Recombinant human erythropoietin in patients with anemia due to end-stage renal disease. US multicenter trials. Contrib Nephrol. discussion 212–8. 1989;76:166-78. Treatment not dependent on markers and comparison of markers. [pmid: 2684519].
530 Soffritti S, Russo G, Cantelli S, Gilli G, Catizone L. Maintaining over time clinical performance targets on anaemia correction in unselected population on chronic dialysis at 20 Italian centres. Data from a retrospective study for a clinical audit. BMC Nephrol. 2009;10:33. Only analytic validity (mean values of biomarkers) seen. [pmid: 19852833].
531 Soininen K, Punnonen K, Matinlauri I, Karhapaa P, Rehu M. Transferrin receptor expression on reticulocytes as a marker of iron status in dialyzed patients. Clin Chem Lab Med. 2010;48(9):1239-45. Sep. Analytic validity data only (for KQ2). [pmid: 20604729].
532 Sorbie J, Olatunbosun D, Corbett WE, Valberg LS. Cobalt excretion test for the assessment of body iron stores. Can Med Assoc J. 1971;104(9):777-82. May. 8. No CKD population. [pmid: 5578125].
533 Sotirakopoulos N, Athanasiou G, Tsitsios T, Mavromatidis K. The influence of l-carnitine supplementation on hematocrit and hemoglobin levels in patients with end stage renal failure on CAPD. Ren Fail. 2002;24(4):505-10. Jul. No comparison between markers and treatment is not dependent on markers. Newer marker ferrum. [pmid: 12212830].
534 Souqiyyeh MZ, Shaheen FA. Attitude of physicians towards iron supplementation in hemodialysis patients treated with erythropoietin. Saudi J Kidney Dis Transpl. 2003;14(2):134-44. Apr–Jun. Not a direct study but a questionnaire. [pmid: 18209438].
535 Spiegel DM. Hemoglobin variability in chronic kidney disease: a cross-sectional study. Am J Med Sci. 2009;337(5):340-3. May. No marker used and treatment is not dependent on marker. [pmid: 19295412].
536 Spinowitz BS, Kausz AT, Baptista J, Noble SD, Sothinathan R, Bernardo MV, Brenner L, Pereira BJ. Ferumoxytol for treating iron deficiency anemia in CKD. J Am Soc Nephrol. 2008;19(8):1599-605. Aug. No comparison between older and newer markers but only older markers mean levels studied with respect to two different treatments. [pmid: 18525001].
537 Spinowitz BS, Schwenk MH, Jacobs PM, Bolton WK, Kaplan MR, Charytan C, Galler M. The safety and efficacy of ferumoxytol therapy in anemic chronic kidney disease patients. Kidney Int. 2005;68(4):1801-7. Oct. Not test-directed Tx. [pmid: 16164657].
538 Stancu S, Barsan L, Stanciu A, Mircescu G. Can the response to iron therapy be predicted in anemic nondialysis patients with chronic kidney disease?. [Erratum appears in Clin J Am Soc Nephrol. 2010 Nov;5(11):2137–8]. Clin J Am Soc Nephrol. 2010;5(3):409-16. Mar. Sensitivity, specificity and predictive values comparison only between older markers. [pmid: 20019121].
539 Stancu S, Stanciu A, Zugravu A, Barsan L, Dumitru D, Lipan M, Mircescu G. Bone marrow iron, iron indices, and the response to intravenous iron in patients with non-dialysis-dependent CKD. [Erratum appears in Am J Kidney Dis. 2010 Nov;5(11):2137–8]. Am J Kidney Dis. 2010;55(4):639-47. Apr. Sensitivity and specificity comparison only between older markers. [pmid: 20079959].
540 Starklint J, Bech JN, Aagaard O, Pedersen EB. Hypochromic reticulocytes, hypochromic erythrocytes and p-transferrin receptors in diagnosing iron-deficient erythropoiesis. Scand J Clin Lab Invest. 2004;64(8):691-702. Analytic validity data only (KQ2). [pmid: 15719887].
541 Starklint J. The diagnostic value of hypochrome reticulocytes, hypochrome erythrocytes and serum-transferrin receptors in detecting iron deficient erythropoiesis in haemodialysis patients and healthy volunteers. [abstract]. Nephrology Dialysis Transplantation. Suppl 4. 2003;18:414-415.
542 Stoves J, Inglis H, Newstead CG. A randomized study of oral vs intravenous iron supplementation in patients with progressive renal insufficiency treated with erythropoietin. Nephrol Dial Transplant. 2001;16(5):967-74. May. not test-directed Tx. [pmid: 11328902].
543 Streja E, Kovesdy CP, Greenland S, Kopple JD, McAllister CJ, Nissenson AR, Kalantar-Zadeh K. Erythropoietin, iron depletion, and relative thrombocytosis: a possible explanation for hemoglobin-survival paradox in hemodialysis. Am J Kidney Dis. 2008;52(4):727-36. Oct. Only analytic validity data. ISAT newer marker used. [pmid: 18760517].
544 Strenev FV. Changes in the work capacity of patients with iron-deficiency anemia as affected by short-term therapy with iron preparations. [Russian]. Gematol Transfuziol. 1988;33(2):35-7. Feb. Non CKD patients. [pmid: 3371641].
545 Strickland ID, Chaput de Saintonge DM, Boulton FE, Brain AJ, Goodwin FJ, Marsh FP, Zychova Z. A trial of oral iron in dialysis patients. Clin Nephrol. 1974;2(1):13-7. Jan–Feb. Analytic validity data for older markers only. [pmid: 4595978].
546 Strickland ID, Chaput de Saintonge DM, Boulton FE, Francis B, Roubikova J, Waters JI. The therapeutic equivalence of oral and intravenous iron in renal dialysis patients. Clin Nephrol. 1977;7(2):55-7. Feb. Analytic validity data for older markers only. [pmid: 321170].
547 Sulowicz W, Drozdz M, Hanicki Z, Krasniak A, Kuzniewski M. Effect of recombinant human erythropoietin (rHu-EPO) on anemia and selected biochemical parameters in patients in the pre-dialysis period. [Polish]. Przegl Lek. 1992;49(1–2):50-3. n<10. [pmid: 1455007].
548 Summers MR, Jacobs A. Iron uptake and ferritin synthesis by peripheral blood leucocytes from normal subjects and patients with iron deficiency and the anaemia of chronic disease. Br J Haematol. 1976;34(2):221-9. Oct. Non CKD patients. [pmid: 974035].
549 Sunder-Plassmann G, Horl WH. Importance of iron supply for erythropoietin therapy. Nephrol Dial Transplant. 1995;10(11):2070-6. Nov. No PDF. [pmid: 8643170].
550 Sunder-Plassmann G, Horl WH. Safety of intravenous injection of iron saccharate in haemodialysis patients. Nephrol Dial Transplant. 1996;11(9):1797-802. Sep. Single arm treatment cohort and analytic validity data for older markers only. [pmid: 8918625].
551 Sungur C, Akpolat T, Ozdemir O, Ozcebe O, Yasavul U, Turgan C, Caglar S. Hematologic profile of dialysis patients receiving alpha-interferon and erythropoietin concomitantly. Nephron. 499. 67(4):1994. n<10. [pmid: 7969693].
552 Svara F, Sulkova S, Kvasnicka J, Polakovic V. Iron supplementation during erythropoietin therapy in patients on hemodialysis. [Czech]. Vnitr Lek. 1996;42(12):849-52. Dec. Analytic validity data for older markers only. [pmid: 9072885].
553 Svara F. Iron supplementation during erythropoietin treatment of haemodialyzed patients. Vnitrni Lekarstvi. 1996;42(12):849-852. Analytic validity data for older markers only. [pmid: 9072885].
554 Swedberg B. A clinical investigation of an iron-poly (sorbitol-gluconic acid) complex, Ferastral, for the treatment of iron deficiency anaemia. Scand J Haematol Suppl. 1977;32:260-8. Non CKD patients. [pmid: 341281].
555 Sweeney JD, Spencer R, Donohoe JD, Carmody M, O’Dwyer WF. The evaluation of iron status in non-dialysis dependent renal failure. Ir Med J. 1981;74(11):334-8. Nov. Not biomarkers of interest—older markers only & Analytical validity data only (KQ2). [pmid: 7309460].
556 Szczech LA, Barnhart HX, Sapp S, Felker GM, Hernandez A, Reddan D, Califf RM, Inrig JK, Patel UD, Singh AK. A secondary analysis of the CHOIR trial shows that comorbid conditions differentially affect outcomes during anemia treatment. Kidney Int. 2010;77(3):239-46. Feb. Treatment fixed and not based on biomarker. [pmid: 19890274].
557 Szczech LA, Bregman DB, Harrington RA, Morris D, Butcher A, Koch TA, Goodnough LT, Wolf M, Onken JE. Randomized evaluation of efficacy and safety of ferric carboxymaltose in patients with iron deficiency anaemia and impaired renal function (REPAIR-IDA): rationale and study design. Nephrol Dial Transplant. 2010;25(7):2368-75. Jul. Treatment is not based on biomarker. [pmid: 20466657].
558 Tabernero Romo JM, Rodriguez Commes JL, ias Nunez JF, Corbacho BL, Bondia RA, Sanchez MS, Juanes A, Talavera JR, De CS. Iron metabolism in chronic renal failure (author’s transl). [Spanish]. Sangre (Barc). 1980;25(5B):657-64. Analytical validity data only (KQ2). [pmid: 7466549].
559 Taes YE, Wuyts B, Boelaert JR, De Vriese AS, Delanghe JR. Prohepcidin accumulates in renal insufficiency. Clin Chem Lab Med. 2004;42(4):387-9. Apr. Analytic validity data only (for KQ2). [pmid: 15147148].
560 Tagboto S, Cropper L, Mostafa S, Turner J, Bailey G, Pugh-Clarke K. Intravenous iron in chronic kidney disease: haemoglobin change shortly after treatment of patients neither on dialysis nor on erythropoietin. J. ren. care. 2008;34(3):112-5. Sep. Not biomarkers of interest—older markers only & Analytical validity data only (KQ2). [pmid: 18786076].
561 Talwar VK, Gupta HL, Shashinarayan. Clinicohaematological profile in chronic renal failure. J Assoc Physicians India. 2002;50:228-33. Feb. Analytic validity data for older markers only. [pmid: 12038654].
562 Tanaka H, Kan E, Takegaki Y, Inariba H, Yoshimoto M, Ohno Y, Maekawa M, Tatsumi N, Kishimoto T. Multicenter study with recombinant human erythropoietin. Artif Organs. 1993;17(4):213-8. Apr. Treatment no dependent on markers and analytic validity data for older markers. [pmid: 8498899].
563 Tangri N, Stevens LA, Griffith J, Tighiouart H, Djurdjev O, Naimark D, Levin A, Levey AS. A predictive model for progression of chronic kidney disease to kidney failure. JAMA. 2011;305(15):1553-9. Apr. 20. No biomarker of interest. [pmid: 21482743].
564 Taralov Z, Koumtchev E, Lyutakova Z. Erythrocyte ferritin levels in chronic renal failure patients. Folia Med (Plovdiv). 1998;40(4):65-70. New marker erythrocyte ferritin and analytic validity data for markers. [pmid: 10371803].
565 Tarng DC, Chen TW, Huang TP. Iron metabolism indices for early prediction of the response and resistance to erythropoietin therapy in maintenance hemodialysis patients. Am J Nephrol. 1995;15(3):230-7. Treatment not dependent on markers and analytic validity data for older markers only. [pmid: 7618648].
566 Tarng DC, Huang TP, Chen TW. Mathematical approach for estimating iron needs in hemodialysis patients on erythropoietin therapy. Am J Nephrol. 1997;17(2):158-64. Analytic validity data for older markers only. [pmid: 9096447].
567 Tarng DC, Huang TP. A parallel, comparative study of intravenous iron versus intravenous ascorbic acid for erythropoietin-hyporesponsive anaemia in haemodialysis patients with iron overload. Nephrol Dial Transplant. 1998;13(11):2867-72. Nov. not test-directed Tx. [pmid: 9829492].
568 Tarng DC, Huang TP. Determinants of circulating soluble transferrin receptor level in chronic haemodialysis patients. Nephrol Dial Transplant. 2002;17(6):1063-9. Jun. Analytic validity data only (for KQ2). [pmid: 12032198].
569 Tatsumi N, Kojima K, Tsuda I, Yamagami S, Itoh Y, Tanaka H. Reticulocyte count used to assess recombinant human erythropoietin sensitivity in hemodialysis patients. Contrib Nephrol. 1990;82:41-8. No marker of interest studied. [pmid: 2093525].
570 Taylor JE, Belch JJ, Fleming LW, Mactier RA, Henderson IS, Stewart WK. Erythropoietin response and route of administration. Clin Nephrol. 1994;41(5):297-302. May. Treatment no dependent on markers and only one marker studied. [pmid: 8050210].
571 Taylor JE, Peat N, Porter C, Morgan AG. Regular low-dose intravenous iron therapy improves response to erythropoietin in haemodialysis patients. Nephrol Dial Transplant. 1996;11(6):1079-83. Jun. Single arm Tx cohort (KQ3). [pmid: 8671972].
572 Teehan GS, Bahdouch D, Ruthazer R, Balakrishnan VS, Snydman DR, Jaber BL. Iron storage indices: novel predictors of bacteremia in hemodialysis patients initiating intravenous iron therapy. Clin Infect Dis. 2004;38(8):1090-4. Apr. 15. Treatment fixed and analytic validity data for older markers. [pmid: 15095212].
573 Tenbrock K, Muller-Berghaus J, Michalk D, Querfeld U. Intravenous iron treatment of renal anemia in children on hemodialysis. Pediatr Nephrol. 1999;13(7):580-2. Sep. Single arm treatment cohort and only older markers studied. [pmid: 10460505].
574 Teruel JL, Marcen R, Navarro JF, Villafruela JJ, Fernandez LM, Rivera M, Ortuno J. Influence of body iron stores on the serum erythropoietin concentration in hemodialyzed patients. Am J Nephrol. 1994;14(2):95-8. Only one marker studied. [pmid: 8080013].
575 Theodoridis M, Passadakis P, Kriki P, Panagoutsos S, Yannatos E, Kantartzi K, Sivridis D, Vargemezis V. Efficient monthly subcutaneous administration of darbepoetin in stable CAPD patients. Perit Dial Int. 2005;25(6):564-9. Nov–Dec. Single arm Tx cohort (KQ3). [pmid: 16411523].
576 Thitiarchakul S, Tasanarong A. 12-week clinical effects of erythropoietin espogen in end stage renal patients undergoing hemodialysis. J Med Assoc Thai. 2007;90(4):636-42. Apr. Not biomarkers of interest—older markers only & Analytical validity data only (KQ2). [pmid: 17487116].
577 Thomas C, Kobold U, Thomas L. Serum hepcidin-25 in comparison to biochemical markers and hematological indices for the differentiation of iron-restricted erythropoiesis. Clin Chem Lab Med. 2011;49(2):207-13. Feb. Analytic validity data (KQ2). In terms of ROC analysis, newer marker to newer marker comparison made. [pmid: 21143009].
578 Thomas C, Thomas L. Biochemical markers and hematologic indices in the diagnosis of functional iron deficiency. Clin Chem. 2002;48(7):1066-76. Jul. non CKD-patienots. [pmid: 12089176].
579 Tielemans CL, Lenclud CM, Wens R, Collart FE, Dratwa M. Critical role of iron overload in the increased susceptibility of haemodialysis patients to bacterial infections. Beneficial effects of desferrioxamine. Nephrol Dial Transplant. 1989;4(10):883-7. Not biomarkers of interest—older markers only (KQ2). [pmid: 2515493].
580 Tonbul HZ, Kaya H, Selcuk NY, Tekin SB, San A, Akcay F, Akarsu E. The importance of serum transferrin receptor level in the diagnosis of functional iron deficiency due to recombinant human erythropoietin treatment in haemodialysis patients. Int Urol Nephrol. 1998;30(5):645-51. Analytical validity data only (KQ2). [pmid: 9934812].
581 Tonelli M, Blake PG, Muirhead N. Predictors of erythropoietin responsiveness in chronic hemodialysis patients. ASAIO J. 2001;47(1):82-5. Jan–Feb. Not biomarkers of interest—older markers only (KQ2). [pmid: 11199321].
582 Tovbin D, Mazor D, Vorobiov M, Chaimovitz C, Meyerstein N. Induction of protein oxidation by intravenous iron in hemodialysis patients: role of inflammation. Am J Kidney Dis. 2002;40(5):1005-12. Nov. Not biomarkers of interest (KQ2). [pmid: 12407646].
583 Trakarnvanich T, Thitiarcharkul S. Comparison between intravenous recombinant human erythropoietin and subcutaneous injection in Thai hemodialysis patients. J Med Assoc Thai. 2004;87(9):1041-7. Sep. Not biomarkers of interest—older markers only (KQ2). [pmid: 15516004].
584 Triolo G, Canavese C, Di GS. Reasons for producing guidelines on anemia of chronic renal failure: dialysis outcome quality initiative of the National Kidney Foundation. Int J Artif Organs. 1998;21(11):751-6. Nov. Guidelines. [pmid: 9894755].
585 Trivedi HS, Brooks BJ. Erythropoietin therapy in pre-dialysis patients with chronic renal failure: lack of need for parenteral iron. Am J Nephrol. 2003;23(2):78-85. Mar–Apr. Not biomarkers of interest—older markers only & Analytical validity data only (KQ2). [pmid: 12481145].
586 Tsai JC, Lai YH, Tsai ZY, Chien LJ, Tsai JH. Clinical efficacy of recombinant human erythropoietin in the treatment of anemia in hemodialysis patients: influence of dosing regimen, iron status, and serum aluminum. Gaoxiong Yi Xue Ke Xue Za Zhi. 1991;7(3):126-35. Mar. Not biomarkers of interest—older markers only & Analytical validity data only (KQ2). [pmid: 1865507].
587 Tsuchihashi D, Abe T, Komaba H, Fujii H, Hamada Y, Nii-Kono T, Tanaka M, Fukagawa M. Serum pro-hepcidin as an indicator of iron status in dialysis patients. Therap Apher Dial. 2008;12(3):226-31. Jun. Analytic validity data only (KQ2). [pmid: 18503700].
588 Tsuchiya K, Saito M, Okano-Sugiyama H, Nihei H, Ando M, Teramura M, Iwamoto YS, Shimada K, Akiba T. Monitoring the content of reticulocyte hemoglobin (CHr) as the progression of anemia in nondialysis chronic renal failure (CRF) patients. Ren Fail. 2005;27(1):59-65. Analytical validity data only (KQ2). [pmid: 15717636].
589 Tsung SH, Rosenthal WA, Milewski KA. Immunological measurement of transferrin compared with chemical measurement of total iron-binding capacity. Clin Chem. 1975;21(8):1063-6. Jul. non-CKD population. [pmid: 1137910].
590 Urrechaga E. Clinical utility of the new Beckman-Coulter parameter red blood cell size factor in the study of erithropoiesis. Int J Lab Hematol. 2009;31(6):623-9. Dec. Population not of interest. [pmid: 18771498].
591 Urrechaga E. The new mature red cell parameter, low haemoglobin density of the Beckman-Coulter LH750: clinical utility in the diagnosis of iron deficiency. Int J Lab Hematol. 2010;32(1 Pt 1):e144-50. Feb. Sensitivity comparison only between two newer biomarkers, one of which is not listed in the protocol. [pmid: 19220525].
592 Valenti L, Girelli D, Valenti GF, Castagna A, Como G, Campostrini N, Rametta R, Dongiovanni P, Messa P, Fargion S. HFE mutations modulate the effect of iron on serum hepcidin-25 in chronic hemodialysis patients. Clin J Am Soc Nephrol. 2009;4(8):1331-7. Aug. Analytical validity data only (KQ2). [pmid: 19541813].
593 van d, Vanheule AA, Majelyne WM, D’Haese P, Blockx PP, Bekaert AB, Buyssens N, de KW, De Broe ME. Serum ferritin as a guide for iron stores in chronic hemodialysis patients. Kidney Int. 1984;26(4):451-8. Oct. Analytic validity data for older markers only. [pmid: 6527472].
594 van der PK, Jie KE, van den BD, Kraaijenhagen RJ, Laarakkers C, Swinkels DW, Braam B, Gaillard CA. Hepcidin-25 is a marker of the response rather than resistance to exogenous erythropoietin in chronic kidney disease/chronic heart failure patients. Eur J Heart Fail. 2010;12(9):943-50. Sep. Anlytic validity data only (for KQ2). [pmid: 20601671].
595 Van Wyck DB, Alcorn H, Gupta R. Analytical and biological variation in measures of anemia and iron status in patients treated with maintenance hemodialysis. Am J Kidney Dis. 2010;56(3):540-6. Sep. Single arm cohort study and analytic validity data only. [pmid: 20638166].
596 Van Wyck DB, Cavallo G, Spinowitz BS, Adhikarla R, Gagnon S, Charytan C, Levin N. Safety and efficacy of iron sucrose in patients sensitive to iron dextran: North American clinical trial. Am J Kidney Dis. 2000;36(1):88-97. Jul. Single arm Tx cohort (KQ3); No Dx information. [pmid: 10873877].
597 Van Wyck DB, Stivelman JC, Ruiz J, Kirlin LF, Katz MA, Ogden DA. Iron status in patients receiving erythropoietin for dialysis-associated anemia. Kidney Int. 1989;35(2):712-6. Feb. estimation of body iron reserves in EPO therapy. [pmid: 2709674].
598 van Zyl-Smit R, Halkett JA. Experience with the use of an iron polymaltose (dextrin) complex given by single total dose infusion to stable chronic haemodialysis patients. Nephron. 2002;92(2):316-23. Oct. Not biomarkers of interest—older markers only & Analytical validity data only (KQ2). [pmid: 12218309].
599 Vankova S, Safarova R, Horackova M, Herink J, Rychlik I, Bahbouh R, Putova I. Clinical and economic significance of iron replacement in anemia treated with recombinant human erythropoietin in patients on hemodialysis. [Czech]. Cas Lek Cesk. 2001;140(7):209-13. Apr. 12. Not biomarkers of interest—older markers only & Analytical validity data only (KQ2). [pmid: 11374225].
600 Vercaigne LM, Collins DM, Penner SB. Conversion from subcutaneous to intravenous erythropoietin in a hemodialysis population. J Clin Pharmacol. 2005;45(8):895-900. Aug. Single arm Tx cohorts (KQ3). [pmid: 16027399].
601 Vernet M, Doyen C. Assessment of iron status with a new fully automated assay for transferrin receptor in human serum. Clin Chem Lab Med. 2000;38(5):437-42. May. Non-CKD population. [pmid: 10952228].
602 Walker R, Pussell BA. Australian Renal Anaemia Group. Fluctuations in haemoglobin levels in haemodialysis, pre-dialysis and peritoneal dialysis patients receiving epoetin alpha or darbepoetin alpha. Nephrology. 2009;14(7):689-95. Oct. Not test-directed Tx (KQ3); no Dx information. [pmid: 19796029].
603 Wallerstedt SM, Ljungman S, Broms E, Andren L. Iron deficiency is a common cause of bad response to epoetin treatment. It’s important to follow iron status--not only the Hb value. [Swedish]. Lakartidningen. 2005;102(37):2550-1-2553-5. Sep. 12–18. Single arm Tx cohort (KQ3); No Dx information. [pmid: 16200900].
604 Warady BA, Kausz A, Lerner G, Brewer ED, Chadha V, Brugnara C, Dahl NV, Watkins SL. Iron therapy in the pediatric hemodialysis population. Pediatr Nephrol. 2004;19(6):655-61. Jun. Not test-directed Tx. [pmid: 15064942].
605 Warady BA, Seligman PA, Dahl NV. Single-dosage pharmacokinetics of sodium ferric gluconate complex in iron-deficient pediatric hemodialysis patients. Clin J Am Soc Nephrol. 2007;2(6):1140-6. Nov. No biomarker comparison and treatment fixed. [pmid: 17942782].
606 Warady BA, Zobrist RH, Finan E. Ferrlecit Pediatric Study Group. Sodium ferric gluconate complex maintenance therapy in children on hemodialysis. Pediatr Nephrol. 2006;21(4):553-60. Apr. Single arm Tx cohort (KQ3). [pmid: 16520948].
607 Warady BA, Zobrist RH, Wu J, Finan E. Ferrlecit Pediatric Study Group. Sodium ferric gluconate complex therapy in anemic children on hemodialysis. [Erratum appears in Pediatr Nephrol. 2005 Dec;20(12):1825]. Pediatr Nephrol. 2005;20(9):1320-7. Sep. Not test-directed Tx. [pmid: 15971073].
608 Weiss G, Theurl I, Eder S, Koppelstaetter C, Kurz K, Sonnweber T, Kobold U, Mayer G. Serum hepcidin concentration in chronic haemodialysis patients: associations and effects of dialysis, iron and erythropoietin therapy. Eur J Clin Invest. 2009;39(10):883-90. Oct. Analytic validity data only (KQ2). [pmid: 19563467].
609 Westerman MP, O’Donnell J, Bacus JW. Assessment of the anemia of chronic disease by digital image processing of erythrocytes. Am J Clin Pathol. 1980;74(2):163-6. Aug. non-CKD population; Not biomarkers of interest (KQ2);. [pmid: 7405894].
610 Wians FH, Urban JE, Keffer JH, Kroft SH. Discriminating between iron deficiency anemia and anemia of chronic disease using traditional indices of iron status vs transferrin receptor concentration. Am J Clin Pathol. 2001;115(1):112-8. Jan. While ROC information is available the it looks like most of the population is non-CKD. [pmid: 11190796].
611 Wiecek A, Franek E, Kokot F, Rudka R. Influence of acetate and bicarbonate hemodialysis on the plasma erythropoietin concentration in patients with chronic renal failure. Int J Artif Organs. 1997;20(2):108-11. Feb. Single arm Tx cohort (KQ3); Not biomarkers of interest—older markers only (KQ2). [pmid: 9093890].
612 Wiecek A, Kokot F, Grzeszczak W, Klin M. Treatment of anemia in patients with renal failure using erythropoietin obtained by genetic recombination. [Polish]. Pol Tyg Lek. 1990;45(38–39):782-6. Sep. 17–24. N<10; Single arm Tx cohort (KQ3); Not biomarkers of interest—older markers only & Analytical validity data only (KQ2). [pmid: 2095546].
613 Winkelmayer WC, Lorenz M, Kramar R, Horl WH, Sunder-Plassmann G. Percentage of hypochromic red blood cells is an independent risk factor for mortality in kidney transplant recipients. Am J Transplant. 2004;4(12):2075-81. Dec. Single arm tx cohort, outcome is mortality—if outcome were a diagnostic one, e.g. response to Tx then we would include for diagnostic odds ratios). [pmid: 15575912].
614 Wolff F, Mesquita M, Corazza F, Demulder A, Willems D. False positive carbohydrate-deficient transferrin results in chronic hemodialysis patients related to the analytical methodology. Clin Biochem. 2010;43(13–14):1148-51. Sep. The CDT biomarker discussed is not of interest. [pmid: 20599878].
615 Wu CJ, Lin HC, Lee KF, Chuang CK, Chen YC, Chen HH. Comparison of parenteral iron sucrose and ferric chloride during erythropoietin therapy of haemodialysis patients. Nephrology. 2010;15(1):42-7. Feb. No comparison between biomarkers influencing treatments. [pmid: 20377770].
616 Yagil Y. Proposed therapeutic algorithm for the treatment of anemia of chronic renal failure in pre-dialysis patients with low dose once weekly subcutaneous r-HuEPO. Multicenter Study Group, Israel. Isr J Med Sci. 1997;33(1):36-44. Jan. Single arm Tx cohort (KQ3); Not biomarkers of interest—older markers only & Analytical validity data only (KQ2). [pmid: 9203516].
617 Yavuz A, Akbas SH, Tuncer M, Kolagasi O, Cetinkaya R, Gurkan A, Demirbas A, Gultekin M, Akaydin M, Ersoy F, Yakupoglu G. Influence of inflammation on the relation between markers of iron deficiency in renal replacement therapy. Transplant Proc. 2004;36(1):41-3. Jan–Feb. Analytic validity data only (for KQ2). [pmid: 15013295].
618 Yong K, Kairaitis L. Effects of proactive iron and erythropoiesis-stimulating agent protocol implementation on achieving clinical guideline targets for anaemia in a satellite haemodialysis patient cohort. Nephrology. 2010;15(3):288-93. Apr. Single arm cohort and no comparison between newer and older markers. [pmid: 20470296].
619 Yorgin PD BA. Sodium ferric gluconate therapy in renal transplant and renal failure patients. Single arm Tx cohort (KQ3); No Dx information. [pmid: 11149105].
620 York S. Current perspectives: iron management during therapy with recombinant human erythropoietin. ANNA J. quiz 651–2. 1993;20(6):645-50. Dec. narrative review. [pmid: 8267408].
621 Zadrazil J, Bachleda P, Papajik T, Scudla V, Zahalkova J, Budikova M, Novotny D. Iron metabolism in patients in kidney failure dialysis treatment. [German]. Acta Univ Palacki Olomuc Fac Med. 1993;135:95-7. Not biomarkers of interest—older markers only & Analytical validity data only (KQ2). [pmid: 7976690].
622 Zadrazil J, Papajik T, Bachleda P, Budikova M, Novotny D, Scudla V. The role of iron deficiency on the development of anemia in patients on regular dialysis therapy. [Czech]. Vnitr Lek. 1994;40(6):362-6. Jun. Single arm Tx cohort (KQ3); No Dx information. [pmid: 8073646].
623 Zadrazil J, Papajik T, Scudla V, Jezakova J, Budikova M, Slavicek J. The iron reserve status in patients on regular dialysis treatment. [Czech]. Vnitr Lek. 1991;37(4):369-75. Apr. Not biomarkers of interest—older markers only & Analytical validity data only (KQ2). [pmid: 2053308].
624 Zanen AL, Adriaansen HJ, van Bommel EF, Posthuma R, Th de Jong GM. ‘Oversaturation’ of transferrin after intravenous ferric gluconate (Ferrlecit(R)) in haemodialysis patients. Nephrol Dial Transplant. 1996;11(5):820-4. May. not test-directed Tx. [pmid: 8671901].
625 Zaritsky J, Young B, Gales B, Wang HJ, Rastogi A, Westerman M, Nemeth E, Ganz T, Salusky IB. Reduction of serum hepcidin by hemodialysis in pediatric and adult patients. Clin J Am Soc Nephrol. 2010;5(6):1010-4. Jun. Analytic validity data only (for KQ2). [pmid: 20299375].
626 Zaritsky J, Young B, Wang HJ, Westerman M, Olbina G, Nemeth E, Ganz T, Rivera S, Nissenson AR, Salusky IB. Hepcidin--a potential novel biomarker for iron status in chronic kidney disease. Clin J Am Soc Nephrol. 2009;4(6):1051-6. Jun. Analytic validity data (KQ2). [pmid: 19406957].
627 Zehnder C, Blumberg A. Human recombinant erythropoietin treatment in transfusion dependent anemic patients on maintenance hemodialysis. Clin Nephrol. 1989;31(2):55-9. Feb. Single arm Tx cohort (KQ3); Not biomarkers of interest—older markers only & Analytical validity data only (KQ2). [pmid: 2920469].
628 Zelichowski G, Lubas A, Wankowicz Z. Effectiveness of subcutaneous and intravenous epoetin alpha in haemodialysed patients. [Polish]. Pol Merkuriusz Lek. 2004;17(98):143-7. Aug. Single arm Tx cohort (KQ3); Not biomarkers of interest—older markers only & Analytical validity data only (KQ2). [pmid: 15603323].
629 Zhang Y, Thamer M, Cotter D, Kaufman J, Hernan MA. Estimated effect of epoetin dosage on survival among elderly hemodialysis patients in the United States. Clin J Am Soc Nephrol. 2009;4(3):638-44. Mar. Single arm Tx cohort—registry data (KQ3); No Dx information. [pmid: 19261818].
630 Zheng S, Coyne DW, Joist H, Schuessler R, Godboldo-Brooks A, Ercole P, Brennan DC. Iron deficiency anemia and iron losses after renal transplantation. Transpl Int. 2009;22(4):434-40. Apr. Single arm study. [pmid: 19076330].
631 Zupan IP, Varl J, Kovac D, Cernelc P, Mlakar U, Andoljsek D, Pretnar J, Zver S, Modic M. Indices of iron status in patients treated by chronic haemodialysis. Pflugers Arch. Suppl 1. 2001;442(6):R202-3. Analytical validity data only (KQ2). [pmid: 11678340].
632 Futenma A, Okura T, Kawahara H. Clinical evaluation of red blood cell ferritin and serum ferritin in maintenance hemodialysis patients (author’s transl). [Japanese]. [pmid: 6808206]. Not relevant.
633 Toriyama T, Matsuo S, Fukatsu A, Takahashi H, Sato K, Mimuro N, Kawahara H. Effects of high-dose vitamin B6 therapy on microcytic and hypochromic anemia in hemodialysis patients. [pmid: 8255009]. Analytic validity data (KQ2).
634 van der Putten K, Jie KE, van den Broek D, Kraaijenhagen RJ, Laarakkers C, Swinkels DW, Braam B, Gaillard CA. Hepcidin-25 is a marker of the response rather than resistance to exogenous erythropoietin in chronic kidney disease/chronic heart failure patients. [pmid: 20601671]. Analytic validity data (KQ2).
635 Malovrh M, Hojs N, Premru V. The influence of need-based, continuous, low-dose iron replacement on hemoglobin levels in hemodialysis patients treated with erythropoiesis-stimulating agents. [pmid: 20618233]. Not relevant.
636 de Lurdes Agostinho, Cabrita A, Pinho A, Malho A, Morgado E, Faisca M, Carrasqueira H, Silva AP, Neves PL. Risk factors for high erythropoiesis stimulating agent resistance index in pre-dialysis chronic kidney disease patients, stages 4 and 5. [pmid: 20640598]. Analytic validity data (KQ2).
637 Ford BA, Eby CS, Scott MG, Coyne DW. Intra-individual variability in serum hepcidin precludes its use as a marker of iron status in hemodialysis patients. [pmid: 20668427]. Analytic validity data (KQ2).
638 Barrios Y, Espinoza M, Baron MA. Pro-hepcidin, its relation with indicators of iron metabolism and of inflammation in patients hemodialyzed treated or not with recombinant erythropoietin. [Spanish]. [pmid: 20694291]. Analytic validity data (KQ2).
639 Mitsopoulos E, Tsiatsiou M, Zanos S, Katodritou E, Visvardis G, Papadopoulou D, Passadakis P, Vargemezis V, Tsakiris D. Impact of C-reactive protein on absolute reticulocyte count in haemodialysis patients: the role of iron status. [pmid: 20696680]. Not relevant.
640 Bratescu LO, Barsan L, Munteanu D, Stancu S, Mircescu G. Is hepcidin-25 a clinically relevant parameter for the iron status in hemodialysis patients?. [pmid: 20797577]. Analytic validity data (KQ2).
641 Ferrari P, Kulkarni H, Dheda S, Betti S, Harrison C, St Pierre TG, Olynyk JK. Serum iron markers are inadequate for guiding iron repletion in chronic kidney disease. [pmid: 20876673]. Analytic validity data (KQ2).
642 Qunibi WY, Martinez C, Smith M, Benjamin J, Mangione A, Roger SD. A randomized controlled trial comparing intravenous ferric carboxymaltose with oral iron for treatment of iron deficiency anaemia of non-dialysis-dependent chronic kidney disease patients. [pmid: 20929915]. Not relevant.
643 Kato A. Increased hepcidin-25 and erythropoietin responsiveness in patients with cardio-renal anemia syndrome. [Review]. [pmid: 21142632]. Analytic validity data (KQ2).
644 Przybylowski P, Malyszko J, Malyszko JS, Koc-Zorawska E, Sadowski J, Mysliwiec M. Anemia in heart and kidney allograft recipients: is there a role for hepcidin?. [pmid: 21168677]. Analytic validity data (KQ2).
645 Fievet P, Brazier F. Iron, hepcidin and chronic kidney disease. [French]. [pmid: 21186144]. Review article.
646 Wikstrom B, Bhandari S, Barany P, Kalra PA, Ladefoged S, Wilske J, Thomsen LL. Iron isomaltoside 1000: a new intravenous iron for treating iron deficiency in chronic kidney disease. [pmid: 21240875]. Not test-directed treatment.
647 Zupan IP, Sabovic M, Salobir B, Ponikvar JB, Cernelc P, Lavre J, Vujkovac B. Association between platelet-related hemostasis impairment and functional iron deficiency in hemodialysis patients. [pmid: 21272250]. Not relevant.
648 Mpio I, Boumendjel N, Karaaslan H, Arkouche W, Lenz A, Cardozo C, Cardozo J, Pastural-Thaunat M, Fouque D, Silou J, Attaf D, Laville M. Secondary hyperparathyroidism and anemia. Effects of a calcimimetic on the control of anemia in chronic hemodialysed patients. Pilot Study. [French]. [pmid: 21353659]. Not relevant.
649 Atkinson MA, White CT. Hepcidin in anemia of chronic kidney disease: review for the pediatric nephrologist. [Review]. [pmid: 21400189]. Review article.
650 Mikhail A, Shrivastava R, Richardson D. Renal Association Clinical Practice Guideline on anaemia of chronic kidney disease. [pmid: 21555890]. Guideline document.
651 Bren A, Arnol M, Kandus A, Varl J, Oblak M, Lindic J, Pajek J, Knap B, Kovac D, Mlinsek G, Buturovic-Ponikvar J. Treatment of anemia with epoetin in kidney transplant recipients. [pmid: 21624072]. Not relevant.
652 Baracco R, Saadeh S, Valentini R, Kapur G, Jain A, Mattoo TK. Iron deficiency in children with early chronic kidney disease. [pmid: 21710251]. Not relevant.
653 Urrechaga E, Unceta M, Borque L, Escanero JF. Low hemoglobin density potential marker of iron availability. [pmid: 21722324]. Not relevant.
654 Chalhoub E, Frinak S, Zasuwa G, Faber MD, Peterson E, Besarab A, Yee J. De novo once-monthly darbepoetin alpha treatment for the anemia of chronic kidney disease using a computerized algorithmic approach. [pmid: 21722599]. Not relevant.
655 Carvalho C, Isakova T, Collerone G, Olbina G, Wolf M, Westerman M, Gutierrez OM. Hepcidin and disordered mineral metabolism in chronic kidney disease. [pmid: 21762639]. Not relevant.
656 Skikne BS, Punnonen K, Caldron PH, Bennett MT, Rehu M, Gasior GH, Chamberlin JS, Sullivan LA, Bray KR, Southwick PC. Improved differential diagnosis of anemia of chronic disease and iron deficiency anemia: a prospective multicenter evaluation of soluble transferrin receptor and the sTfR/log ferritin index. [pmid: 21812017]. Not CKD patients.
657 Smorkalova EV, Aznabaeva LF, Nikulicheva VI, Safuanova GSh, Chepurnaia AN. The characteristics of iron metabolism under iron-deficiency anemia and chronic disorders anemia. [Russian]. [pmid: 21899115]. Not relevant.
658 Besarab A. Anemia and iron management. [pmid: 21906169]. Review article.
659 Kowalczyk M, Banach M, Rysz J. Ferumoxytol: a new era of iron deficiency anemia treatment for patients with chronic kidney disease. [Review]. [pmid: 21956770]. Review article.
660 Malyszko J, Glowinska I, Malyszko JS, Levin-Iaina N, Koc-Zorawska E, Mysliwiec M. Iron metabolism in kidney allograft recipients: still a mystery?. [pmid: 21996204]. Not a test of interest.
661 Xu Y, Ding XQ, Zou JZ, Liu ZH, Jiang SH, Chen YM. Serum hepcidin in haemodialysis patients: associations with iron status and microinflammation. [pmid: 22118000]. Analytic validity data (KQ2).
662 Mahdavi MR, Makhlough A, Kosaryan M, Roshan P. Credibility of the measurement of serum ferritin and transferrin receptor as indicators of iron deficiency anemia in hemodialysis patients. [pmid: 22165676]. Analytic validity data (KQ2).
663 Matsumoto Y, Ozawa Y, Imafuku Y, Yoshida H. Evaluation of serum iron in hemodialysis patients and its variation due to the difference of blood sampling time. [Japanese]. [pmid: 22352015]. Not relevant.
664 Nasir A, Yasmin H, Korejo R. Management of iron deficiency anaemia in gynaecological patients at Jinnah Postgraduate Medical Centre, Karachi. [pmid: 22356035]. Not CKD patients.