# Literature Search Strategy

Database(s): Ovid MEDLINE(R) 1948 to July Week 2 2011, Ovid MEDLINE(R) In-Process & Other Non-Indexed Citations July 21, 2011, EBM Reviews—Cochrane Central Register of Controlled Trials 3rd Quarter 2011

1. percentage of hypochromic erythrocytes.mp. [mp=ps, rs, ti, ot, ab, nm, hw, ui, sh, kw] (15)
2. (percentage adj2 hypochromic erythrocytes).tw. (15)
3. *Reticulocytes/pa [Pathology] (77)
4. (%HYPO and CHr).mp. [mp=ps, rs, ti, ot, ab, nm, hw, ui, sh, kw] (11)
5. *Erythrocyte Indices/ (783)
6. Erythrocyte Count.mp. [mp=ps, rs, ti, ot, ab, nm, hw, ui, sh, kw] (10128)
7. *Erythrocytes/an, du, me [Analysis, Diagnostic Use, Metabolism] (18919)
8. *Erythrocytes/pa (994)
9. Erythropoiesis/ph (1271)
10. *Reticulocytes/ch (65)
11. *Reticulocyte Count/ (156)
12. Ferritins/bl (7434)
13. *Hemoglobins/an (5118)
14. *Erythrocyte Indices/ (783)
15. Reticulocytes/me (4605)
16. Transferrin/an (3892)
17. TSAT.tw. (221)
18. exp Anemia, Hypochromic/ or exp Anemia, Iron-Deficiency/ (15078)
19. hypochromic an?emia.mp. (802)
20. hypochromic erythrocytes.mp. (40)
21. Anemia, Iron-Deficiency/dt (1439)
22. (transferrin adj saturation).af. (2614)
23. exp transferrin/ (14770)
24. hepcidin.af. (1413)
25. ((soluble or serum) adj transferrin).af. (3648)
26. ((soluble or serum) adj transferrin adj receptor).af. (822)
27. (zinc adj protoporhyrin).af. (5)
28. erythrocyte zinc protoporhyrin.mp. (1)
29. superconducting quantum interference device.mp. (345)
30. *Biological Markers/an, bl, me [Analysis, Blood, Metabolism] (11098)
31. *ferritins/ or *apoferritins/ (6927)
32. acute-phase proteins/ or exp transferrin/ (19169)
33. transferrin.mp. (28365)
34. Transferrin/ad, an, bl, du, de, me, pk, tu [Administration & Dosage, Analysis, Blood, Diagnostic Use, Drug Effects, Metabolism, Pharmacokinetics, Therapeutic Use] (10637)
35. or/1–34 (104459)
36. exp “sensitivity and specificity”/ (347657)
37. exp Predictive Value of Tests/ (116486)
38. exp ROC CURVE/ (20708)
39. exp Mass Screening/ (88916)
40. exp diagnosis/ (5609927)
41. exp REPRODUCIBILITY OF RESULTS/ (224874)
42. exp false negative reactions/ or false positive reactions/ (31445)
43. predictive value.tw. (47133)
44. (sensitivity or specificity).tw. (616885)
45. accuracy.tw. (179753)
46. screen$.tw. (378934)
47. diagno$.tw. (1399885)
48. roc.tw. (15058)
49. reproducib$.tw. (95276)
50. (false positive or false negative).tw. (41652)
51. likelihood ratio.tw. (4915)
52. accuracy.tw. (179753)
53. di.fs. (1755561)
54. biological variability.mp. (700)
55. reference values.tw. (8341)
56. reference standard$.tw. (6786)
57. or/36–56 (7398453)
58. (NeoRecormon or Aranesp or Methoxy Polyethylene Glycol Epoetin Beta or MIRCERA or Epoetin or Dynepo or PDpoetin).af. or (NeoRecormon or Aranesp or Methoxy Polyethylene Glycol Epoetin Beta or MIRCERA or Epoetin or Dynepo or PDpoetin).tw. (2810)
59. (epogen or epotin or betapoietin or relpoietin or epokine or procrit or eprex or darbopoietin).af. or (epogen or epotin or betapoietin or relpoietin or epokine or procrit or eprex or darbopoietin).tw. (252)
60. (Ferumoxytol or Feraheme or Iron Dextran or DexFerrum or INFeD or Ferrous fumarate or ferrous gluconate or ferrous sulfate or ferrous sulphate or carbonyl iron or polysaccharide iron complex or Icar or Feosol or Ircon or Hemocyte or Nephro-Fer or Feostat or Ferro-DSS or Ferro-Sequels or Fergon or Fer-Gen-Sol or Fer-In-Sol or Mol-Iron or Feratab or Ferrex or Niferex or Hytinic or Fe-Tinic or Iron sucrose or Venofer or Sodium ferric gluconate or Ferrlecit).mp. or exp Iron/ or exp Ferric Compounds/ or exp Ferrous Compounds/ or exp Anemia, Iron-Deficiency/ or ferrous.mp. (105161)
61. exp recombinant erythropoietin/ or recombinant erythropoietin.mp. (6065)
62. or/58–61 (111284)
63. exp Renal Replacement Therapy/ or exp Renal Dialysis/ or exp Kidney Transplantation/ or exp Kidney Function Tests/ or renal.mp. or nephro$.mp. or kidney.mp. or ur?emia.tw. or h?emodialysis.tw. (827443)
64. hemodialysis.af. (45683)
65. peritoneal dialysis.mp. or exp Peritoneal Dialysis/ (24886)
66. exp Kidney Diseases/ or exp Kidney Failure, Chronic/ or chronic kidney disease.mp. or exp Chronic Disease/ or exp Kidney Glomerulus/ (584160)
67. or/63–66 (1060229)
68. 35 and 57 and 67 (5403)
69. remove duplicates from 68 (5089)
70. 35 and 62 and 67 (2619)
71. remove duplicates from 70 (2409)
72. 69 and 71 (1287)
73. 69 not 72 (3802)
74. 73 or 71 (6211)
75. limit 74 to (addresses or bibliography or biography or case reports or comment or congresses or consensus development conference or dictionary or directory or festschrift or in vitro or interactive tutorial or interview or lectures or legal cases or legislation or news or newspaper article or overall or patient education handout or periodical index or portraits or “scientific integrity review” or twin study) [Limit not valid in CCTR; records were retained] (458)
76. 74 not 75 (5753)