# Abbreviations and Acronyms

%HYPO: Percentage of Hypochromic Erythrocytes
AAAC: American Association for Clinical Chemistry
AHRQ: Agency for Healthcare Research and Quality
AUC: Area Under the Curve
CHr: Hemoglobin Content of Reticulocytes
CI: Confidence Interval
CKD: Chronic Kidney Disease
EPC: Evidence-based Practice Center
ESA: Erythropoiesis Stimulating Agents
FDA: Food and Drug Administration
Hb: Hemoglobin
Hct: Hematocrit
HD: Hemodialysis
IV: Intravenous
KDOQI: Kidney Disease Outcome Quality Initiative
ND CKD: Nondialysis Chronic Kidney Disease
NKF: National Kidney Foundation
PD: Peritoneal dialysis
PICO: Populations, interventions, comparators, and outcomes
PRISMA: Preferred Reporting Items for Systematic Reviews and Meta-Analyses
RBC: Red Blood Cell
RCT: Randomized Controlled Trial
Ret He: Reticulocyte Hemoglobin Equivalent
ROC: Receiver Operating Characteristic
SQUID: Superconducting Quantum Interference Devices
sTfR: soluble Transferrin Receptor
TEP: Technical Expert Panel
TOO: Task Order Officer
TSAT: Transferrin Saturation
ZPP: Erythrocyte Zinc Protoporphyrin