# Summary and Discussion

We conducted an extensive literature search, data abstraction, and quantitative analysis where possible, to assess the comparative effectiveness of bariatric surgery in patients with diabetes or impaired glucose tolerance (IGT) and a body mass index (BMI) of at least 30 but less than 35. Here we describe the limitations of our systematic review then present our conclusions. We also discuss the implications of our findings for future research.

## Limitations

The research on bariatric surgery in patients with BMI of at least 30 kg/m^2^ and less than 35 kg/m^2^ and diabetes or IGT has many limitations. Most importantly, very few studies have long term followup (more than two years). Two report data at five years or more; one has a followup rate of only 13.8 percent, while the other includes only seven patients. Thus, we have almost no data on long-term efficacy and safety. No evidence was found on major clinical end points such as all-cause mortality, cardiovascular mortality or morbidity, or peripheral arterial disease. Some evidence from the diabetes literature indicates it may be premature to assume that controlling glucose to normal or near normal levels completely mitigates the risk of microvascular and macrovascular events. While it is more likely than not that this is true, conclusive proof is lacking, and the point is still debated in the diabetes literature.

Another limitation is the dearth of high quality studies. Randomized controlled trials (RCTs) are considered the highest level of medical evidence. We found three RCTs of surgery versus nonsurgical treatment (one of these also compared two procedures) and another RCT comparing surgical procedures. This was expected given the difficulty in conducting randomized trials of surgery. Still, we identified only two observational studies comparing surgical procedures and two small cohort studies comparing surgery with nonsurgical approaches. The rest of our data come from studies with no comparison group, with data submitted primarily by the practicing surgeons. The sample sizes, regardless of methodological design, are far smaller than those of most trials of diet, exercise, and medications.

Applicability of this research to the larger treatment population of diabetes and IGT patients with BMI between 30.0 kg/m^2^ and 34.9 kg/m^2^ is important in interpreting the results. The participation rate, population characteristics, representativeness of the setting, and representativeness of the individuals are used to assess applicability. One RCT comparing surgery with non-surgery was performed in the United States and included two of the more commonly performed procedures – Roux-en-Y gastric bypass (RYGB) and sleeve gastrectomy (SG). However, it was of modest size and was conducted in an academic setting in a select group of patients with uncontrolled type II diabetes at baseline. Two RCTs of LAGB versus nonsurgical interventions conducted in Australia were comprised primarily of Caucasian patients. However, the RCT comparing laparoscopic adjustable gastric banding (LAGB) with SG was conducted in Taiwan, where diets and lifestyle may differ considerably from the West. One of the cohort studies comparing procedures was conducted in the U.S, but only three of the remaining observational studies were conducted here. The others were conducted in Western Europe, South America, India, Asia, and Australia. Diet, behavior, and culture in many of these locations may differ dramatically from that in the United States. In addition, there may be biological or genetic differences. Thus, the results seen in non-U.S. studies may not be directly applicable to American patients.

Data reported on adverse events have several limitations. Most studies were not designed to assess these outcomes and reflect surgeon or surgery-team reported events. Additionally, followup times and rates were variable, and many studies did not state exactly when adverse events occurred, other than “within a year post surgery.” As such, the rates of adverse events may be biased and lower than actual. Comparisons between procedure types are limited for the same reasons. We found almost no long-term adverse events data for our target population.

Key stakeholders, especially consumers, expressed interest in quality of life (QOL) and psychological outcomes post-surgery. These were rarely reported in the studies we identified.

Finally, although our literature search procedures were extensive and included canvassing experts for studies we may have missed, the possibility of publication bias still exists. For all surgical procedures there is the concern that published studies usually come from academic medical centers with high performing surgical teams and careful patients selection. Outcomes reported for such patients may not be representative of the outcomes achieved in the wider community. The difference between complication rates seen in the major clinical trials of carotid endarterectomy and those observed in the general Medicare population is one well-known example of this phenomenon. In addition, there are media reports (Los Angeles Times) on a number of deaths following LAGB surgery. Whether there is any causal relationship between the surgery and the deaths has not yet been assessed in a peer-reviewed publication, so no conclusions can be drawn. Still, it illustrates the potential for there to exist adverse events and/or beneficial outcomes in as-yet-undescribed populations.

## Conclusions

### Short-Term Outcomes

Based on glucose control outcomes, there is moderate strength evidence of efficacy of bariatric surgery in treating diabetes in patients with BMI of at least 30 but less than 35 kg/m^2^ in the short term. At one year, surgery patients show much greater weight loss than usually seen in studies of diet, exercise, or other behavioral interventions. With the exception of GLP-1T agonists, diabetes medications do not cause significant weight loss. While both behavioral interventions and various medications lower HbA1c levels significantly, the decreases reported in bariatric surgery patients at one year are greater. Improvements in glucose control outcomes have been reported as early as one month post-surgery. Several studies report improvement in hypertension and cholesterol at one year. We rated the overall evidence as moderate due to sparseness of data - three RCTs directly compared surgery with nonsurgical interventions, and two came from the same group of researchers. Observational data, which start as “low” strength evidence, were upgraded due to consistency of results regarding BMI and blood sugar. Thus, the total body of evidence is considered moderate strength, based on moderate strength of evidence for BMI and glucose outcomes. Strength of evidence for cholesterol and blood pressure outcomes is low.

### Long-Term Outcomes

There are few long-term data on patients with diabetes or IGT in this weight class who have undergone bariatric surgery. We identified only two studies with followup of more than two years. One, a case series of LAGB patients in Italy, reported followup at five years for 29 of the 210 initial patients, for a followup rate of only 13.8 percent. Another very small Italian study followed seven biliopancreatic diversion with duodenal switch (BPD) patients for at least 5 years Thus, despite promising short term outcomes reported, the evidence that bariatric surgery is an effective way to treat diabetes in patients with BMI of at least 30 kg/m^2^ but less than 35 kg/m^2^ in the long term is insufficient. Strength of evidence is insufficient for all outcomes, including BMI, blood glucose, cholesterol, and hypertension. In contrast, behavior and medication interventions have been studied extensively for decades; several large long-term RCTs have found improved HbA1c continues for 10 years. Several long-term trials and meta-analyses have reported clinically significant improvements in microvascular and macrovascular outcomes as a result of behavioral or medication interventions.

### Specific Bariatric Procedures

We found two head to head trials comparing bariatric procedures (one also had a medication only group). An average size trial (N=60) conducted in Taiwan compared RYGB with SG; the RYGB group had better weight and diabetes outcomes at one year post surgery. A recent United States trial comparing these same procedures found similar results.

We also found two observational studies that compared procedures. One conducted in the United States compared RYGB with LAGB. This study was fairly large (N = 235), and had an adequate followup rate (61.9 percent for RYGB, 69.2 percent for LAGB) at 6 to 12 months. Some patients were followed for two years. Weight loss was similar among groups; diabetes outcomes were generally better for RYGB patients. The other study, conducted in Germany, compared results for twelve BPD patients with four RYGB patients. Both groups lost a significant amount of weight. At one year, decrease in HbA1c was significantly greater in the BPD group.

Observational studies of surgical procedures without a comparison arm reported clinically meaningful decreases in BMI with all types of bariatric surgery at less than one year. Clinically meaningful diabetes outcomes were also reported at less than a year for all surgery types. At a year or more, weight loss was maintained or improved in all groups; RYGB patients had the greatest decrease in BMI.

Taking into consideration the entire body of evidence, we rate the strength of evidence of efficacy as moderate for RYGB, LAGB, and SG in treating diabetes and IGT in patients with a BMI of between 30 kg/m^2^ and 35 kg/m^2^, in the short term (up to two years) based primarily on glucose control outcomes. For BPD, both the number of studies and their sample sizes are much lower; thus the strength of evidence of efficacy is rated low. Evidence on comparative effectiveness of surgical procedures is insufficient.

### Adverse Events

We rate the strength of evidence for overall short term harms as low for all four procedure types. In the two RCTs comparing SG with RYGB complications were minor and rates were similar between groups. The surgical complications reported for RYGB and LAGB in observational studies were fairly consistent; they differ due to the nature of the procedures. Complications related to LABG include band slippage, tube problems, and band erosion, while those related to RYGB include stricture, ulcer, and on rare occasions, hemorrhage.

The low strength of evidence reflects several limitations in the data. The majority of the adverse events data were submitted by surgeons, and thus subject to possible publication bias. Few studies were clear exactly when adverse events took place, and patients who were lost followup had no adverse events data. In addition, definitions of complications varied from study to study.

We found no data on long term adverse events of bariatric surgery in diabetes or IGT patients in our specific BMI range. Thus, strength of evidence for long term adverse events is rated insufficient.