# Results

Figure 2 displays the results of our literature search. We identified 7,088 titles through our electronic database searches, reference mining, scientific information packets received from manufacturers, and expert panel suggestions. Our researchers selected 2,376 for further review; almost half were rejected upon abstract review. Of the 1,220 studies that underwent full-text review, we included 24 studies that included a surgical arm, 12 systematic reviews, and ten large studies of nonsurgical interventions published after those reviews. The most common reasons for exclusion of surgical studies were wrong body mass index (BMI) range (516 studies) or the study did not include patients with diabetes or impaired glucose tolerance (IGT) (94 studies). The most common reasons for excluding nonsurgical studies were followup of less than one year or inclusion in previous systematic reviews.

Figure 2 Study/Literature flow diagram

BMI = body mass index; RCT = randomized controlled trial

Figure 2 displays the results of our literature search. We identified 7,088 titles, including 5,528 through our electronic database searches, 1,511 through reference mining, and 49 from Scientific Information Packets received from manufacturers or suggestions from expert panel members. Our researchers selected 2,376 for abstract review; almost half were rejected at that phase. Of the 1,220 studies that underwent full-text review, we included 24 studies with a surgical arm, 12 systematic reviews on non-surgical interventions, and ten large trials of non-surgical interventions published after those reviews. Patient composition was the most common reason for exclusion of surgical studies; either they were in the wrong BMI range (516 studies) or did not have diabetes or IGT (94 studies). The most common reasons for excluding non-surgical studies were follow-up of less than one year (210 studies) or inclusion in previous systematic reviews (also 210 studies).

## KQ1 What does the evidence show regarding the comparative effectiveness of bariatric surgery for treating adult patients with BMI of 30 to 34.9 and metabolic conditions, including diabetes? Are certain surgical procedures more effective than others (laparoscopic adjustable gastric banding, gastric bypass, or sleeve gastrectomy)?

## KQ2 What does the evidence show regarding the comparative effectiveness of bariatric surgery versus conventional nonsurgical therapies for treating adult patients with BMI of 30 to 34.9 and metabolic conditions?

Of the 24 studies reporting bariatric surgery results in patients with diabetes or IGT and a BMI of ≥ 30 < 35 kg/m^2^, we found two head to head, one cohort study, and one case series comparing surgical procedures. We also identified three controlled trials with a nonsurgical comparison arm (one of which also compared two surgical procedures) and two small cohorts with a nonsurgical arm. The rest of the studies were observational with no comparison group. Six studies included only a portion of patients with diabetes or IGT; in the rest, all patients had these disorders. The majority of the surgical studies came represented single institutions. Of these, three studies reported that only one surgeon performed the cases, three others reported that two surgeons performed the cases, and one study reported procedures were performed by three surgeons. It is unknown how many surgeons performed the cases in the remaining studies.

There were thirteen Roux-en-Y gastric bypass (RYBG) arms, seven laparoscopic adjustable gastric banding (LAGB) arms, five biliopancreatic diversion with duodenal switch (BPD) arms, and three sleeve gastrectomy (SG) arms. Table 2 displays the followup times for each study, along with whether BMI, HbA1c, and/or fasting glucose were measured at each point. Many studies measured additional metabolic outcomes; however, no studies reported on diabetes sequelae such as nephropathy or retinopathy. The vast majority of the studies included followup between 10 and 12 months postsurgery. Unfortunately, few studies followed patients more than two years. It is important to note that when assessing outcomes across time points (for example, 4–6 month data and 10–12 month data) the patients contributing data at 4–6 months may not be the same patients contributing data at 10–12 months, either within study across studies.

Table 2 Bariatric outcomes by followup time

Study | Surgery | 0-3 mths | 4-6 mths | 7-9 mths | 10-12 mths | 13-24 mths | >24 mths
Cohen, 2006^26^ | RYGB | | | | | §
Lee, 2008^27^ | RYGB | | | | † § #
DeMaria, 2010^28^ | RYGB | † | † | | † | †
Shah, 2010^29^ | RYGB | § # | § # | † § #
Boza, 2011^30^ | RYGB | | | | #
de Sa, 2011^31^ | RYGB | | | | | † § #
Frenken, 2011^32^ | RYGB | | | | † #
Huang, 2011^33^ | RYGB | | † § # | | † § #
Lee, 2011^34^ | RYGB | † # | † # | | † #
Lee,2011^35^ | RYGB | † § # | † § # | | † § # | † § #
Ramos, 2011^36^ | RYGB | | | | | #
Schauer, 2012^37^ | RYGB | † § # | † § # | † § # | † § #
Serrot,2011^a,38^ | RYGB | | | | † #
Angrisani, 2004^39^ | LABG | | † | | † | † | †
O'Brien, 2006^40^ | LABG | | † | | † | † §
Parikh, 2006^41^ | LABG | | | | † | † | †
Dixon, 2008^42^ | LABG | | | | | † #§
Sultan, 2009^43^ | LABG | | † | | † | †
Choi, 2010^b,44^ | LABG
DeMaria, 2010^28^ | LABG | † | † | | † | †
Lee, 2011^34^ | Sleeve | † # | † # | | † #
Lembach,2011, T2DM45 | Sleeve | | | | † § #
Lembach,2011,IR^c,45^ | Sleeve | | | | † §
Schauer, 2012^37^ | Sleeve | † § # | † § # | † § # | † § #
Noya, 1998^46^ | BPD | | | †
Scopinaro, 2007^47^ | BPD | | | | † § | † §
Chiellini, 2009^48^ | BPD | | | | † # | † #
Frenken, 2011^d,32^ | BPD | | | | † #
Scopinaro, 2011, OB^e,49^ | BPD | † § # | † § # | † § # | † § # | † § #
Scopinaro, 2011, OW^f,49^ | BPD | † § # | † § # | † § # | † § # | † § #

BMI = body mass index;BPD= biliopancreatic diversion; BPD/DS = biliopancreatic diversion with duodenal switch; IR = insulin resistant patients; LABG = laparoscopic adjustable gastric banding; mths = months; OB = obese; OW = overweight; RYGB = Roux-en-Y gastric bypass; Sleeve = sleeve gastrectomy; T2DM = type 2 diabetes mellitus

† BMI.

# HbA1c.

§ Glucose.

a Only reported Median, used in outcome table.

b Only usable outcome is % diabetes remission: defined as “% improved/resolved” not otherwise specified.

c IR=insulin resistant patients.

d BPD-DS & BPD treated as 1 group.

e Obese (BMI 30-35).

f Overweight (BMI 25-30).

### Head-to-Head Trials of Bariatric Surgery Versus Nonsurgical Interventions

We identified three randomized controlled trials (RCTs) comparing bariatric surgery with a nonsurgical intervention. One study by Schauer 37 compared medical treatment alone with medical treatment following laparoscopic RYGB or gastric sleeve in diabetic patients. Approximately one third of subjects had a baseline BMI in the target range (38%, 28%, and 36% respectively). Outcomes were assessed at 12 months. Two RCTs from an Australian research group assessed weight loss and diabetes outcomes for LAGB compared with nonsurgical interventions in our target population. O'Brien40 focused on patients with BMI 30 kg/m^2^–35 kg/m^2^ and Dixon42 included patients with somewhat higher BMI (range 30 kg/m^2^–40 kg/m^2^). The comparison arms included medical care and usual diabetes care. Patients were followed up to 24 months. Information on these studies is displayed in Table 3.

Table 3 RCTs with comparison nonsurgical arms

Author/Study Type | Procedure/# Patients | Weight Outcomes at 12 Months | | Diabetes and Metabolic Syndrome Outcomes at 12 Months
Author/Study Type | Procedure/# Patients | Weight Change, kg (SD) | BMI at 12 mo | Fasting Blood Glucose Change, mg/dL (SD) | HbA1c, % (SD) | HbA1c <6.0% at 12 mo | Average # Diabetes Meds, at 12 mo, | Diabetes Remission^*^, % at 12 mo [Change]
Schauer 37 RCT | Medical therapy +RYGB (n=50) Medical therapy + GS (n =50) Medical therapy alone (n=50) | -29.4 (9.0) -25. (8.5) -5.4 (8.0) p<0.0001^†^ | 26.5 27.2 34.4 p<0.001^†^ | 99 97 120 p<=0.002^†^ | 6.4 (0.9) 6.6 (1.0) 7.5 (1.8) p<=0.003^†^ | 42% 37% 12% p<=0.002^†^ | 0.3 0.9 3.0 p<0.001^†^
Author/Study Type | Procedure/# Patients | Weight Outcomes at 24 mo | | Diabetes and Metabolic Syndrome Outcomes at 24 mo
Author/Study Type | Procedure/# Patients | Weight Change, kg (SD) | BMI at 24 mo [95% CI] | Fasting Blood Glucose change, mg/dL (SD) | | | | Metabolic Syndrome, % at 24 mo, [change]
O'Brien 40 RCT | LAGB (n=40) Medical Care (n=40) Betw grp comparison Baseline BMI = 33.5 (SD =1.4) | -20.5, (6.4) -6.1, (8.5) 95% CI [-18.9, -11.6] | 26.4 [25.6, 27.2] 31.5, [30.6, 32.4] p<0.001 | -7.3 (15.2) 0.35 (8.3) 95% CI [-13, -0.7] | --- | --- | --- | 2.7, [-35] 24, [-12] p=.0006
| | Weight Change, kg (SD) | BMI at 24 mo [Change] | Fasting Blood Glucose Change, mg/dL (SD) | HbA1c, % Change, (SD) | HbA1c <6.2% at 24 mo | Taking DM Meds, % at 24 mo, [Change] | Diabetes Remission, % at 24 mo^*^ [Change]
Dixon 42 RCT | LAGB (n=30) Conventional (n=30) Betw grp comparison Baseline BMI = 37.0 (SD = 2.7) | -21.1 (10.5) -1.5 (5.4) -19.6 [23.8,15.2] p<0.001 | 29.6, [-7.4] 36.7, [-0.5] p<0.001 | -51.2, (37.2) -18.4, (41.2 ) -32.8 [-53.1, -12.3] p=0.002 | -1.81, (1.24) -0.38, (1.26) -1.43 [-2.1, -0.80] p<0.001 | 80% 20% p<0.001 | 13.3, [-79.7] 73.3, [-13.4] p<0.001 | 73 [-73] 13 [-13] p<0.001

betw = between; BMI = body mass index; CI = confidence interval; DM = diabetes mellitus; grp = group; LAGB = laparoscopic adjustable gastric banding; meds = medications; mo = months; RCT = randomized controlled trial; RYGB = Roux-en-Y gastric bypass; SD = standard deviation

* Diabetes remission defined as fasting blood glucose <126mg/dL, HbA1c <6.2% without the use of insulin or oral hypoglycemics.

† Medical treatment compared with each surgical group.

Note: n=33 in the Medical Care Group.

Schauer37 conducted a recent RCT in 150 patients with uncontrolled type 2 diabetes (HbA1c >7.0%) and BMI of 27–43 kg/m^2^ comparing intensive medical treatment alone with medical treatment following either RYGB or gastric sleeve. Study inclusion/exclusion criteria and randomization protocol were described in detail. Ninety-three percent of patients completed the 12 month follow-up. Eight patients withdrew from the study (seven in the medical therapy only group did not attend follow-up appointment and one subject in the SG group decided against surgery). Two additional patients in the medical therapy only group did not complete their nine month or 12 month follow-up—leaving 41 patients in the medical therapy alone group, 50 patients in the RYGB group and 49 in the SG group at 12 month followup.

The medical therapy alone group lost less weight at 12 months (−5.4 kg+/−8 kg) than medical therapy with RYGB (−29.4+/−9 kg,) or SG (−25.2+/−8.5 kg, p<.0001 for both comparisons). More patients in the surgical arms achieved glycemic control of HbA1c <6.0 percent: 12 percent in medical group, 42 percent in RYGB (p=0.002), and 37 percent in SG (p=0.008). Mean HbA1c at one year was lower following surgery: 7.5+/−1.8 percent for medical group, 6.4+/−0.9 percent for RYGB (p<0.001), and 6.6+/−1.0 percent for SG (p=0.003). The surgical groups reduced the mean number of both cholesterol medication and hypertension medications significantly compared with the surgical group. (p<.0001).

O'Brien40 performed an RCT comparing LAGB (n=40) and medical management (n=40) which included low calorie diet, pharmacotherapy, and behavioral change. Patients had a mean baseline BMI of 33 kg/m^2^ and were well-matched for baseline characteristics; the randomization process was well-described, as were dropouts. No patients were excluded from the analysis. One patient randomized to the surgical arm dropped out preoperatively; seven patients in the medical management did not attend followup at 24 months.

Both groups lost a similar amount of weight at six months (13.8 percent of initial weight in both arms). The surgical arm continued to lose weight out to 24 months (21.6 percent of initial weight), but the medical arm regained much of the weight they initially lost. At that followup, the surgical arm (n=39) had a mean BMI of 26.4 kg/m^2^ and the medical arm (n=33) mean BMI was 31.5 kg/m^2^. The surgical group experienced significantly greater weight loss (p<0.001). The majority of other outcomes were improved to a statistically significant degree in the surgical arm as compared with the medical arm, including diastolic blood pressure and lipid levels. Fasting blood glucose was lower in the surgical patients at 24 months as compared with the medical group (which did not experience a decrease). Metabolic syndrome was present in 37.5 percent of patients in both groups at baseline and decreased to 2.7 percent in the surgical patients (p<0.001) and 24 percent in the medical patients (p=0.22) at followup. A greater proportion of patients in the surgical group improved metabolic syndrome than in the medical group (p=.0006). Other laboratory values, such as HbA1c or use of diabetes medications, were not reported. Of note, quality of life (by short form 36) scores improved to a statistically significant degree in 5 of the 8 domains in the surgical group (8 of 8 subscores) as compared with the medical group (3 of 8).

Dixon et al42 performed a similar study but included patients of somewhat higher BMI (mean baseline 37 kg/m^2^). Sixty patients were randomized to LAGB or diabetes care as usual. Usual care focused on weight loss via conventional methods including counseling on diet and exercise. Authors described the randomization process and dropouts; patient baseline characteristics were similar following randomization.

At two years, 55 of 60 patients completed the followup. Surgical patients lost a mean of 21.1 kg initial weight compared with 1.5 kg in the conventional treatment arm (p<0.001 between groups). BMI decreased to 29.6 kg/m^2^ in the surgery patients and 36.7 kg/m^2^ in the conventional therapy group (p<.001 between groups). Fasting blood glucose (105.2 versus 139.6) was significantly lower in the surgery patients at two years as compared with the medical group (mean difference -32.8 [95% confidence interval (CI) -53.1, -12.3]). HbA1c was also improved to a greater degree in the surgical patients at two years as compared with the convention therapy group (6.00 versus 7.21; mean difference -1.43 [95% CI -2.1, -0.80]). Remission of type 2 diabetes was seen in 73 percent of the surgical group and 13 percent of the usual care group; relative risk of remission was 5.5 (95% CI 2.2, 14.0). Remission of diabetes was defined as fasting plasma glucose levels less than 126 mg/dL and HbA1c less than 6.2 percent without the use of oral hypoglycemic or insulin. Eighty percent of surgery patients had HbA1c <6.2 percent at 24 months compared with 20 percent of conventional therapy group (p<0.001). Resolution of type 2 diabetes was related to weight loss and lower baseline HbA1c levels.

### Head-to-Head Trials of Surgical Procedures

We identified two RCTs comparing surgical procedures in our target population (Table 4). Lee34 randomized 60 diabetic patients in Taiwan to RYGB or SG. Baseline demographics and clinical characteristics (mean BMI=30.3 kg/m^2^) were similar between the groups. At 12 months followup the RYGB group had lost more weight: BMI was 22.8 kg/m^2^ for RYGB, compared with 24.4 kg/m^2^ for SG (p=0.009). Diabetes outcomes were also better in the RYGB group with 93 percent remission compared with 47 percent in SG group (p=0.02). Diabetes type 2 remission was defined as fasting plasma glucose levels less than 126 mg/dL and HbA1c values less than 6.5 percent without the use of oral hypoglycemics or insulin. HbA1c decreased by 4.2 percentage points in the RYGB versus 3.0 percentage points in the SG patients (p<0.05). Fasting glucose was lower in the RYGB patients compared with SG (99.3 versus 140.1; p<0.001). Total cholesterol level, triglycerides, low-density lipoprotein (LDL) cholesterol, and high-density lipoprotein (HDL) cholesterol improved in both groups but to a greater degree in the RYGB patients. A composite measure of diabetes improvement (HbA1c<7 percent, LDL<100 mg/dL, and triglycerides<150 mg/dL) revealed greater improvement in the RYGB group (57 percent versus 0 percent; p<0.001). Complication rates were similar between groups and were minor. Operative time and hospital stay were no different.

Table 4 RCT with comparison surgical arms – Outcomes at one year

Author/Study Type | Procedure/# Patients | Weight Change (%) | BMI, kg/m^2^ (SD) | Fasting Blood Glucose Mean, mg/dL (SD) | HbA1c %, Mean (SD) | Metabolic Syndrome No (%) | Successful Treatment Diabetes,^†^No (%) | Diabetes Remission,^‡^No (%)
Lee34 RCT | Roux–en-Y gastric bypass (n=30) | -23.3 | 22.8 (2.2) | 99.3 (19.4) | 5.7 (0.5) | 2 (6.6) | 17 (57) | 28 (93)
Lee34 RCT | Sleeve gastrectomy (n=30) | -19.9 | 24.4 (2.4) | 140.1 (53.0) | 7.2 (1.5) | 18 (60.0) | 0 (0) | 14 (47)
Lee34 RCT | Betw grp comparison^*^ | p=0.02 | p=0.009 | p<0.001 | p<0.001 | p<0.001 | p<0.001 | p=0.02
Schauer37 RCT | Roux-en-Y gastric bypass (n=50) | -27.6 | 26.8 | 99.0 | 6.4 (0.9) | N/A | 21 (42) | 21 (42)
Schauer37 RCT | Sleeve gastrectomy (n=49) | -25.0 | 27.2 | 97.0 | 6.6 (1.0) | N/A | 18 (37) | 13 (27)
Schauer37 RCT | Betw grp comparison^*^ | p=.02^§^ | p=.03^§^ | p=.86 | p=.23 | N/A | p=.59 | p=.10

BMI = body mass index; btw = between; grp = group; LDL-C = low-density lipoprotein cholesterol; N/A = not applicable; No = number; RCT = randomized clinical trial; SD = standard deviation

* Between group comparisons are mean difference and 95% CI.

† Successful treatment of diabetes mellitus (HbA1c <7%, LDL-C <100 mg/dL, and triglycerides <150 mg/dL in Lee; HbA1c ≤ 6 percent in Schauer).

‡ Remission defined as fasting plasma glucose levels less than 126 mg/dL and HbA1c values less than 6.5% without the use of oral hypoglycemics or insulin in Lee; HbA1c values ≤ 6 percent without use of oral hypoglycemic or insulin in Schauer.

§ p for mean change from baseline.

Schauer randomized 150 U.S. patients to either RYGB, SG, or intensive medical therapy alone (discussed earlier). The surgical groups also received the same intensive medical therapy. Patients' baseline characteristics were similar. Mean BMI was 37.0 ± 3.3 for the RYGB group, compared with 36.2 ± 3.9 for the gastric sleeve group. At 12 month followup, the bypass group had lost significantly more weight (p=.02) and had a slightly lower mean BMI (26.8 vs. 27.2). Changes in blood glucose were similar; however, all patients in the bypass group who achieved a pre-determined target glycated hemoglobin level (6 percent) did so without medications, while 28 percent in the sleeve group required medications to reach this level.

Changes in blood pressure and cholesterol did not differ significantly by surgical group.

### Observational Studies With Surgical Procedure Comparisons

One cohort study compared RYGB with LAGB. Demaria28 accessed a large retrospective database of patients operated on in the United States from 2005 to 2007 (n=66,264) and identified 235 who met the lower weight criteria (BMI ≥30 and <35 kg/m^2^). 109 patients underwent RYGB, the same number had had laparoscopic adjustable gastric band. (The remaining 17 underwent other procedures.) The study methods did not comment on the rationale of procedure choice for patients, but groups did not differ by baseline weight (33.7 kg/m^2^ versus 33.9 kg/m^2^), gender, race, or age. Followup was 61.9 percent and 69.2 percent at 6-12 months for RYGB and laparoscopic adjustable gastric band patients, respectively. At 6-12 months, RYGB patients lost more weight than those undergoing laparoscopic adjustable gastric band (6-12 months: BMI 27.1 kg/m^2^ and 30.9 kg/m^2^; p=0.0002). RYGB achieved better diabetes control for all time intervals as the number of patients off diabetes medications (at 6-12 months: 55.2 percent versus 27.2 percent; p=.0199), with the exception of the latest followup at 12-24 months (but only 4 RYGB and 11 LAGB patients were followed up at that time interval). For patients with diabetes controlled with oral medications, 60.9 percent and 38.5 percent, for RYGB and laparoscopic adjustable gastric band, respectively, were able to stop their diabetes medications within 3-6 months. For patients on insulin and oral medications, 50 percent and 11.1 percent, respectively, were able to stop their medications. Complications, while minor, occurred more commonly in the RYGB group (18 percent versus three percent, p<0.05).

One small study conducted in Germany compared results for twelve BPD patients with the results for four RYGB patients.32 Both groups lost a significant amount of weight. At one year, decrease in HbA1c in the RYGB group was significantly greater than in the BPD group.

### Small Cohorts: Surgery Versus Nonsurgical Interventions

We found two small cohort studies matching data from surgical patients with data from similar patients who did not have bariatric surgery. One small study by Chiellini48 compared patients undergoing BPD (n=5) with those managed by diet (n=7). The study did not specify what variables the patients were matched on and only one month followup was reported. In this very short-term followup, HbA1c and weight were significantly lower in both groups. The BPD group did see a significant decrease in the blood glucose (at 2 hr) during an oral glucose tolerance test, whereas the diet arm did not.

Serrot38 retrospectively compared data for 17 diabetic patients who underwent RYGB with 17 matched patients on routine medical management for diabetes / weight control. The nonsurgical group received counseling regarding diet, physical activity, and weight management. At one year, BMI did not change significantly in the routine management group, but decreased significantly from 34.6 kg/m^2^ to 25.8 kg/m^2^ in the RYGB group. HbA1c decreased significantly from a mean 8.2 percent at baseline to 6.1 percent at one year in the RYGB group, but did not change significantly in the comparison group. Systolic blood pressure and LDL cholesterol did not change significantly in either group; however, 41% of the RYGB group ceased use of antihypertension medications and 35% ceased use of antihyperlipidemia medications despite lack of clinically meaningful improvement on these outcomes.

### Observational Studies—Diabetes Outcomes

Tables 5 and 6 display data from the observational studies. Table 5 presents data for the studies where all patients entering had type 2 diabetes or IGT; Table 6 displays the remaining handful of studies where only a portion of patients had these metabolic conditions. The tables are organized by outcome, surgery type, and followup time. Each table displays BMI, HbA1c, fasting glucose, percentage of patients off diabetes medication, and percentage of diabetes patients in remission, at three post-surgery intervals: 0 to 3 months, 6 to 11 months, and 12 months or more. Unlike RCTs, which try to measure outcomes at exact followup times, in these observational studies patient outcomes are measured at a wide range of times, depending on availability / convenience. Thus, we also include a column displaying the exact range of followup points included.

Table 5 Bariatric surgery results—by surgery type, studies of only diabetes or IGT patients

Outcome | F-Up | F-Up Range | # Studies | Surg Type | BL (N) | BL Mean (%) | BL (SE) | F-Up (N) | F-Up Mean (%) | F-Up (SE) | Mean Chg
BMI | 0-3m | 0-3m^*^ | 3 | RYGB | 201 | 32.1 | 1.2 | 163 | 27.7 | 2.3 | -4.4
BMI | 0-3m | 0-3m^*^ | 1 | LABG | 109 | 33.9 | | 90 | 31.6 | | -2.3
BMI | 0-3m | 3m | 1 | Sleeve | 30 | 30.3 | | 30 | 26.0 | | -4.3
BMI | 0-3m | 1m | 1^‡^ | BPD | 30 | 30.6 | 2.5 | 30 | 26.7 | 2.4 | -3.9
HbA1c | 0-3m | 3m | 3 | RYGB | 107 | 9.8 | 0.1 | 90 | 6.3 | 0.4 | -3.5
HbA1c | 0-3m | | | LABG
HbA1c | 0-3m | 3m | 1 | Sleeve | 30 | 10.0 | | 30 | 7.8 | | -2.2
HbA1c | 0-3m | 1m | 1^‡^ | BPD | 30 | 9.3 | 0.2 | 30 | 7.3 | 0.0 | -2.0
Glucose | 0-3m | 3m | 2 | RYGB | 77 | 203.0 | 14.7 | 60 | 115.5 | 1.9 | -89.6
Glucose | 0-3m | | | LABG
Glucose | 0-3m | | | Sleeve
Glucose | 0-3m | 1m | 1^‡^ | BPD | 30 | 220.0 | 14.0 | 30 | 165.0 | 11.0 | -55.0
% on Diabetes Meds | 0-3m | 0-3m^*^ | 2 | RYGB | 124 | 100.0 | 0.0 | 103 | 53.4 | 22.0 | -46.6
% on Diabetes Meds | 0-3m | 0-3m^*^ | 1 | LABG | 109 | 100.0 | | 90 | 78.9 | | -21.1
% on Diabetes Meds | 0-3m | | | Sleeve
% on Diabetes Meds | 0-3m
Diabetes Remission/Resolution | 0-3m | | | RYGB
Diabetes Remission/Resolution | 0-3m | | | LABG
Diabetes Remission/Resolution | 0-3m | | | Sleeve
Diabetes Remission/Resolution | 0-3m | | | BPD
BMI | 6-11m | 6-<12m^*^ | 5 | RYGB | 124 | 31.8 | 0.9 | 44 | 25.5 | 1.4 | -5.4
BMI | 6-11m | 6-<12m^*^ | 1 | LABG | 109 | 33.9 | | 40 | 27.1 | | -6.8
BMI | 6-11m | 6 | 1 | Sleeve | 30 | 30.3 | | 30 | 25.0 | | -5.3
BMI | 6-11m | 8m | 2^‡^ | BPD | 40 | 31.3 | 1.7 | 40 | 26.1 | 1.0 | -5.2
HbA1c | 6-11m | 6-9m | 4 | RYGB | 129 | 9.7 | 0.1 | 107 | 5.9 | 0.1 | -3.7
HbA1c | 6-11m | | 0 | LABG
HbA1c | 6-11m | 6m | 1 | Sleeve | 30 | 10.0 | | 30 | 7.4 | | -2.6
HbA1c | 6-11m | 6m | 1^‡^ | BPD | 30 | 9.3 | 0.2 | 30 | 6.4 | 0.5 | -2.9
Glucose | 6-11m | 6-9m | 3 | RYGB | 99 | 203.3 | 9.2 | 77 | 103.4 | 5.9 | -102.0
Glucose | 6-11m | | 0 | LABG
Glucose | 6-11m | | | Sleeve
Glucose | 6-11m | 8m | 1^‡^ | BPD | 30 | 220.0 | 14.0 | 30 | 152.0 | 19.0 | -68.0
% on Diabetes Meds | 6-11m | 6-<12m^*^ | 2 | RYGB | 124 | 100.0 | 0.0 | 44 | 29.5 | 21.2 | -70.5
% on Diabetes Meds | 6-11m | 6-<12m^*^ | 1 | LABG | 109 | 100.0 | | 40 | 72.5 | | -27.5
% on Diabetes Meds | 6-11m | | | Sleeve
% on Diabetes Meds | 6-11m | 8m | 1 | BPD | 10 | 40.0 | | 10 | 10.0 | | -30.0
Diabetes Remission/Resolution | 6-11m | 6m | 1 | RYGB | | | | 37 | 97.3
Diabetes Remission/Resolution | 6-11m | | 0 | LABG
Diabetes Remission/Resolution | 6-11m | | 1 | Sleeve
Diabetes Remission/Resolution | 6-11m | | 0 | BPD
BMI^†^ | 12-24m | 12-24m | 8 | RYGB | 315 | 32.2 | 0.6 | 168 | 23.9 | 0.5 | -7.9
BMI | 12-24m | >12m^*^ | 1 | LABG | 109 | 33.9 | | 11 | 29.9 | | -4.0
BMI | 12-24m | 12-13m | 2 | Sleeve | 42 | 31.9 | 2.5 | 42 | 25.5 | 1.7 | -6.4
BMI | 12-24m | 12-24m | 4^‡^ | BPD | 54 | 31.3 | 1.1 | 54 | 25.7 | 0.6 | -5.6
HbA1c^†^ | 12-24m | 12-24m | 9 | RYGB | 433 | 8.6 | 0.3 | 275 | 5.9 | 0.1 | -2.4
HbA1c | 12-24m | | 0 | LABG
HbA1c | 12-24m | 12-13m | 2 | Sleeve | 42 | 9.2 | 1.3 | 42 | 6.3 | 1.4 | -2.9
HbA1c | 12-24m | 12-24m | 3^‡^ | BPD | 47 | 9.1 | 0.2 | 47 | 6.0 | 0.4 | -3.1
Glucose | 12-24m | 12-24m | 5 | RYGB | 192 | 178.2 | 10.0 | 150 | 94.0 | 3.6 | -79.3
Glucose | 12-24m | | 0 | LABG
Glucose | 12-24m | 12-13m | 1 | Sleeve | 12 | 150.6 | | 12 | 88.0 | | -62.6
Glucose | 12-24m | 24m | 2^‡^ | BPD | 37 | 226.2 | 12.8 | 37 | 133.9 | 16.1 | -92.4
% on Diabetes Meds | 12-24m | 12-20m | 3 | RYGB | 293 | 100.0 | 0.0 | 188 | 12.8 | 4.6 | -87.2
% on Diabetes Meds | 12-24m | 12m^*^ | 1 | LABG | 109 | 100.0 | | 11 | 63.6 | | -36.4
% on Diabetes Meds | 12-24m | | 0 | Sleeve
% on Diabetes Meds | 12-24m | 24m | 1 | BPD | 7 | 71.4 | | 7 | 0.0 | | -71.4
Diabetes Remission/Resolution | 12-24m | 12-20m | 6 | RYGB | | | | 323 | 77.7 | 5.3
Diabetes Remission/Resolution | 12-24m | | 0 | LABG
Diabetes Remission/Resolution | 12-24m | 12m | 1 | Sleeve | | | | 30 | 46.7
Diabetes Remission/Resolution | 12-24m | 12m | 1^‡^ | BPD | | | | 30 | 83.5 | 16.5

BL= baseline; BMI = body mass index; BPD = biliopancreatic diversion; chg = change; F-up = followup; IGT = impaired glucose tolerance; IQR = inter-quartile range; LAGB = laparoscopic adjustable gastric banding; m = month; meds = medications; N = sample size; RYGB = Roux-en-Y gastric bypass; SE = standard error ; Sleeve = sleeve gastrectomy

* DeMaria et al. 2010^28^ reported results as 0-3m, 3-6m, 6-12m,12-24m. The range 6-12m was reported in the 6-11m category, 12-24m was reported in the >=12mth category.

† Serrot, 2011 (6027) only reported median and IQR. Median value used instead of mean for summary calculations.

‡ Scopinaro et al. 2001^49^ reports data for obese and overweight patients separately, both subgroups contribute to this analysis but it is only counted as 1 study/article.

Table 6 Bariatric surgery results—by surgery type, studies with less than 100% diabetes or IGT patients

Outcome | F-Up | F-Up Range | # Studies | Surg Type | BL (N) | BL Mean (%) | BL (SE) | F-Up (N) | F-Up Mean (%) | F-Up (SE) | Mean Chg
BMI | 6-11m | | 0 | RYGB
BMI | 6-11m | 6m | 2 | LABG | 263 | 33.74 | 0.32 | 244 | 30.68 | 1.04 | -3.11
BMI | 6-11m | | 0 | Sleeve
BMI | 6-11m | | 0 | BPD
HbA1c | 6-11m | | 0 | RYGB
HbA1c | 6-11m | | 0 | LABG
HbA1c | 6-11m | | 0 | Sleeve
HbA1c | 6-11m | | 0 | BPD
Glucose | 6-11m | | 0 | RYGB
Glucose | 6-11m | | 0 | LABG
Glucose | 6-11m | | 0 | Sleeve
Glucose | 6-11m | | 0 | BPD
% on Diabetes Meds | 6-11m | | 0 | RYGB
% on Diabetes Meds | 6-11m | | 0 | LABG
% on Diabetes Meds | 6-11m | | 0 | Sleeve
% on Diabetes Meds | 6-11m | | 0 | BPD
Diabetes Remission/Resolution | 6-11m | | 0 | RYGB
Diabetes Remission/Resolution | 6-11m | 6m | 1 | LABG | | | | 210 | 100.00
Diabetes Remission/Resolution | 6-11m | | 0 | Sleeve
Diabetes Remission/Resolution | 6-11m | | 0 | BPD
BMI | 12-24m | | 0 | RYGB
BMI | 12-24m | 24m | 3 | LABG | 356 | 33.47 | 0.38 | 302 | 28.09 | 0.68 | -5.47
BMI | 12-24m | 12m | 1 | Sleeve | 9 | 33.60 | | 9 | 23.40 | | -10.20
BMI | 12-24m | | 0 | BPD
HbA1c | 12-24m | | 0 | RYGB
HbA1c | 12-24m | | 0 | LABG
HbA1c | 12-24m | | 0 | Sleeve
HbA1c | 12-24m | | 0 | BPD
Glucose | 12-24m | | 0 | RYGB
Glucose | 12-24m | | 0 | LABG
Glucose | 12-24m | 12m | 1 | Sleeve | 9 | 99.20 | | 9 | 76.00 | | -23.20
Glucose | 12-24m | | 0 | BPD
% on Diabetes Meds | 12-24m | | 0 | RYGB
% on Diabetes Meds | 12-24m | | 0 | LABG
% on Diabetes Meds | 12-24m | | 0 | Sleeve
% on Diabetes Meds | 12-24m | | 0 | BPD
Diabetes Remission/Resolution | 12-24m | | 0 | RYGB
Diabetes Remission/Resolution | 12-24m | 12m | 1 | LABG | | | | 66 | 33.33
Diabetes Remission/Resolution | 12-24m | | 0 | Sleeve
Diabetes Remission/Resolution | 12-24m | | 0 | BPD
BMI^*^ | 36m | | 2 | LABG | 303 | 33.53 | 0.55 | 277 | 26.85 | 0.26 | -6.76
BMI^*^ | 48m | | 1 | LABG | 210 | 33.90 | | 210 | 27.90 | | -6.00
BMI^*^ | 60m | | 1 | LABG | 210 | 33.90 | | 210 | 28.20 | | -5.70
% on Diabetes Meds^*^ | 36m | | 1 | LABG | 93 | 8.60 | | 67 | 0 | | -8.60

BL= baseline; BMI = body mass index; BPD = biliopancreatic diversion with duodenal switch; chg = change; F-up = followup; IGT = impaired glucose tolerance; LAGB = laparoscopic adjustable gastric banding; m = month; meds = medications; N = sample size; RYGB = Roux-en-Y gastric bypass; SE = standard error ; Sleeve = sleeve gastrectomy

* Angrisani et al. 2004^39^ has BMI data for 36m-60m, Parikh et al. 2006^41^ has BMI data at 36m and % off diabetes meds at 36m.

#### BMI

At up to three months followup, mean decrease in BMI ranged from 2.3 kg/m^2^ in one study of LABG to 4.4 kg/m^2^ in three studies of RYGB. Between six and 11 months followup, BMI decrease continued. Decreases were similar for BPD (5.2 kg/m^2^), sleeve (5.3 kg/m^2^) and RYGB (5.4 kg/m^2^). The one LABG study that reported BMI during this time showed a decrease of 6.8 kg/m^2^ (in contrast, this study reported a mean decrease of 4.0 kg/m^2^ from baseline to 12 months.) At 12 to 24 months, mean BMI decrease was 5.6 kg/m^2^ for BPD, 6.4 kg/m^2^ for SG, and 7.9 kg/m^2^ for RYGB.

#### Blood Glucose

Metabolic improvements after surgery were reported various ways including changes in HbA1c and plasma glucose, percentage of patients who no longer required diabetes medication, and remission or resolution of diabetes. There were six surgery arms reporting change in HbA1c at six to 11 months. Baseline HbA1c values were quite high ranging from 9.3 percent for BPD to 10.0 percent for SG. Considerable decreases were reported after surgery, with a mean drop of 2.9 percentage points for BPD, 2.6 percentage points for sleeve and 3.7 percentage points for RYGB. Unfortunately, none of the observational studies of LAGB reported HbA1c outcomes. Studies that reported HbA1c at one year or more also reported clinically significant improvement. RYGB patients had a mean decrease of 2.4 percentage points, compared with 3.1 percentage points for SG and 3.1 percent points for BPD patients.

Studies also reported clinically significant improvements in plasma glucose levels. Many patients were hyperglycemic preoperatively. In studies reporting results at six to 11 months, baseline levels ranged from 203.3 mg/dL for RYGB patients to 220.0 mg/dL for sleeve. These studies reported decreases in plasma glucose of 68.0 mg/dL for BPD to 102.0 mg/dL in the one sleeve study. Studies with followup of at least one year reported decreases in plasma glucose ranging from 62.6 mg/dL in one sleeve study to 92.4 mg/dL for BPD. At this time point, most surgical patients were euglycemic.

#### Medication Needs

A few studies reported the percentage of patients who no longer required diabetes medication after surgery. The majority of these studies regularly measured and reported corresponding data on HbA1c, fasting glucose, C-Peptite, etc. One LAGB study (Parikh, 2006^41^ reported only the data regarding medication use, making it impossible to confirm whether discontinuation was appropriate; all eight diabetic patients discontinued medication.41 At three months or less, two RYGB studies reported that 46.6 percent of their patients no longer needed diabetes medication, compared with 21.1 percent of patients in one LABG study. Two RYGB studies reported that 70.5 percent of patients no longer required medication at six to 11 months after surgery compared with 27.5 percent in an LABG study and 30.0 percent in a BPD study. At 12 months, the LABG study reported 36.4 percent of patients discontinued medications. At 24 months, a BPD study of seven patients reported that all had discontinued medications. Three RYBG studies reported a mean 87.2 percent of patients had discontinued diabetes medications between 12 to 20 months. At 12 to 24 months followup, discontinuation rate was 87.2 percent in three RYGB studies.

#### Remission/Resolution

Eight studies reported at 12 months or more. Definitions of remission and resolution varied; however, all these studies monitored metabolic data regularly. 87.2 percent of RYGB patients in six studies had resolved their diabetes, along with half of SG patients in one study and 83.5 percent of BPD patients in one study.

### Observational Studies – Other Health Outcomes

#### Blood Pressure

Eight surgery studies reported blood pressure outcomes; measures reported included percent of patients with hypertension, percent able to discontinue blood pressure medication, and mean systolic and diastolic blood pressure. One study (primarily of non-diabetics) followed patients for 12 months after undergoing LAGB and found that the percentage of patients with hypertension decreased from 4.3 percent to 0.5 percent.39 Another reported that hypertension improved or resolved in 28.6 percent of patients, 18 months after receiving LAGB.44 Two LAGB studies reported the number who no longer required antihypertensive medications; one found that 75 percent were able to discontinue 24 months after surgery, while another found that 46 percent were able to 36 months post-op.41,43 Unfortunately, these two studies did not report corresponding systolic or diastolic blood pressure data. Four RYGB studies reported blood pressure outcomes. One reported that 41 percent of patients were off hypertension medications at one year; however, they did not report baseline percentage taking the medications. Mean systolic blood pressure in this RYGB group actually increased from 126.0 at baseline to 132.0 at one year.38 Another RYGB study30 reported hypertension resolved in 46.7 percent of patients at one year; however diastolic and systolic blood pressure data were not reported. Another RYGB study29 reported a mean 11 point drop in systolic blood pressure at six months. One study50 reported a mean decrease of 9 mmHg in diastolic and 11 mmHg in systolic blood pressure at six months.

#### Cholesterol and Triglycerides

Cholesterol and triglyceride outcomes were reported inconsistently. One small BPD study followed seven patients at one, two, three, and five years47 and reported that none had hypercholesterolemia or high triglycerides at any followup. Baseline mean triglycerides were 311.6 mg/dL in this study. Another study of 10 BPD patients reported a mean decrease of 106.3 mg/dL in total cholesterol at followup of two to 18 months. One LAGB study43 reported that 33.3% of patients no longer needed cholesterol medications at two years but gave no other details on this outcome. Lemback45 reported SG results separately for patients with diabetes versus impaired glucose tolerance (IGT) at one year post-surgery. Triglycerides decreased 69 mg/dL and 76 mg/dL respectively.

Five RYGB studies26,27,29,37,38 reported on cholesterol. Decreases in LDL ranged from only 3 mg/dL to 53.8 mg/dL at one year. Two studies reported change in total cholesterol. Shah29 reported a decrease of 40 mg/dL at nine months, while Cohen26 reported a decrease of 80 mg/dL at 20 months.

#### GERD and Sleep Apnea

A few studies reported on gastroesophageal reflux disease (GERD) and obstructive sleep apnea (OSA); these studies included a small subset of patients who had preoperative GERD or OSA who underwent LAGB. In one study that included five patients with preoperative GERD, all had complete resolution at one year after surgery.39 In a slightly larger study that included 22 patients with preoperative GERD, only 31.3 percent experienced improvement or resolution at one year after LAGB.44 Neither study detailed the exact methods of diagnosing resolution of GERD. Of the three studies that reported on OSA, one study found that half of the 19 patients had complete resolution (defined as discontinuation of continuous positive airway pressure [CPAP] mask use) at two years after LAGB and an additional 30 percent had improvement (decreased CPAP use).43 In another study that included seven patients with preoperative OSA, six had OSA resolution (did not require CPAP use) by three years after LAGB.41 In a third study, only three of nine patients with OSA had improvement or resolution at one year (definition of improvement or resolution not specified).44

### Systematic Reviews on Behavioral Interventions

The effects of interventions such as exercise, diet, and health education on weight loss and diabetes outcomes have been studied for decades. Thus, the primary literature on these topics is extensive. In such cases we attempt to find existing reviews.51 We identified six fair to excellent quality systematic reviews; four focused on adults with pre-existing diabetes while the other two focused on diabetes prevention in adults with impaired glucose tolerance. Details on the reviews are displayed in Table 7.

Table 7 Systematic reviews on nonsurgical interventions

Author / Year | Intervention | Patients | Search Through | # of Included Studies | AMSTAR | Findings
Norris, 2004^52^ | Exercise, diet, behavioral | Type 2 DM mean BMI = 33 range 23-38 mean HbA1C^*^ = 10 range 7–13 Mean age = 55 | August 2003 | 22 RCTs duration 1 year–5 years (16/22 ≤ 1.5 yr) | 10 | 1.7 kg weight loss for all interventions pooled, vs. usual care, at 1–5 years. Physical activity + very low cal diet lost 3.0 kg more than physical activity + low cal diet (N = 126). Identical diets + more intense physical activity lost 3.9 kg more. Differences in glycated hemoglobin and fasting glucose not significant.
Kirk, 2008^53^ | Low carbohydrate diets | Type 2 DM Mean weight = 77 – 132 kg Mean HbA1c^*^ = 6.9 – 9.8 North America only | April 2006 | 13 studies (9 RCTs) duration 3 weeks–26 weeks | 6 | No pooling conducted. Weight loss ranged from 0.5 to 8.7 kg from baseline at 3 to 26 weeks Decrease in HbA1c ranged from 0.3 to 2.2 points.
Dyson, 2008^54^ | Low carbohydrate diets | Type 2 DM Mean weight = 76 – 131 kg Mean BMI = 28 – 42 Mean age = 51 – 66 | March 2007 | 6 trials (1 RCT) duration 14 days – 22 months | 6 | No pooling conducted. Weight loss ranged from 1.2 to 11.4 kg from baseline . Decrease in HbA1c^*^ ranged from 0.5 to 1.4. Decrease in BMI ranged from 0.4 to 4.1 points.
Kodama, 2009^55^ | Low carbohydrate diets vs. low fat diets | Type 2 DM Mean BMI = 23 – 33 Mean age = 48 – 66 Mean % on diabetes meds = 52 | 2007 | 19 RCTs duration < 1 year | 9 | Low carb high cholesterol diet led to significant increases in fasting insulin and triglycerides from base, and decreases in HDL. Changes in HbA1c^*^ were not significant.
Norris, 2005^56^ | Weight loss Interventions (diet, physical activity, behavioral) | Adults with IGT, BMI range 26-34 Mean BMI 28.7 Mean age 51.2 Mean GHb 5.8 | August 2003 | 9 RCTs f/u 1 to 10 years 7 of the RCTs were diet vs. usual care/counseling | 10 | Pooled results 2.8 kg weight loss at 1 year compared with usual care & decrease in BMI of 1.4; at 2 years, 2.7 kg weight loss. No pooling for GHb. Decrease in GHb ranged from 0.0 to 0.2 percentage points. 3 studies reported diabetes incidence; one reported decrease of 31% at 2.8 years.
Gillies, 2007^57^ | Treatment to delay or prevent DM (pharma, diet, exercise) | Adults with IGT Mean age ranged 38.7 to 56.7 Mean BMI ranged 23.8 to 37.3 | July 2006 | 12 RCTs of behavioral interventions 12 RCTs of herbal/pharmacological 4 other studies | 9 | Hazard ratios for progression to diabetes: 0.51 for lifestyle vs. standard advice 0.70 for oral diabetes meds vs. control 0.44 for orlistat vs. control 0.32 for herbal jiang tang bushen vs. advice

AMSTAR = measurement tool to assess the methodological quality of systematic reviews; BMI = body mass index; DM = diabetes mellitus; GHb = glycated hemoglobin IGT = impaired glucose tolerance; RCTs = randomized controlled trials

* HbA1C measured as a percentage of total hemoglobin.

Pooling 22 RCTs with a total of 4,659 participants and a followup interval of 1 to 5 years, Norris and colleagues52 assessed the effectiveness of lifestyle and behavioral interventions on weight loss or weight control among adults with type 2 diabetes (mean BMI = 33.2kg/m^2^, mean duration of diabetes = 6.5 years). Interventions examined included physical activity, low calorie diet, and behavioral interventions such as self-monitoring blood glucose and spousal involvement in education. Comparisons of three groups of studies were conducted: any intervention versus usual care, very low-calorie diet versus low-calorie diet, and physical activity versus no or less intensive physical activity. The pooled weight loss for intervention group (any intervention) in comparison with usual care was 1.7 kg at 1 and 2 years of followup, and the pooled weight loss for very low-calorie diets in comparison with low-calorie diets was 3.0 kg at 72 and 104 weeks of followup. Among those who received identical dietary and behavioral interventions, the pooled weight loss for intensive physical activity in comparison with no or less physical activity was 3.9 kg. Of the six intervention types (including usual care and different combinations of interventions), all interventions were associated with significant weight loss, but a very low-calorie diet combined with physical activity and behavioral therapy produced the largest weight loss effect. However, changes in glycated hemoglobin level were not significant.

Kirk and colleagues (2008) evaluated 13 studies (including nine RCTs) that examined effects of carbohydrate-restricted diets in type 2 diabetes patients (mean weight = 77 to 132 kg, mean HbA1c = 6.9 – 9.8) in North America.53 Seven outcomes were reported: weight, fasting glucose, HbA1c, total cholesterol, HDL cholesterol, LDL cholesterol, and triglycerides. At 3 to 26 weeks followup, weight loss after carbohydrate-restricted diets ranged from 0.5 to 8.7 kg, representing 0.5 percent to 7.5 percent changes from baseline; decrease in HbA1c ranged from 0.2 to 2.2, representing 2.9 percent to 22.4 percent changes from baseline; and reduction in fasting glucose ranged from 1.8 to 83.0, representing 1.3 percent to 36.6 percent changes from baseline. They also found a greater mean reduction in fasting glucose and HbA1c in the lower-carbohydrate diet phase compared with the higher-carbohydrate diet phase. While triglyceride reductions were observed in both lower- and higher-carbohydrate phases, an especially strong relationship was found in the lower-carbohydrate phase. No significant relationships were found for the three cholesterol outcomes.

Dyson, 2008^54^ reviewed 6 studies (including one RCT) that examined short-term effect and associated risks of low and reduced carbohydrate diets in type 2 diabetes patients (mean BMI = 28.5 to 42.2kg/m^2^, mean HbA1c = 7.3 to 9.7). Meta-analysis was not conducted due to heterogeneity of the studies. Sample size ranged from 10 to 206; only two studies had sample size over 100). Short-term effects (followup duration n= 14 days – 22 months but only two studies with data beyond six months) were reported and carbohydrate levels ranged from <20g/day to 95g/day. All studies reported reductions in body weight and glycated hemoglobin: reductions in body weight ranged from 1.2 to 11.4 kg, reductions in BMI ranged from 0.4 to 4.1 kg/m^2^, and reductions in HbA1c ranged from 0.5 to 1.7 points. A few studies also recorded either reduction or discontinuation of glucose-lowering medications such as metformin and thiazoladinediones.

Kodama and colleagues55 conducted a meta-analysis to assess the influence of fat and carbohydrate proportions on glucose and lipid parameters in type 2 diabetes patients. Pooling 22 trials with a total of 306 participants (mean BMI = 22.7 to 33.1kg/m^2^, diabetes duration = 5 to 8 years) and an intervention period of 1.4 to 12 weeks, the study compared the effects of a low-fat high-carbohydrate (LFHC) diet with a high-fat low-carbohydrate (HFLC) diet. While no significant differences in the reduction in HbA1c, total cholesterol, and LDL cholesterol were found between the LFHC and HFLC diets, LFHC diet led to significant increases in fasting insulin (8.4 percent, with marked elevations observed when the carbohydrate/fat ratio >=3) and triglycerides levels (13.4 percent), and a significant reduction in HDL cholesterol (6 percent). They also found significant positive relationships among the change in fasting plasma glucose, fasting insulin, and triglycerides. They concluded that replacing fat with carbohydrate have negative implications for diabetes patients.

Norris and colleagues56 examined the effects of weight-loss interventions in 9 RCTs consisting a total of 5,168 overweight or obese participants (mean BMI = 25.8 to 34.0 kg/m^2^, mean glycated hemoglobin (GHb) = 5.7 to 5.9) with pre-diabetes (impaired fasting glucose or impaired glucose tolerance). Most of the studies reported long-term data, with followup durations ranging from 1 to 10 years. Weight-loss strategies included diet, physical activity, and behavioral interventions, while comparison group interventions consisted of usual care or general information and counseling. Compared with usual care, these weight-loss interventions led to 2.8 kg weight loss at one year (representing 3.3 percent of baseline body weight) and 2.7 kg at two years; reduction in BMI was 1.4 kg/m^2^ at 1 year. The most notable mean weight change was observed in the lifestyle intervention of the DPP (Diabetes Prevention Program) study, which had the largest study population. It reported a mean weight loss of 5.5 kg at an average followup of 2.8 years. A few studies reported small decreases in systolic and diastolic blood pressure, minor improvements in lipids, and 0.0 to 0.2 decreases in GHb. Three large trials also demonstrated a significant lower cumulative incidence of diabetes in the intervention versus control groups, at three to six years followup.

Gillies and colleagues57 also reviewed studies that evaluated interventions to delay or prevent type 2 diabetes among patients with impaired glucose tolerance. Behavioral interventions included diet and exercise; pharmacological/herbal interventions included acarbose, flumamine, glipizide, metformin, phenformin, orlistat, and herbal iangtang busheng. They identified 21 RCTs and conducted a meta-analysis using 17 RCTs with a total of 8,084 participants (mean BMI = 23.8 to 37.3 kg/m^2^, baseline risk of type 2 diabetes = 2.6 to 30.0 cases per 100 person years). They found high strength of evidence in favor of interventions compared with controls, the pooled effects (in terms of hazard ratios) were 0.51 for overall behavioral interventions (corresponding to a relative 49 percent reduction in risk of developing diabetes), 0.67 for diet, 0.49 for exercise, 0.49 for diet and exercise combined, 0.70 for oral diabetes drugs, 0.44 for orlistat, and 0.32 for the herbal Jiangtang busheng recipe. All except for the herbal Jiangtang busheng recipe were statistically significant. The authors concluded that behavioral interventions were at least as effective as pharmacological interventions.

In sum, compared with surgical options, the effects of nonsurgical weight loss or weight control strategies among type 2 diabetes patients have been widely investigated. Evidence has shown that exercise, diet, lifestyle, and behavioral interventions are associated with significant weight loss and improved blood sugar outcomes (e.g., decreasing HbA1c or fasting glucose) among adult patients with pre-existing type 2 diabetes. Evidence is stronger for the weight loss effect, compared with the diabetes improvement effect, and more intensive and sustained interventions seem more effective. These findings were consistent with those found in non-diabetic but high-risk population with impaired glucose tolerance or impaired fasting glucose. Among those patients, nonsurgical interventions were associated with reduced risk of developing diabetes in the long run. However, studies also pointed out that the magnitude of effects of nonsurgical interventions in reducing weight and improving blood sugar outcomes are often small, although statistically significant. Most of these systematic reviews reported that studies were very heterogeneous with respect to the interventions; thus the effects should be interpreted cautiously.

### Systematic Reviews of Diabetes Medications

Four high quality systematic reviews focused on the efficacy and safety of diabetes medications in patients with type 2 diabetes. Two of the reviews11,58 examined incretin-based agents (exenatide, liraglutide, vildagliptin, and sitagliptin), another59 examined oral agents (second-generation sulfonylureas, biguanides, thiazolidinediones, meglitinides, and α-glucosidase inhibitors), and one60 examined newer agents available for blood glucose control (exenatide, sitagliptin and vildagliptin, glargine and detemir, and thiazolidinediones). These reviews provide evidence that most blood glucose control medications are effective in glycemic control; some of them also lead to weight loss. However, clinical data such as effects on all-cause and cardiovascular mortality are limited. Results are summarized in Table 8.

Table 8 Systematic reviews of medications

Author / Year | Intervention | Patients | Search Through | # of Included Studies | AMSTAR | Findings
Fakhoury, 2010^58^ | Incretin-based medications: exenatide, liraglutide, vildagliptin, and sitagliptin | Type 2 DM mean weight = 61.5 - 104.0 kg mean HbA1C^*^ = 6.7 - 9.4 Mean age = 50.9 - 62.9 | July 2009 | 38 RCTs Duration 4 - 52 weeks | 7 | All agents significantly reduced HbA1c^*^ level in comparison with placebo (pooled results of weighted mean differences: -1.03, -0.79, -0.75, -0.67 percentage points for liraglutide, sitagliptin, exenatide, and vildaglitin, respectively); weight loss associated with exenatide (WMD= -1.10).
Waugh, 2010^60^ | Exenatide, sitagliptin and vildagliptin, glargine and detemir, and thiazolidinediones | Type 2 DM mean weight/BMI/HbA1c^*^ separately reported for each arm | April 2008 | Hard to count # of included studies since reported separately for individual arms; but > 24 RCTs and 10 Systematic reviews Duration >=12 weeks | 9 | Exenatide and DPP-4 inhibitors were effective in glycemic control: adding exenatide produced a 1 percentage point point reduction in HbA1c^*^ in patients with inadequate control on dual oral combination therapy; DPP-4 inhibitors + metformin reduced HbA1c by 0.8 percentage points; pioglitazone + insulin reduced HbA1c by 0.54 percentage points.
Bolen, 2007^59^ | Oral medications: second-generation sulfonylureas, biguanides, thiazolidinediones, meglitinides, and α-glucosidase inhibitors | Type 2 DM | January 2006 | 216 Controlled trials and cohort studies 2 Systematic reviews Duration >= 3 mo | 10 | Pooled result: thiazolidinediones, metformin, and repaglinide decreased HbA1c^*^ by one percentage point; No pooling for nateglinide and α-glucosidase inhibitors: reduced HbA1c by 0.5 percentage point; No effectiveness evidence on all-cause mortality, cardiovascular mortality or morbidity, peripheral arterial disease, neuropathy, retinopathy, or nephropathy.
Visboll, 2012^11^ | GLP-1R agents: Exenatide, Liraglutide | Overweight or obese patients with or without Type 2 DM | May 2011 | 25 RCTs Duration ≥ 20 weeks | 9 | Patients with diabetes lost a mean 2.8kg on the drugs; weight loss was greater with higher doses. Control groups included placebo, insulin, and oral diabetic medication groups. GLP-1R agonist groups had significantly greater decreases in blood pressure, cholesterol, and HbA1c than control groups. Gastro-intestinal adverse events including nausea, vomiting, and diarrhea were common in the GLP-1R agonist groups.

AMSTAR = measurement tool to assess the methodological quality of systematic reviews; BMI = body mass index; DM = diabetes mellitus;DPP-4 = dipeptidyl peptidase-4; GLP-1R = GLP-1 Agonists: Glucagon-like peptide-1 agonists, a class of diabetes drugs targeting the incretin system; RCTs = randomized controlled trials, WMD = weighted mean difference

* HbA1C measured as percentage of total hemoglobin.

Fakhoury and colleagues58 conducted a systematic review and a meta-analysis to compare incretin-based agents with placebo. They identified 38 RCTs directly comparing either exenatide and liraglutide, which are GLP-1R agonists, or the dipeptidyl / peptidase-4 (DPP-4) inhibitors, vildagliptin and sitagliptin with placebo. Mean baseline HbA1c of participants included in the study ranged from 6.7 to 9.4 percent, mean duration of diabetes from 1.7 to 9.0 years, and mean baseline weight from 61.5 to 104.0 kg. Duration of trials ranged from 4 to 52 weeks. While all incretin-based agents significantly reduced HbA1c level in comparison with placebo (weighted mean difference [WMD]= -0.79 percentage points, -0.75, and -0.67 percentage points for sitagliptin, exenatide, and vildagliptin, respectively), liraglutide was found to produce the greatest reduction (WMD= - 1.03 percentage points) although this value was not statistically different from the other incretin-based drugs. A statistically significant weight gain was found in vildagliptin and sitagliptin groups, while a statistically significant weight reduction was found in the exenatide and liraglutide groups, especially in the exenatide group. Participants in sitagliptin and exenatide groups were more likely to experience some hypoglycemia compared with participants in the placebo group. The authors concluded that incretin-based agents produced beneficial effect on glycemic control, and that exenatide and liraglutide also led to weight loss. A new meta-analysis on these two GLP-1R agonists was published recently.11 RCTs comparing exenatide or liraglutide with placebo, oral antidiabetic medication, or insulin were included. The authors found that patients taking these GLP-1R agonists lost a mean 2.90 kg (95% CI 2.22 kg to 3.59kg) more than patients in the control groups. Decrease in systolic blood pressure averaged 3.57 mmHg (95% CI 5.49 to 7.66) more than in the control groups, while decrease in diastolic blood pressure was also significantly greater (1.38 mmHg, 95% CI 0.73 to 2.22). Reduction in HbA1c (0.63 percentage points, 95% CI 0.80 to 0.46) was also superior in the GLP-1R agonistic groups. Gastro-intestinal adverse events including nausea, vomiting, and diarrhea were more common in the groups taking these medications.

Bolen and colleagues59 reviewed the benefits and harms of oral agents in treating type 2 diabetes patients in the United States Two hundred and sixteen controlled trials and cohort studies were included. No evidence was found to support the effectiveness of oral agents on major clinical end points such as all-cause mortality, cardiovascular mortality or morbidity, peripheral arterial disease, neuropathy, retinopathy, or nephropathy. However, most oral agents showed a beneficial effect on intermediate outcomes such as glycemic control: thiazolidinediones, metformin, and repaglinide decreased HbA1c level by about one percentage point; nateglinide and α-glucosidase inhibitors produced weaker reductions in HbA1c by about 0.5 percentage point. Most oral agents other than metformin were associated with one to five kg of weight gain. Different agents were associated with different adverse events: sulfonylureas and repaglinide were associated with greater risk for hypoglycemia, thiazolidinediones with greater risk for heart failure, and metformin with greater risk for gastrointestinal problems. The authors concluded that older agents such as second-generation sulfonylurea and metformin were at least as effective as other oral agents on intermediate outcomes such as glycemic control.

A group of UK researchers reviewed newer pharmacological agents60 for blood glucose control in type 2 diabetes patients from four classes: the glucagon-like peptide-1 (GLP-1) analogue exenatide; dipeptidyl peptidase-4 (DPP-4) inhibitors sitagliptin and vildagliptin; the long-acting insulin analogues, glargine and detemir; and thiazolidinediones. While focused on cost-effectiveness and comparing newer agents with neutral protamine Hagedorn (NPH), the study found that exenatide and DPP-4 inhibitors were all clinically effective in glycemic control: in patients with inadequate control on dual oral combination therapy, adding exenatide produced a one percentage point reduction in HbA1c level; when combined with metformin, the DPP-4 inhibitors reduced HbA1c level by about 0.8 percentage point. Exenatide was found to be associated with an added benefit of weight loss. Hypoglycemia, weight gain, heart failures, fractures, and cardiovascular events were among the side effects associated with the agents.

### Major Trials Published After the Systematic Reviews

Since the systematic reviews discussed above were published, several long-term followups of included studies have been published. These studies assessed the long-term effects of nonsurgical interventions in China61 (behavioral intervention), Finland62 (behavioral), United States63 (behavioral and medications), and the United Kingdom64 (medications). Weight loss effects that were observed during active intervention period did not always persist in the long run, while the reductions in diabetes incidence and diabetes-related end points persisted. This effect was consistent across locations. However, behavioral interventions did not lead to any significant reduction in some major clinical end points such as mortality. Pharmacological interventions reduced mortality in the long run only in the U.K. study64. More long-term data are needed to investigate morbidity reduction effects of nonsurgical interventions.

In China, Li and colleagues61 conducted a 20-year followup study of the China Da Qing Diabetes Prevention Study (CDQDPS), which compared behavioral interventions (diet, exercise, and diet plus exercise) with a control group among adults with impaired glucose tolerance. Long-term effect on the risk of diabetes, diabetes-related macrovascular and microvascular complications, and mortality were reported. Although changes in body weight during the entire 20-year followup period did not differ significantly by intervention and control groups, participants in the intervention group had a 43 percent lower incidence of diabetes over the 20-year period, compared with those in control group. The average annual incidence of diabetes and 20-year cumulative incidence of diabetes were lower in the intervention group (7 percent annual incidence and 80 percent cumulative incidence) than those in the control group (11 percent annual incidence and 93 percent cumulative incidence). Diabetes onset was delayed an average of 3.6 years in the intervention group. However, no significant difference was observed in the rate of first cardiovascular disease (CVD) event, CVD mortality, and all-cause mortality between intervention group and control group. The authors concluded that behavioral interventions produced a long-lasting reduction in the incidence of type 2 diabetes.

Ilanne-Parikka and colleagues62 reported on the Finnish Diabetes Prevention Study and assessed effects of behavioral intervention on metabolic syndrome and its components. Mean BMI at baseline was 31.2, with a standard deviation of 4.6 kg/m^2^. At mean followup of 3.9 years, they found that intensive behavioral intervention produced a significant reduction in the prevalence of metabolic syndrome (from 74.0 percent to 58.0 percent), compared with the standard care provided to the control group (from 74.0 percent to 67.7 percent). A reduction in the prevalence of abdominal obesity in the long term was also observed in intervention group (odds ratio = 0.48).

In the United States, Knowler and colleagues63 conducted a 10-year followup study of the DPP and investigated the persistence of the diabetes incidence and weight loss effects of behavioral and medication interventions that were observed during the intervention period. The effect of an intensive behavioral intervention and metformin on diabetes incidence, weight loss, and cardiovascular disease risk were compared with that of placebo. During the 10-year followup period, the behavioral group lost the most weight initially, and then gradually regained weight (but still weighed less than they did at baseline), while the metformin group maintained a modest weight loss. Cumulative incidence of diabetes in the 10 years was reduced by 34 percent in the behavioral group and 18 percent in the metformin group. It remained lower in the behavioral and metformin groups than in the placebo group, although diabetes incidence during the 10-year followup did not differ significantly between groups. Diabetes onset was delayed in behavioral group and metformin group by four years and two years, respectively, compared with placebo group. The authors concluded that both behavioral and metformin interventions reduced cumulative incidence of diabetes; this effect persisted for at least 10 years.

Holman and colleagues64 performed a 10-year followup study of the United Kingdom Prospective Diabetes Study (UKPDS), which compared effects of an intensive glucose therapy (sulfonylurea or insulin or, in overweight patients, metformin) with conventional dietary therapy. No significant difference in mean body weight had been found between groups. After one year, between-group differences in mean glycated hemoglobin levels were lost: participants in both groups had similar improvements. However, the sulfonylurea/insulin group maintained significant reductions in relative risk for any diabetes-related end point (risk reduction 9 percent) and microvascular disease (risk reduction 24 percent) observed during the active intervention period. Overtime, the sulfonylurea/insulin intervention reduced risks for diabetes-related mortality, myocardial infarction, and all-cause mortality by 17 percent, 15 percent, and 13 percent, respectively, compared with the conventional dietary therapy. Among overweight patients, over 10 years, metformin reduced risks for any diabetes-related end point, diabetes-related mortality, myocardial infarction, and all-cause mortality by 21 percent, 30 percent, 33 percent, and 27 percent, respectively.

Three large RCTs recently published initial findings that were not included in the systematic reviews. The studies assessed nonsurgical interventions in India,65 Spain,66 and the U.K. Findings suggest that interventions can be effective across different ethnic populations, despite different BMI and other clinical and diabetes related characteristics.

In India, Ramachandran and colleagues65 conducted a RCT in urban Asian Indians (mean BMI 25.8, SD 3.5 kg/m^2^) with persistent IGT that evaluated the effects of behavioral modifications and metformin on the development of type 2 diabetes. With a median followup duration of 30 months, they found that compared with the control group, both behavioral modification and metformin significantly reduced the cumulative incidence of diabetes at year 3 (39.3 percent, 40.5 percent, and 55.0 percent in behavioral modification, metformin, and control group, respectively), while no added benefit was observed to combine lifestyle modification and metformin (39.5 percent). This represented a relative risk reduction of 28.5 percent, 26.4 percent, and 28.2 percent with behavioral modification, metformin, and the combination, in comparison with control, respectively.

In Spain, Salas-Salvado and colleagues66 reported one year data from the PREDIMED trial, which evaluated the effect of two diet interventions (Mediterranean diet plus virgin olive oil and Mediterranean diet plus nuts) on metabolic syndrome status compared with a control (low-fat diet advice) among older participants at high risk for CVD. Mean BMI at baseline was 29.3 kg/m^2^. They found a significant reduction of overall prevalence of metabolic syndrome in the Mediterranean diet plus nuts group (prevalence reduced by 13.7 percent), compared with that in control group (prevalence reduced by 2.0 percent). Although no significant difference in the incidence rates of metabolic syndrome was observed among groups, the effect of Mediterranean diet plus nuts seemed more a consequence of higher rates of reversion among those who had the metabolic syndrome at the baseline. Mediterranean diet plus virgin olive oil showed a nonsignificant reduction in metabolic syndrome prevalence. The authors concluded that a beneficial effect on metabolic syndrome could be achieved by diet alone.

Finally, a 12-month RCT67 was carried out in 13 sites in primary care in the UK to evaluate the effectiveness of a structured group education program focused on behavior change among newly diagnosed type 2 diabetes patients (mean BMI= 32.3 kg/m^2^; mean HbA1c=8.1). In addition to weight loss and blood glucose outcomes, this study also reported behavioral outcomes (smoking status and physical activity), psychosocial outcomes (illness belief and depression), and quality of life at 4, 8, and 12 months. Compared with usual care, the education intervention was found to be associated with significant weight loss (2.98 kg in education intervention group vs. 1.86 kg in usual care group), a significant reduction in triglyceride levels at eight months, a significant reduction in smoking status at all time points, and a significantly greater increase in physical activity at 4 months. The education intervention group also showed significantly greater understanding of their illness and its seriousness, and had a lower depression score. However, changes in HbA1c level and quality of life scores were not significantly different between groups at any time point.

### Summary

Table 9 displays a summary of data on interventions and outcomes in patients with diabetes or IGT. While direct comparisons of these interventions in many cases have not been assessed in randomized trials, it is nonetheless useful to present the data in a side-by-side format. We discuss the limitations of such comparisons in detail in the discussion section; readers should keep in mind that patients enrolled in the nonsurgical trials of medication and behavioral interventions differ in important ways from those participating in the surgical studies.

Table 9 Summary of data on interventions and outcomes in patients with diabetes or impaired glucose tolerance

Outcome | Behavioral Changes (Data Almost Entirely From Systematic Reviews, RCTs) | Intervention Medications (Data Almost Entirely From Systematic Reviews, RCTs) | Bariatric Surgery (Data Primarily From Observational Studies)
Weight loss at one year: | 2.8 kg for diet, exercise, behavioral vs. usual care. | Weight gain from 1 to 5 kg with some drugs. 2.8 kg weight loss with GLP-1R agonists. No weight change with metformin. | BMI loss of 5 to 7 kg/m^2^ (about 15 to 20 kg for someone 5 foot 6 inches tall)
Weight loss at two years: | 2.7 kg for diet, exercise, behavioral vs. usual care. | Data unavailable. | BMI loss of 4 to 8 kg/m^2^ (about 11 to 23 kg for someone 5 foot 6 inches tall)
Long term weight loss (five years and more): | 1.7 kg for diet, exercise, behavioral vs. usual care at 5 years. | Few data; the U.S. Diabetes Prevention Program Outcomes Study (DPPOS) found no significant change with metformin at 10 years. | BMI loss of 5.7 kg/m^2^ at 5 years, in one study of 29 LAGB patients
HbA1C, percentage of total hemoglobin, at one year: | Decrease of 0.3 to 2.2 percentage points. | Decrease of 0.5 to 1.0 percentage points. | Decrease of 2.6 to 3.7 percentage points.
HbA1C at two years: | No significant change. | Few data; the UKPDS study found no significant difference in HbA1c for sulfonylurea-insulin or metformin at 2 year time-point. | Decrease of 1.8 to 3.1 percentage points.
HbA1C at five years and more: | Few data; the U.S. Diabetes Prevention Program Outcomes Study (DPPOS) found HbA1C concentrations lower in behavioral group at 10 years (vs. placebo). | Few data; the U.S. Diabetes Prevention Program Outcomes Study (DPPOS) found HbA1C concentrations lower in metformin group at 10 years (vs. placebo). | Data unavailable.
Other metabolic outcomes at one year: | Diet improved fasting glucose (1.3%-36.6% reduction) and triglycerides (11.3% - 58.9% reduction); the Spain PREDIMED study found Mediterranean diet reduced metabolic syndrome prevalence by 13.7% at 1 year; the Finnish Diabetes Prevention Study (DPS) found behavioral change reduced metabolic syndrome prevalence at 3.9 years (odds ratio: 0.62). | Most medications had minimal effects on systolic & diastolic blood pressure (< 5 mmHg change). Metformin and second generation sulfonylureas generally decreased LDL cholesterol levels. | Mixed results, one RYGB and one BPD study reported slight increase in triglycerides at one year.
Other metabolic outcomes at five years and more: | Data unavailable. | Data unavailable. | Of 7 BPD patients followed, all had normal serum cholesterol and triglycerides.
Microvascular outcomes: (Renal disease, neuropathy, retinopathy, etc) | Data unavailable. | UK Prospective Diabetes Study (UKPDS) found patients taking sulfonylurea, insulin, or metformin had 24% risk reduction for microvascular disease at 10 years. | Data unavailable.
Macrovascular outcomes: (Cardiovascular disease, stroke, heart attack) | Few data; the China Da Qing Diabetes Prevention Study (CDQDPS) found no significant difference in first CVD event, CVD mortality and all-cause mortality between intervention and control group. | Meta-analysis of 5 trials with 33,040 participants found that on an average A1C reduction of 0.9% there was a 19% reduction in non-fatal myocardial infarction and a 15% reduction on coronary heart disease, and no statistically significant effect on stroke or all cause mortality. | Data unavailable.
Prevention of diabetes: | Hazard ratio 0.51 for behavioral interventions vs. standard advice at 1 to 5 years; the U.S. Diabetes Prevention Program (DPP) found diabetes incidence in 10 years reduced by 34% by behavioral change vs. placebo, and the China Da Qing Diabetes Prevention Study (CDQDPS) found it was 43% lower in behavioral group over 20 years. | Hazard ratio 0.70 for oral medications vs. control at 1 to 5 years; the U.S. Diabetes Prevention Program (DPP) found diabetes incidence in 10 years reduced by 18% in the metformin group vs. placebo. | Data unavailable.

HbA1C = Glycosylated hemoglobin; BPD = biliopancreatic diversion; BMI = body mass index; CVD = cardiovascular disease; GLP-1R = GLP-1 Agonists: Glucagon-like peptide-1 agonists, a class of diabetes drugs targeting the incretin system; LAGB = laparoscopic adjustable gastric banding; LDL = low-density lipoprotein cholesterol; RCT = randomized controlled trial; RYGB = Roux-en-Y gastric bypass

#### Short-Term Outcomes

Based on glucose outcomes, there is moderate strength evidence of efficacy of bariatric surgery in treating diabetes in patients with BMI of at least 30 but less than 35 kg/m^2^ in the short term. At one year, surgery patients show much greater weight loss than usually seen in studies of diet, exercise, or other behavioral interventions. With the exception of GLP-1T agonists, diabetes medications do not cause significant weight loss. While both behavioral interventions and various medications have been shown to lower HbA1c levels significantly, the decreases reported in bariatric surgery patients at one year are greater. Improvements in glucose control outcomes have been reported as early as one month post-surgery.68 Improvements in hypertension, and cholesterol have been reported at one year in some studies. We judged this evidence as moderate due to sparseness of data - only three RCTs directly compared surgery with nonsurgical interventions; two came from the same group of researchers. Observational data, which start as “low” strength evidence, were upgraded due to consistency of results regarding BMI and blood sugar. Thus, the total body of evidence is considered moderate strength.

#### Long-Term Outcomes

There are few long-term data on patients in this weight class with diabetes or IGT who have undergone bariatric surgery. We identified only two studies, both observational, with followup of three or more years. One, a case series of LAGB patients in Italy, reported followup at five years for 29 of the 210 initial patients, for a followup rate of only 13.8 percent. Another small Italian study followed BPD patients for over 10 years; there were only seven patients total. Thus, the evidence that bariatric surgery is an effective way to treat diabetes or IGT in patients with BMI of at least 30 kg/m^2^ but less than 35 kg/m^2^ in the long term is insufficient, due to the small number of patients followed. In contrast, behavior and medication interventions have been studied extensively for decades; several large long-term RCTs have found improved HbA1c levels continue for ten years. Some long-term trials and meta-analyses have reported clinically significant improvements in microvascular and macrovascular outcomes as a result of behavioral or medication interventions.

#### Specific Bariatric Procedures

Taking into consideration the entire body of evidence, we rate the strength of evidence as moderate for RYGB, LAGB and gastric sleeve for treating diabetes and IGT in patients with a BMI of between 30 kg/m^2^ and 35 kg/m^2^, in the short term (up to two years). Each of these procedures have shown efficacy in two randomized trials, in addition to numerous observational studies. In contrast, BPD has not been studied in randomized trials in this particular population, although five observational studies have been published. Thus, the strength of evidence for BPD is rated low.

In two RCTs, RYGB patients lost significantly more weight than gastric sleeve patients. Both RCTs reported better blood glucose outcomes for RYGB; the difference was statistically significant in one. Observational data echo these findings, and also support that RYGB patients have greater changes in weight and blood glucose in the short term than those undergoing LABG. These results must be balanced with the different adverse event profiles of the procedures, discussed in the results for KQ 3.

## KQ3 What are the potential short-term adverse effects (AEs) and/or complications involved with bariatric surgery for treating adult patients with BMI of 30 to 34.9 who have metabolic conditions?

The incidence of adverse events following bariatric surgery is displayed in Table 10 for all studies, including case series, cohorts and controlled trials. Adverse events for the few nonsurgical arms of these studies are also displayed. Followup times varied widely from the day of surgery to 2 years; the exception are two studies that reported events up to 3 and 5 years post-surgery. Few studies were clear exactly when the adverse events took place, and patients who were lost to followup had missing adverse events data. Adverse events were often identified and self-reported by the surgical team, with definitions of some complications varying from study to study. Little administrative data were available to diminish these biases. In addition, there were few studies that compared adverse events between different surgical procedures, making direct comparisons difficult.

Table 10 Incidence of adverse events - surgical weight loss treatments

Adverse Event^*^ | Subcategory | Nonsurgical Arms | | | | LAGB | | | | Gastric Sleeve | | | | RYGB | | | | BPD
Adverse Event^*^ | Subcategory | # Arms | # With Event | N | %^**^ | # Arms | # With Event | N | %^**^ | # Arms | # With Event | N | %^**^ | # Arms | # With Event | N | %^**^ | # Arms | # With Event | N | %^**^
Cardiovascular/Respiratory | Pulmonary embolism | | | | | | | | | | | | | | | | | 1 | 1 | 10 | 10.00
Cardiovascular/Respiratory | TIA | 1 | 1 | 30 | 3.33
Cardiovascular/Respiratory | Arrhythmia | 1 | 2 | 43 | 4.65 | | | | | 1 | 1 | 49 | 2.04 | 2 | 1 | 159 | 0.63
Cardiovascular/Respiratory | Pneumonia | 1 | 0 | 43 | 0.00 | | | | | 1 | 1 | 49 | 2.04 | 3 | 5 | 268 | 1.87
Constitutional | Cellulitis (nonwound related) | 1 | 1 | 43 | 2.33 | 1 | 1 | 30 | 3.33 | 1 | 0 | 49 | 0.00 | 1 | 0 | 50 | 0.00
Constitutional | Not specified | 1 | 1 | 30 | 3.33
Gastro-intestinal | Anorexia or excessive weight loss | 1 | 0 | 43 | 0.00 | | | | | 1 | 0 | 49 | 0.00 | 3 | 0 | 69 | 0.00
Gastro-intestinal | Cholecystitis/Other biliary | 2 | 4 | 83 | 4.82 | 1 | 1 | 40 | 2.50 | 1 | 0 | 49 | 0.00 | 2 | 2 | 159 | 1.26
Gastro-intestinal | Dehydration | 1 | 4 | 43 | 9.30 | | | | | 1 | 4 | 49 | 8.16 | 1 | 11 | 50 | 22.00
Gastro-intestinal | Excessive weight gain | 1 | 3 | 43 | 6.98 | | | | | 1 | 0 | 49 | 0.00 | 1 | 0 | 50 | 0.00
Gastro-intestinal | Feeding difficulties | 2 | 3 | 70 | 4.29 | 2 | 3 | 83 | 3.61 | | | | | 1 | 1 | 109 | 0.92
Gastro-intestinal | Reflux/Hiatal hernia | | | | | 2 | 4 | 146 | 2.74 | | | | | 1 | 0 | 37 | 0.00
Gastro-intestinal | Diarrhea | 1 | 1 | 30 | 3.33 | | | | | | | | | 1 | 1 | 22 | 4.55
Gastro-intestinal | Gastroplegia | | | | | | | | | | | | | | | | | 1 | 4 | 30 | 13.33
Gastro-intestinal | Ileus | | | | | 1 | 1 | 109 | 0.92
Gastro-intestinal | Vomiting and/or nausea | | | | | 1 | 1 | 109 | 0.92 | | | | | 1 | 4 | 109 | 3.67
Gastro-intestinal | Not specified | 2 | 10 | 70 | 14.29 | 1 | 1 | 30 | 3.33
Metabolic | Ketoacidosis | 1 | 0 | 43 | 0.00 | | | | | 1 | 0 | 49 | 0.00 | 1 | 1 | 50 | 2.00
Metabolic | Anemia | 1 | 3 | 43 | 6.98 | | | | | 1 | 6 | 49 | 12.24 | 1 | 6 | 50 | 12.00
Metabolic | Hypoglycemia^†^ | 2 | 36 | 73 | 49.32 | 1 | 1 | 30 | 3.33 | 1 | 39 | 49 | 79.59 | 2 | 28 | 67 | 41.79
Metabolic | Hypokalemia | 1 | 1 | 43 | 2.33 | | | | | 1 | 2 | 49 | 4.08 | 1 | 2 | 50 | 4.00
Metabolic | Vitamin deficiency | | | | | | | | | | | | | 1 | 1 | 109 | 0.92
Renal | Kidney stone | 1 | 1 | 43 | 2.33 | | | | | 1 | 0 | 49 | 0.00 | 1 | 0 | 50 | 0.00
Renal | Renal insufficiency | 1 | 0 | 43 | 0.00 | | | | | 1 | 0 | 49 | 0.00 | 1 | 1 | 50 | 2.00
SURGICAL
Band Related | Band erosion | | | | | 1 | 1 | 66 | 1.52
Band Related | Band removal | | | | | 1 | 7 | 210 | 3.33
Band Related | Port or tubing complication | | | | | 5 | 9 | 462 | 1.95
Band Related | Band slippage | | | | | 6 | 13 | 571 | 2.28
Band Related | Pouch dilation | | | | | 2 | 13 | 240 | 5.42
Bleeding/Hematoma | Anastomotic hemorrhage | | | | | | | | | | | | | 1 | 1 | 22 | 4.55
Bleeding/Hematoma | Intraabdominal hemorrhage | | | | | | | | | | | | | 1 | 1 | 109 | 0.92 | 1 | 1 | 30 | 3.33
Bleeding/Hematoma | Transfusion NOS | | | | | | | | | 1 | 1 | 49 | 2.04 | 1 | 1 | 50 | 2.00
Minor Surgical | Incisional hernia | | | | | | | | | 1 | 0 | 49 | 0.00 | 2 | 3 | 67 | 4.48
Minor Surgical | Wound infection/seroma | 1 | 0 | 43 | 0.00 | 1 | 1 | 30 | 3.33 | 1 | 0 | 49 | 0.00 | 3 | 8 | 186 | 4.30
Minor Surgical | Not specified | | | | | | | | | 1 | 3 | 30 | 10.00 | 1 | 3 | 30 | 10.00
Pouch/Anastomosis | Leak | | | | | | | | | 1 | 1 | 49 | 2.04 | 3 | 1 | 239 | 0.42
Pouch/Anastomosis | Fistula | | | | | | | | | | | | | 1 | 1 | 147 | 0.68
Pouch/Anastomosis | Stricture | | | | | | | | | | | | | 4 | 18 | 363 | 4.96
Pouch/Anastomosis | Ulcer | | | | | | | | | 1 | 0 | 49 | 0.00 | 2 | 6 | 67 | 8.96
Reoperation | Not specified | | | | | | | | | 2 | 2 | 98 | 2.04 | 3 | 6 | 180 | 3.33 | 1 | 1 | 10 | 10.00
Revision | Revision secondary to diarrhea | | | | | | | | | | | | | | | | | 1 | 1 | 30 | 3.33
Other | Morbidity major - unspecified | | | | | | | | | | | | | 1 | 2 | 44 | 4.55
Other | Other adverse event - unspecified | | | | | | | | | | | | | 1 | 1 | 109 | 0.92
Other | Readmission | | | | | | | | | 1 | 1 | 30 | 3.33 | 1 | 1 | 30 | 3.33
Other | Internal hernia | | | | | | | | | | | | | 1 | 1 | 109 | 0.92
Other | Surgical NOS | | | | | 1 | 5 | 40 | 12.50 | 1 | 0 | 30 | 0.00 | 3 | 0 | 72 | 0.00 | 1 | 0 | 30 | 0.00

BPD = biliopancreatic diversion with duodenal switch; gastric sleeve = sleeve gastrectomy; LAGB = laparoscopic adjustable gastric banding; N = number; NOS = not otherwise specified; RYGB = Roux-en-Y gastric bypass; TIA = transient ischemia attack

* Studies may have reported on >1 adverse event category and the majority reported on >1 surgical weight loss treatment. Some patients had >1 adverse event. The total number of adverse events was counted for each category.

** % = number of patients with adverse event/total number of patients.

† Schauer et al. 2012^37^ hypoglycemia was self-reported.

Studies were included in our mortality analyses only if they reported/mentioned either the number of deaths or lack of any deaths. Thus, 14 studies were included, which accounted for five LAGB arms, one gastric sleeve arm, nine RYGB arms, and one BPD arm. Only one death was reported—an LAGB patient with complications of a gastric perforation. Thus, the reported rate of mortality was 0.48 percent for LAGB and 0.0 percent for gastric sleeve, RYGB and BPD.

Medical complications (cardiovascular, respiratory, gastrointestinal) were reported in several studies. Four studies reported cardiovascular or respiratory complications. A BPD study reported that one of ten patients had a pulmonary embolism, while an RYGB study reported one case of arrthyhmia and three cases of pneumonia. (It is not clear whether these cases were mutually exclusive or in separate patients.) Another study reported two cases of pneumonia in RYGB patients, one case in a gastric sleeve patient and none in the nonsurgical arm. This same study noted two patients with arrhythmias in the nonsurgical arm, one case in a gastric sleeve patient, and none in the RYGB arm. One study of LAGB versus nonsurgical treatment reported one transient ischemia attack (TIA) among 30 patients in the nonsurgical arm.

Metabolic issues were also reported. Self-reported hypoglycemia was common in one RCT of diabetes patients who were receiving aggressive medical treatment in both surgical and nonsurgical: 28 of 50 (56.0 percent) RYGB patients, 39 of 49 (79.6 percent) SG patients, and 35 of 43 (81.4 percent) nonsurgical patients. The same study reported ketoacidosis in one of the RYGB patients and none of the SG or nonsurgical patients. In another study, hypoglycemia was reported by one of 30 LABG patients and did not occur in the non-surgery arm. Vitamin deficiency was reported in one of 109 patients in an RYGB study, and one study each of RYGB and LAGB mentioned that no patients suffered from malnutrition. Anemia was reported in an RCT by 12.0 percent of RYBG, 12.2 percent of SG, and almost 7 percent of nonsurgical patients.

Gastrointestinal (GI) complications were reported at a relatively low rate. Feeding difficulties were reported by 3.6 percent of LAGB patients, 0.9 percent of RYGB patients, and 4.3 percent of nonsurgical patients. There were no reports of feeding difficulties among BPD or gastric sleeve patients. Similarly, hiatal hernia or reflux was reported in four of 146 LAGB patients (2.7 percent), but in no studies of the other procedures. In one RCT, dehydration was reported in 22.0 percent of RYGB patients, 9.3 percent of SG patients, and 8.16 percent of nonsurgical patients. Gastroplegia was reported in one study of 30 BPD patients; the rate was 13.33 percent.

Wound infections were reported in three RYGB studies; the rate was 4.3 percent. A study of 30 LAGB patients also reported one wound infection. Incisional hernias were reported in two RYGB studies; rate was 4.5 percent.

Anastomotic and pouch complications were reported in gastric sleeve and RYGB patients. Five percent of RYGB patients experienced stricture. One RYGB patient and one sleeve patient experienced an anastomotic leak. Ulcer was reported in nine percent of RYGB patients. One RYBG study reported an anastomotic hemorrhage in one of 22 patients. Likewise, one RYGB study reported an intra-abdominal hemorrhage in one of 109 patients.

Several complications specific to LAGB were reported. Band slippage was reported in 2.3 percent of patients, port or tube problems in about two percent, and 3.3 percent of LAGB patients had the band removed. Five of 40 patients in one study had unspecified surgical complications. 5.42 percent of LAGB patients had pouch dilation post-surgery.

Two gastric sleeve patients, six RYGB patients, and another BPD patient required re-operation for unspecified reasons. In addition, one BPD patient required a revision due to chronic diarrhea.

### Summary

In the two RCTs comparing SG with RYGB complications were minor and rates were similar between groups. The surgical complications reported for RYGB and LAGB in observational studies were fairly consistent; they differ due to the nature of the procedures. Complications related to LABG include band slippage, tube problems, and band erosion, while those related to RYGB include stricture, ulcer, and on rare occasions, hemorrhage. We rate the strength of evidence for overall short term harms as low for all four procedure types.

The low strength of evidence reflects several limitations in the data. The majority of the adverse events data were submitted by surgeons, and thus subject to possible publication bias. There were only 20 instances where 100 or more patients contributed data to a particular adverse event category; thus, the rate estimate for most adverse events is imprecise. Additionally, in 76 percent of instances, only a single study contributed data to a particular adverse event rate calculation, meaning the generalizability of the estimate is questionable. Few studies were clear exactly when adverse events took place, and patients who were lost followup had no adverse events data. In addition, definitions of complications varied from study to study.

## KQ4 Does the evidence show racial and demographic disparities with regard to potential benefits and harms associated with bariatric surgery for treating adult patients with BMI of 30 to 34.9 and metabolic conditions? What other patient factors (social support, counseling, pre-operative weight loss, compliance) are related to successful outcomes?

There were insufficient data in the included surgery studies to assess whether racial and demographic disparities exist in terms of weight loss and metabolic outcomes. However, previous research shows that some patient-level factors are associated with successful weight loss after bariatric surgery. Regardless of procedure type, patients who lose more weight tend to be younger, have a lower preoperative BMI, and be non-diabetic.69-71

One recent systematic literature review identified a number of psychosocial patient factors that may be associated with weight loss after bariatric surgery.72,73 This review was based on observational studies that included all bariatric patients, including those with baseline BMI> 35 kg/m^2^ and those without diabetes. Data specific to patients with a BMI less than 35 kg/m^2^ and diabetes are not available. Preoperative factors include baseline BMI, with heavier patients losing less weight than their lighter counterparts in 37 out of 62 studies. Meta-analysis revealed a decrease of 10.1 percent more EWL (excess weight loss) for super obese versus non-super obese patients (95% CI 3.7 percent – 16.5 percent). Some programs request that bariatric candidates lose a modest degree of weight (generally 10-20 pounds) in the weeks immediately prior to surgery. This mandatory preoperative weight loss was associated with successful outcomes after bariatric surgery in many studies. In a meta-analysis on the association between preoperative weight loss versus no weight loss and postoperative weight loss, the preoperative weight loss group lost a mean of 5.0 percent greater EWL (95% CI 2.7 to 7.3 percent).74

Social support is believed to be an important component of successful weight loss, and support group attendance in particularly is associated with improved weight loss outcomes after surgery. For example, one study of RYGB patients found that when controlling for time elapsed since surgery, the number of support group meetings attended explained some variance in weight loss (R2 = .09, P<0.05).75 Another study of patients who underwent LAGB reported that patients who attended support groups had greater weight loss starting at 6 months after surgery, and continuing at 12 months (9.7 vs. 8.1 BMI points decrease at 12 months, P<0.05).76,77

Support groups can help to provide continuing postoperative education regarding behavior modification, as well as identify any problems early on. Increased postoperative physical activity was also associated with greater postoperative weight loss in the majority of studies (11 out of 13 studies). A meta-analysis assessing the association of exercise versus no exercise and postoperative weight loss at 12 months showed that the exercise group lost a mean of 4.2 percent greater total BMI (95% CI 0.3 to 8.1 percent).72 Other factors that may be predictive of postoperative weight loss include specific eating habits or disorders, such as hunger and emotional eating. The emotional and physical stresses of such dramatic weight loss can trigger maladaptive responses in patients with preexisting eating disorders. The impact of other eating disorders and psychiatric disorders such as depression is not clear. This is in part due to variability in how eating and psychiatric disorders are defined from study to study, which survey instruments are used, and the followup time.

### Summary

There was insufficient evidence in the studies of patients with diabetes or IGT and BMI 30 to 34.9 kg/m^2^ on demographic disparities regarding benefits and harms of bariatric surgery. The same is true for patient factors related to successful outcomes. A recent systematic review on patients with higher BMI found that mandatory pre-operative weight loss, social support, and increased physical activity were associated with better outcomes.

## KQ5 What does the evidence show regarding long-term benefits and harms of bariatric surgery for treating adult patients with BMI of 30 to 34.9 and who have metabolic conditions? How do they compare to short-term outcomes (within 1 year from surgery)?

Few long-term data exist on patients with diabetes or IGT in this weight class who have undergone bariatric surgery. Fifteen surgical studies reported outcomes at 13 to 24 months; however, only a handful included followup of more than two years. This section focuses on those studies.

A case series of 210 LAGB patients in Italy with baseline BMI of 30 to 34.9 kg/m^2^ included only four patients with diabetes. The authors reported that diabetes had resolved in all four at one year, but resolution was not defined and metabolic evidence was not presented. Authors attempted to followup on the entire group at two, three, four, and five years. Five-year data were reported for only 29 of the 210 initial patients, for a followup rate of only 13.8 percent.39 No other diabetes related outcomes were reported. Another study of 93 LAGB patients of one surgeon in Australia41 reported on followup at one, two, and three years. Response rate was good, ranging from 79 to 89 percent per year. Only eight patients had diabetes at baseline; none needed diabetes medications at three years. Again, no other metabolic evidence was presented. For the entire group, mean BMI decreased from 32.7 kg/m^2^ at baseline to 27.0 kg/m^2^ at one year, and this BMI was maintained at two and three years. Finally, one author followed seven BPD patients with diabetes and BMI < 35 kg/m^2^ for over five years in Italy.47 Serum glucose was normalized at one, two, and three years in all patients. At five years, serum glucose had increased to above 125 mg/dL in five patients. Diabetes had “resolved” in the other two patients. At each follow-up, all patients had normal cholesterol and triglyceride levels. None of these studies reported long-term (over two years) adverse events, although the Italian LAGB study reported a death at 20 months post-surgery from sepsis due to perforation of a dilated gastric pouch.

For comparison, one RCT of surgery versus nonsurgical treatment in our target population40 reported BMI at six, 12, 18 and 24 months. Both LAGB and medical management groups lost 13.8 percent of excess weight at six months. However, the medical management group gained weight at each subsequent followup while the LAGB group continued to lose weight. Mean BMI decreased from 33.7 kg/m^2^ at baseline to 28.9 kg/m^2^ at six months, 27.0 kg/m^2^ at 12 months, 26.7 kg/m^2^ at 18 months, and 26.4 kg/m^2^ at two years. (Detailed results for LAGB versus usual care in this study are discussed in the section on KQs 1 and 2.) Metabolic outcomes were not reported at these intervals.

Though not within the parameters of this systematic review, we note the results of a recent European study on long-term outcomes of laparoscopic adjustable gastric band78 because it reports the longest followup we identified in the bariatric literature published to date. Of 151 consecutive patients from a single institution operated on from 1994-1997, the mean preoperative BMI was 41.57 kg/m^2^ (range, 35-57). Of these patients, 82 (54.3 percent) were available for long-term followup at 13 years. The number of patients varied somewhat for each outcome depending on preoperative data availability. For example, complete weight loss data were available for 70 of 151 patients. Overall, 43 percent maintained a loss of excess weight, nearly 60 percent required reoperation, and obesity-related comorbidities such diabetes, hypertension, and sleep apnea persisted. Of 78 patients, 20 (25.6 percent) were treated for hypertension before band insertion and 23 (29.5 percent) were treated for hypertension 12 years after their laparoscopic adjustable gastric band (p=.72). Of 78 patients, 5 (6.4 percent) had type 2 diabetes before band insertion and 11 had diabetes 12 years after surgery. Of the 78 patients, two (2.6 percent) needed continuous positive pressure for sleep apnea before surgery and 6 (7.7 percent) after surgery. Nearly one-third of patients experienced band erosion, while 17 percent were converted to a RYGB. Intent to treat excess weight loss was 33.92 percent (range 24 percent – 143 percent). 36 patients (51.4 percent) still had the band in place and their mean excess weight loss was 48 percent (range 38 percent – 58 percent).

This study on long-term outcomes included patients with preoperative weight higher than that of our target population. It is not clear how these results translate to a lower weight group. Additionally, the study was limited in its ability to draw conclusions as almost 50 percent of patients were not available for followup, which may contribute to significant bias. Still, the study described above draws attention to the importance of having long-term outcomes following bariatric surgery as some obesity-related comorbidities were not resolved at 12 years and there was a high rate of significant band-related complications.

### Summary

Due to the dearth of data available, the strength of evidence that bariatric surgery is an effective way to treat diabetes or IGT in patients with BMI of at least 30 kg/m^2^ but less than 35 kg/m^2^ in the long term is insufficient. There are very few long-term (over two years) studies, each includes only a handful of patients in our target population, and none includes a comparison group. We identified no long-term reports of surgery-related adverse events in our target population; thus strength of evidence for harms is also insufficient.