# References

1 Nguyen NT, Nguyen XM, Lane J, et al. Relationship between obesity and diabetes in a US adult population: findings from the National Health and Nutrition Examination Survey, 1999-2006. Obes Surg. Mar. 2011;21(3):351-5. [pmid: 21128002].
2 Sjostrom CD, Lissner L, Wedel H, et al. Reduction in incidence of diabetes, hypertension and lipid disturbances after intentional weight loss induced by bariatric surgery: the SOS Intervention Study. Obes Res. Sep. 1999;7(5):477-84. [pmid: 10509605].
3 Mingrone G, Panunzi S, De Gaetano A, et al. Bariatric surgery versus conventional medical therapy for type 2 diabetes. N Engl J Med. Mar. 26. 2012;366(17):1577-85. [pmid: 22449317].
4 Okay DM, Jackson PV, Marcinkiewicz M, et al. Exercise and obesity. Prim Care. Jun. 2009;36(2):379-93. [pmid: 19501249].
5 James WP, Caterson ID, Coutinho W, et al. Effect of sibutramine on cardiovascular outcomes in overweight and obese subjects. N Engl J Med. Sep. 2. 2010;363(10):905-17. [pmid: 20818901].
6 Li Z, Maglione M, Tu W, et al. Meta-analysis: pharmacologic treatment of obesity. Ann Intern Med. Apr. 5. 2005;142(7):532-46. [pmid: 15809465].
7 Gardner CD, Kiazand A, Alhassan S, et al. Comparison of the Atkins, Zone, Ornish, and LEARN diets for change in weight and related risk factors among overweight premenopausal women: the A TO Z Weight Loss Study: a randomized trial. JAMA. Mar. 7. 2007;297(9):969-77. [pmid: 17341711].
8 Kelley DE, Bray GA, Pi-Sunyer FX, et al. Clinical efficacy of orlistat therapy in overweight and obese patients with insulin-treated type 2 diabetes: a 1-year randomized controlled trial. Diabetes Care. Jun. 2002;25(6):1033-41. [pmid: 12032111].
9 Pi-Sunyer FX. The effects of pharmacologic agents for type 2 diabetes mellitus on body weight. Postgrad Med. Jul. 2008;120(2):5-17. [pmid: 18654064].
10 Bode B. An overview of the pharmacokinetics, efficacy and safety of liraglutide. Diabetes Res Clin Pract. Jan. 14. 2012;97(1):27-42. [pmid: 22245694].
11 Vilsboll T, Christensen M, Junker AE, et al. Effects of glucagon-like peptide-1 receptor agonists on weight loss: systematic review and meta-analyses of randomised controlled trials. BMJ. 2012;344:d7771. [pmid: 22236411].
12 Executive summary of the clinical guidelines on the identification, evaluation, and treatment of overweight and obesity in adults. Arch Intern Med. Sep. 28. 1998;158(17):1855-67. [pmid: 9759681].
13 Medicare National Coverage Determinations Manual Chapter 1, Part 2 (Sections 90-160.26). Centers for Medicare & Medicaid Services. editor. 2006.
14 Buchwald H, Estok R, Fahrbach K, et al. Weight and type 2 diabetes after bariatric surgery: systematic review and meta-analysis. Am J Med. Mar. 2009;122(3):248-56 e5. [pmid: 19272486].
15 Phurrough S, Salive ME, Brechner R, et al. Decision Memo for Surgery for Diabetes (CAG-00397N). The Centers for Medicare & Medicaid Services, DHHS. December. 2. 2010.
16 International Diabetes Federation Taskforce on Epidemiology and Prevention. Bariatric surgical and procedural interventions in the treatment of obese patients with type 2 diabetes. March. 28. 2011. www.idf.org/webdata/docs/IDF-Position-Statement-Bariatric-Surgery.pdf. January 31 2012.
17 FDA expands use of banding system for weight loss. U.S. Food and Drug Administration. 2011. www.fda.gov/NewsEvents/Newsroom/PressAnnouncements/ucm245617.htm.
18 Shekelle PG, Morton SC, Maglione M, et al. Pharmacological and surgical treatment of obesity. Agency for Healthcare Research and Quality. 1530-440X (Print) 1530-440X (Linking). Rockville, MD. July. 2004. wwwncbi.nlm.nih.gov/entrez/query.fcgi?cmd=Retrieve&db=PubMed&dopt=Citation&list_uids=15526396.
19 Jadad AR, Moore RA, Carroll D, et al. Assessing the quality of reports of randomized clinical trials: is blinding necessary?. Control Clin Trials. Feb. 1996;17(1):1-12. [pmid: 8721797].
20 Moher D, Pham B, Jones A, et al. Does quality of reports of randomised trials affect estimates of intervention efficacy reported in meta-analyses?. Lancet. Aug. 22. 1998;352(9128):609-13. [pmid: 9746022].
21 Shea BJ, Grimshaw JM, Wells GA, et al. Development of AMSTAR: a measurement tool to assess the methodological quality of systematic reviews. BMC Med Res Methodol. 2007;7:10. [pmid: 17302989].
22 Shea BJ, Hamel C, Wells GA, et al. AMSTAR is a reliable and valid measurement tool to assess the methodological quality of systematic reviews. J Clin Epidemiol. 2009;62(10):1013-20. [pmid: 19230606].
23 Methods Reference Guide for Effectiveness and Comparative Effectiveness Reviews. Rockville, MD. Draft Posted. October. 2007. www.effectivehealthcare.ahrq.gov/repFiles/2007_10DraftMethodsGuide.pdf.
24 Owens DK, Lohr KN, Atkins D, et al. AHRQ series paper 5: grading the strength of a body of evidence when comparing medical interventions--agency for healthcare research and quality and the effective health-care program. J Clin Epidemiol. May. 2010;63(5):513-23. [pmid: 19595577].
25 Atkins D, Best D, Briss PA, et al. Grading quality of evidence and strength of recommendations. BMJ. Jun. 19. 2004;328(7454):1490. [pmid: 15205295].
26 Cohen R, Pinheiro JS, Correa JL, et al. Laparoscopic Roux-en-Y gastric bypass for BMI < 35 kg/m(2): a tailored approach. Surg Obes Relat Dis. May-Jun. 2006;2(3):401-4. discussion 4. [pmid: 16925363].
27 Lee WJ, Wang W, Lee Y, et al. Effect of laparoscopic mini-gastric bypass for type 2 diabetes mellitus: comparison of BMI>35 and <35 kg/m2. J Gastrointest Surg. May. 2008;12(5):945-52. [pmid: 17940829].
28 Demaria EJ, Wineger DA, Pate VW, et al. Early postoperative outcomes of metabolic surgery to treat diabetes from sites participating in the ASMBS bariatric surgery center of excellence program as reported in the Bariatric Outcomes Longitudinal Database. Ann Surg. Sep. 2010;252(3):559-66. discussion 66-7. [pmid: 20739857].
29 Shah SS, Todkar JS, Shah PS, et al. Diabetes remission and reduced cardiovascular risk after gastric bypass in Asian Indians with body mass index <35 kg/m(2). Surg Obes Relat Dis. Jul-Aug. 2010;6(4):332-8. [pmid: 19846351].
30 Boza C, Gamboa C, Viscido G, et al. Laparoscopic Roux-en-Y gastric bypass for the treatment of type 2 diabetes in patients with BMI below 35. Obesity Surgery. 2010;20(8):1011.
31 de Sa VC, Ferraz AA, Campos JM, et al. Gastric bypass in the treatment of type 2 diabetes in patients with a BMI of 30 to 35 kg/m2. Obes Surg. Mar. 2011;21(3):283-7. [pmid: 21153449].
32 Frenken M, Cho EY. Metabolic intestinal bypass surgery for type 2 diabetes in patients with a BMI < 35 kg/m2: comparative analysis of 16 patients undergoing either BPD, BPD-DS, or RYGB. Obesity Facts. 2011;4(SUPPL. 1):13-7. [pmid: 22027284].
33 Huang CK, Shabbir A, Lo CH, et al. Laparoscopic Roux-en-Y gastric bypass for the treatment of type II diabetes mellitus in Chinese patients with body mass index of 25-35. Obes Surg. Apr. 9. 2011;21(9):1344-9. [pmid: 21479764].
34 Lee WJ, Chong K, Ser KH, et al. Gastric bypass vs sleeve gastrectomy for type 2 diabetes mellitus: a randomized controlled trial. Arch Surg. Feb. 2011;146(2):143-8. [pmid: 21339423].
35 Lee WJ, Chong K, Chen CY, et al. Diabetes remission and insulin secretion after gastric bypass in patients with body mass index <35 kg/m2. Obesity Surgery. 2011;21(7):889-95. [pmid: 21499957].
36 Ramos A, Neto MPG, Galvao M, et al. Metabolic bypass. Initial experience with Roux-and-Y gastric bypass on type 2 diabetes treatments for non-morbid obese patients. Obesity Surgery. 2010;20(8):1011-2.
37 Schauer PR, Kashyap SR, Wolski K, et al. Bariatric surgery versus intensive medical therapy in obese patients with diabetes. N Engl J Med. Mar. 26. 2012;366(17):1567-76. [pmid: 22449319].
38 Serrot FJ, Dorman RB, Miller CJ, et al. Comparative effectiveness of bariatric surgery and nonsurgical therapy in adults with type 2 diabetes mellitus and body mass index <35 kg/m(2). Surgery. Oct. 2011;150(4):684-91. [pmid: 22000180].
39 Angrisani LF, Furbetta F, Iuppa F, et al. Italian Group for Lap-Band System®: Results of multicenter study on patients with BMI ≤35 kg/m2. Obes Surg. 2004;14(3):415-8. [pmid: 15072665].
40 O'Brien PE, Dixon JB, Laurie C, et al. Treatment of mild to moderate obesity with laparoscopic adjustable gastric banding or an intensive medical program: a randomized trial. Ann Intern Med. May. 2. 2006;144(9):625-33. [pmid: 16670131].
41 Parikh M, Duncombe J, Fielding GA. Laparoscopic adjustable gastric banding for patients with body mass index of <or=35 kg/m2. Surg Obes Relat Dis. Sep-Oct. 2006;2(5):518-22. [pmid: 17015204].
42 Dixon JB, O'Brien PE, Playfair J, et al. Adjustable gastric banding and conventional therapy for type 2 diabetes: a randomized controlled trial. JAMA. Jan. 23. 2008;299(3):316-23. [pmid: 18212316].
43 Sultan S, Parikh M, Youn H, et al. Early U.S. outcomes after laparoscopic adjustable gastric banding in patients with a body mass index less than 35 kg/m2. Surg Endosc. Jul. 2009;23(7):1569-73. [pmid: 19263156].
44 Choi J, Digiorgi M, Milone L, et al. Outcomes of laparoscopic adjustable gastric banding in patients with low body mass index. Surg Obes Relat Dis. Jul-Aug. 2010;6(4):367-71. [pmid: 20185374].
45 Lembach H, Lanzarini E, Csendes A, et al. Metabolic outcomes of sleeve gastrectomy in patients with impaired glucose metabolism. Obes Surg. 2010;20(8):988.
46 Noya G, Cossu ML, Coppola M, et al. Biliopancreatic diversion preserving the stomach and pylorus in the treatment of hypercholesterolemia and diabetes type II: results in the first 10 cases. Obes Surg. Feb. 1998;8(1):67-72. [pmid: 9562490].
47 Scopinaro N, Papadia F, Marinari G, et al. Long-term control of type 2 diabetes mellitus and the other major components of the metabolic syndrome after biliopancreatic diversion in patients with BMI < 35 kg/m2. Obes Surg. Feb. 2007;17(2):185-92. [pmid: 17476869].
48 Chiellini C, Rubino F, Castagneto M, et al. The effect of bilio-pancreatic diversion on type 2 diabetes in patients with BMI <35 kg/m2. Diabetologia. Jun. 2009;52(6):1027-30. [pmid: 19308351].
49 Scopinaro N, Adami GF, Papadia FS, et al. The effects of biliopancreatic diversion on type 2 diabetes mellitus in patients with mild obesity (BMI 30-35 kg/m(2)) and simple overweight (BMI 25-30 kg/m (2)): a prospective controlled study. Obes Surg. Jul. 2011;21(7):880-8. [pmid: 21541815].
50 Geloneze B, Geloneze SR, Fiori C, et al. Surgery for nonobese type 2 diabetic patients: an interventional study with duodenal-jejunal exclusion. Obes Surg. Aug. 2009;19(8):1077-83. [pmid: 19475464].
51 Whitlock EP, Lin JS, Chou R, et al. Using existing systematic reviews in complex systematic reviews. Ann Intern Med. May. 20. 2008;148(10):776-82. [pmid: 18490690].
52 Norris SL, Zhang X, Avenell A, et al. Long-term effectiveness of lifestyle and behavioral weight loss interventions in adults with type 2 diabetes: a meta-analysis. Am J Med. Nov. 15. 2004;117(10):762-74. [pmid: 15541326].
53 Kirk JK, Graves DE, Craven TE, et al. Restricted-carbohydrate diets in patients with type 2 diabetes: a meta-analysis. J Am Diet Assoc. Jan. 2008;108(1):91-100. [pmid: 18155993].
54 Dyson PA. A review of low and reduced carbohydrate diets and weight loss in type 2 diabetes. J Hum Nutr Diet. Dec. 2008;21(6):530-8. [pmid: 18759958].
55 Kodama S, Saito K, Tanaka S, et al. Influence of fat and carbohydrate proportions on the metabolic profile in patients with type 2 diabetes: a meta-analysis. Diabetes Care. May. 2009;32(5):959-65. [pmid: 19407076].
56 Norris SL, Zangh X, Avenell A, et al. Long-term effectiveness of weight-loss interventions in adults with pre-diabetes: a review. Am J Prev Med. Jan. 2005;28(1):126-39. [pmid: 15626569].
57 Gillies CL, Abrams KR, Lambert PC, et al. Pharmacological and lifestyle interventions to prevent or delay type 2 diabetes in people with impaired glucose tolerance: systematic review and meta-analysis. BMJ. February. 10. 2007. 2007;334(7588):299. [pmid: 17237299].
58 Fakhoury WK, Lereun C, Wright D. A meta-analysis of placebo-controlled clinical trials assessing the efficacy and safety of incretin-based medications in patients with type 2 diabetes. Pharmacology. 2010;86(1):44-57. [pmid: 20616619].
59 Bolen S, Feldman L, Vassy J, et al. Systematic review: comparative effectiveness and safety of oral medications for type 2 diabetes mellitus. Ann Intern Med. Sep. 18. 2007;147(6):386-99. [pmid: 17638715].
60 Waugh N, Cummins E, Royle P, et al. Newer agents for blood glucose control in type 2 diabetes: systematic review and economic evaluation. Health Technol Assess. Jul. 2010;14(36):1-248. [pmid: 20646668].
61 Li G, Zhang P, Wang J, et al. The long-term effect of lifestyle interventions to prevent diabetes in the China Da Qing Diabetes Prevention Study: a 20-year follow-up study. The Lancet. 2008;371(9626):1783-9. [pmid: 18502303].
62 Ilanne-Parikka P, Eriksson JG, Lindstrom J, et al. Effect of lifestyle intervention on the occurrence of metabolic syndrome and its components in the Finnish Diabetes Prevention Study. Diabetes Care. Apr. 2008;31(4):805-7. [pmid: 18184907].
63 Knowler WC, Fowler SE, Hamman RF, et al. 10-year follow-up of diabetes incidence and weight loss in the Diabetes Prevention Program Outcomes Study. Lancet. Nov. 14. 2009;374(9702):1677-86. [pmid: 19878986].
64 Holman RR, Paul SK, Bethel MA, et al. 10-year follow-up of intensive glucose control in type 2 diabetes. N Engl J Med. Oct. 9. 2008;359(15):1577-89. [pmid: 18784090].
65 Ramachandran A, Snehalatha C, Mary S, et al., Indian Diabetes Prevention, Programme. The Indian Diabetes Prevention Programme shows that lifestyle modification and metformin prevent type 2 diabetes in Asian Indian subjects with impaired glucose tolerance (IDPP-1). Diabetologia. 2006;49(2):289-97. [pmid: 16391903].
66 Salas-Salvado J, Fernandez-Ballart J, Ros E, et al. Effect of a Mediterranean diet supplemented with nuts on metabolic syndrome status: one-year results of the PREDIMED randomized trial. Arch Intern Med. Dec. 8. 2008;168(22):2449-58. [pmid: 19064829].
67 Davies MJ, Heller S, Skinner TC, et al. Effectiveness of the diabetes education and self management for ongoing and newly diagnosed (DESMOND) programme for people with newly diagnosed type 2 diabetes: cluster randomised controlled trial. BMJ. Mar. 1. 2008;336(7642):491-5. [pmid: 18276664].
68 DePaula AL, Stival A, Halpern A, et al. Thirty-day morbidity and mortality of the laparoscopic ileal interposition associated with sleeve gastrectomy for the treatment of type 2 diabetic patients with BMI <35: an analysis of 454 consecutive patients. World J Surg. Jan. 2011;35(1):102-8. [pmid: 21052999].
69 Snyder B, Nguyen A, Scarbourough T, et al. Comparison of those who succeed in losing significant excessive weight after bariatric surgery and those who fail. Surg Endosc. Oct. 2009;23(10):2302-6. [pmid: 19184204].
70 Chevallier JM, Paita M, Rodde-Dunet MH, et al. Predictive factors of outcome after gastric banding: a nationwide survey on the role of center activity and patients' behavior. Ann Surg. Dec. 2007;246(6):1034-9. [pmid: 18043107].
71 Dixon JB, Dixon ME, O'Brien PE. Pre-operative predictors of weight loss at 1-year after Lap-Band surgery. Obes Surg. Apr. 2001;11(2):200-7. [pmid: 11355027].
72 Livhits M, Mercado C, Yermilov I, et al. Exercise following bariatric surgery: systematic review. Obes Surg. May. 2010;20(5):657-65. [pmid: 20180039].
73 Livhits M, Mercado C, Yermilov I, et al. Is social support associated with greater weight loss after bariatric surgery?: a systematic review. Obes Rev. Feb. 2011;12(2):142-8. [pmid: 20158617].
74 Livhits M, Mercado C, Yermilov I, et al. Does weight loss immediately before bariatric surgery improve outcomes: a systematic review. Surg Obes Relat Dis. Nov-Dec. 2009;5(6):713-21. [pmid: 19879814].
75 Hildebrandt SE. Effects of participation in bariatric support group after Roux-en-Y gastric bypass. Obes Surg. Oct. 1998;8(5):535-42. [pmid: 9819086].
76 Elakkary E, Gazayerli MM. Laparoscopic adjustable gastric band: do support groups add to the weight loss?. Obes Surg. Sep. 2004;14(8):1139-40. [pmid: 15479609].
77 Elakkary E, Elhorr A, Aziz F, et al. Do support groups play a role in weight loss after laparoscopic adjustable gastric banding?. Obes Surg. Mar. 2006;16(3):331-4. [pmid: 16545165].
78 Himpens J, Cadiere GB, Bazi M, et al. Long-term outcomes of laparoscopic adjustable gastric banding. Arch Surg. July. 2011;146(7):802-7. [pmid: 21422330].