# Methods

## Original Proposed Key Questions (KQs)

KQ1. What does the evidence show regarding the comparative effectiveness of bariatric surgery for treating adult patients with a BMI of 30.0 to 34.9 kg/m^2^ and metabolic conditions, including diabetes? Are certain surgical procedures more effective than others (LAGB, RYGB, or SG)?

KQ2. What does the evidence show regarding the comparative effectiveness of bariatric surgery versus conventional nonsurgical therapies for treating adult patients with a BMI of 30.0 to 34.9 kg/m^2^ and metabolic conditions?

KQ3. What are the potential short-term adverse effects and/or complications associated with bariatric surgery for treating adult patients with a BMI of 30.0 to 34.9 kg/m^2^ who have metabolic conditions?

KQ4. Does the evidence show racial and demographic disparities with regard to potential benefits and harms associated with bariatric surgery for treating adult patients with a BMI of 30.0 to 34.9 kg/m^2^ and metabolic conditions? What other patient factors (social support, counseling, preoperative weight loss, compliance with recommended treatment) are related to successful outcomes?

KQ5. What does the evidence show regarding long-term benefits and harms of bariatric surgery for treating adult patients with a BMI of 30.0 to 34.9 kg/m^2^ and who have metabolic conditions? How do the long-term benefits and harms of bariatric surgery compare to short-term outcomes (within 1 year after surgery)?

## Technical Expert Panel

For each Agency for Healthcare Research and Quality (AHRQ) evidence report, a Technical Expert Panel (TEP) is assembled to provide clinical expertise and context. We invited a distinguished group of scientists and clinicians, including individuals with expertise in obesity, surgery, and metabolic conditions such as diabetes, to participate in the TEP for this report. A list of members is included in the front matter of this report. A TEP conference call was held on October 4, 2010. On the call, staff presented the KQs as well as the preliminary literature search results and asked experts to help define the scope of the review (e.g. types of metabolic conditions and bariatric procedures to include). Panel members reviewed a draft version of this report and provided feedback.

## Analytic Framework

Figure 1 presents the analytic framework for this comparative effectiveness review (CER). Using data from controlled trials, cohort studies, and case series, we documented evidence of the benefits and harms of different types of bariatric surgeries and conventional nonsurgical therapies in treating targeted patients (those with diabetes or impaired glucose tolerance [IGT] and a body mass index [BMI] of 30 to 34.9 kg/m^2^). The evidence for both short- and long-term outcomes was assessed. Comparisons included: (1) among different surgical procedures such as Roux-en-Y gastric bypass (RYGB), laparoscopic adjustable gastric banding (LAGB), sleeve gastrectomy (SG), and biliopancreatic diversion with duodenal switch (BPD) to answer KQ1, and (2) of surgical procedures to conventional nonsurgical therapies (e.g., diet, exercise, and pharmaceuticals) to answer KQ2. Documented short- and long-term benefits and harms of surgical procedures were compared to answer KQ3 and KQ5.

Figure 1 Analytic framework for evaluationg the effectiveness and safety of alternative approaches to treatment of metabolic conditions in the patient population with BMI ≥ 30 < 35

KQ = Key Question; LAGB = laparoscopic adjustable gastric banding LAGB; RYGB = Roux-en-Y gastric bypass

Figure 1 displays the analytic framework for our systematic review. We only include studies of bariatric surgery if most patients have type 2 diabetes or impaired glucose tolerance. The majority of patients must have BMI of at least 30 kg/m2 but less than 35 kg/m2. Short term efficacy outcomes analyzed include changes in glucose measurements (fasting glucose, HbA1c), weight, blood pressure, and cholesterol. Long term outcomes include those same measures in addition to cessation of anti-diabetic medications and quality of life. Harms analyzed include mortality, bleeding / hematoma, leak, fistula, infection, and band slippage.

Benefits and harms for specific subpopulations (by gender, age, and race/ethnicity) and other patient factors (social support, counseling, preoperative weight loss, compliance with recommended treatment) were examined, where available, to answer KQ4.

A protocol for this review was available for public comment on the AHRQ Effective Healthcare Web site http://effectivehealthcare.ahrq.gov/index.cfm/search-for-guides-reviews-and-reports/?productid=595&pageaction=displayproduct.

## Literature Search

Our search for studies began in April 2009, with an electronic search of PubMed^®^ and Embase^®^ for reports on bariatric surgery and patients with diabetes or IGT. We also searched the CINAHL (Cumulative Index to Nursing and Allied Health Literature), Cochrane library of systematic reviews, Cochrane Central Register of Controlled Trials (CENTRAL) and the Cochrane Database of Abstracts of Reviews of Effects (DARE). (The Cochrane Collaboration is an international organization that helps people make well-informed decisions about health care by preparing, maintaining, and promoting the accessibility of systematic reviews on the effects of heath care interventions.) Other sources included Clinicaltrials.gov, references of included studies, and relevant reviews, and personal files from projects with related topics. Reviewers performed additional reference mining by scanning titles listed in the reference section of each selected study to identify additional potential articles. The literature search was updated in March 2010, and October 2010 after the TEP call, and search updates were conducted monthly through March 2012. Appendix A shows our specific search terms. We also searched for studies of nonsurgical treatments (diet, exercise, education, medications, and other interventions). The following bariatric procedures: laparoscopic adjustable gastric banding (LAGB), sleeve gastrectomy (SG), Roux-en-Y gastric bypass (RYGB), and biliopancreatic diversion (BPD) were included in our searches. Jejunoileal bypass, one of the earliest procedures performed for weight loss, was not included, as this procedure was abandoned about 25 years ago due to a high rate of complications. We used various search terms for each type of procedure. For example, for Roux-en-Y gastric bypass, we also used gastric bypass, RYGB, laparoscopic gastric bypass, and open gastric bypass. We ordered all articles on metabolic conditions and weight loss interventions, regardless of language or publication date.

The strongest evidence to assess the relative benefits and harms of bariatric surgery with nonsurgical therapy would come from randomized controlled trials comparing the treatment options, including only patients in the BMI range of our KQs (30 kg/m^2^ – 34.9 kg/m^2^) and measuring relevant outcomes such as glucose control and use of diabetic medications, but also the outcomes that treating diabetes is meant to prevent: microvascular and macrovascular complications. Because a priori we expected there to be very few RCTs comparing surgical with nonsurgical therapy, we expected – as in our prior Evidence Report on surgical and nonsurgical weight loss therapies in more obese patients18 – that we would need to make indirect comparisons between the best available data on the effects of surgery and the best available data on the effects of nonsurgical therapy. For the former, we expected to use case series data. For the latter, there is a voluminous literature on the management of diabetes, and we expected to use existing systematic reviews supplemented with any recent trials published after the search dates of these reviews.

## Article Review

### Study Inclusion

We searched the literature for systematic reviews, case series, cohort, case control and controlled trials. Editorials, historical pieces, and descriptive articles without data were excluded. The studies included in this report are of one of the following types.

Review articles identified by the search were classified as either systematic (including meta-analyses) or nonsystematic. Systematic reviews were identified by reading the methods section of the article to determine whether an acceptable method was employed to identify evidence (such as a description of the name of the computerized database searched and the full set of search terms used, as well as details about the method for accepting and rejecting identified articles).

Randomized controlled trials (RCTs) are studies where the participants are definitely assigned prospectively to one of two (or more) alternative forms of intervention, using a process of random allocation (e.g., random number generation, coin flips).

Controlled clinical trials (CCTs) are studies where participants (or other units) are either

a. definitely assigned prospectively to one of two (or more) alternative forms of health care using a quasi-random allocation method (e.g., alternation, date of birth, patient identifier)
  OR
b. possibly assigned prospectively to one of two (or more) alternative forms of health care using a process of random or quasi-random allocation.

Observational studies (such as cohort and cases series) are those where the investigators do not control who gets the interventions.

To be included, studies had to report on one of the surgical procedures or conservative nonsurgical treatments described in the introduction, and had to include patients with BMI 30.0 to 34.9 kg/m^2^ with diabetes or IGT. Systematic reviews of interventions both surgical and nonsurgical were the exception to this rule, since they often synthesized data over a number of studies with varying BMI patient population. The following studies were excluded: (1) studies that did not report any outcomes of efficacy, effectiveness, or safety/adverse events; (2) nonsurgical studies with less than one year followup; (3) nonsurgical studies already included in previous systematic reviews; (4) background articles; and (5) studies with less than three subjects. We note here that we are dealing with two concepts, weight and disorders of glucose metabolism, that are a continuum physiology, but in the KQs are treated as dichotomous. In other words, we expect the risk of weight to be similar for a person with a BMI of 29.5 kg/m^2^ and a person with a BMI of 31.5 kg/m^2^, yet our key questions deal with the latter and not the former. Indeed, the published literature does not always conform to the same threshold specified in the KQs. We judged that studies that included substantial number of patients within the threshold of our KQs, but perhaps also some outside the range, were still informative, and were included. Thus, if a study included patients with a BMI of 29 kg/m^2^–37 kg/m^2^ we judged that it would be more informative to the KQs to include rather than exclude it. Similar decisions were made about the presence of impaired glucose tolerance and the clinical diagnosis of diabetes.

## Screening

Using a single-page “screening form” (included in Appendix B), we reviewed the studies retrieved from the various sources against our exclusion criteria. Items included specific surgical procedure or nonsurgical treatment, study design, sample size, and type of outcomes reported (i.e. metabolic conditions, mortality, adverse events). Two reviewers, each trained in the critical analysis of scientific literature, independently reviewed each study and resolved disagreements by consensus. The lead investigator resolved any disagreements that remained after discussions between the reviewers.

## Data Abstraction and Synthesis of Results

Results from controlled trials, case-control studies, cohort studies, and cases series were abstracted by researchers using Distiller software. Because of study heterogeneity, meta-analysis was not possible; thus, we summarize the data both quantitatively and qualitatively. Data abstracted included metabolic outcomes (glucose, blood pressure, lipids) and weight loss, mortality, and other adverse events. Other details included trial name (if applicable), setting, population characteristics (including sex, age, ethnicity, and diagnosis), eligibility and exclusion criteria, any co-interventions, other allowed medication, comparisons, and results for each outcome. Intent-to-treat results were recorded if available. For each study that provided sufficient information, we calculated the mean change from baseline to followup, where a negative mean change indicates decrease in outcome measure (e.g. BMI). We used the estimates to calculate a weighted mean change within surgery type and outcome.

## Assessment of Methodological Quality

To arrive at a quantitative measure for controlled trials, the Jadad scale was used, which was originally developed for drug trials.19 This method measures quality on a scale that ranges from 0–5, assigning points for randomization and blinding and accounting for withdrawals and dropouts. (Across a broad array of meta-analyses, an evaluation of the scale found that trials scoring from 0–2 report exaggerated results when compared with trials scoring from 3–5.^20^ The latter scores indicate studies of “good” quality and the former indicate those of “poor” quality.) For any disagreement that arose during the quality assessment, issues were discussed in the project meeting, and group decisions were made by the research team.

To assess the quality of included systematic reviews and meta-analyses, we used AMSTAR—a measurement tool for the assessment of multiple systematic reviews.21 This tool contains eleven yes/ no items, such as whether the literature search was comprehensive, if dual abstraction was used, and if individual study characteristics are displayed. The tool has strong face and content validity, inter-rater reliability, and construct validity.22 A copy is included in Appendix B.

## Grading the Evidence for Each KQ

The overall strength of evidence for intervention effectiveness was assessed by using guidance suggested by AHRQ for its Effective Health Care Program.23,24 This method is based loosely on one developed by the GRADE working group,25 and classifies the grade of evidence according to the following criteria:

- High = High confidence that the evidence reflects the true effect. Further research is very unlikely to change our confidence on the estimate of effect.
- Moderate = Moderate confidence that the evidence reflects the true effect. Further research may change our confidence in the estimate of effect and may change the estimate.
- Low = Low confidence that the evidence reflects the true effect. Further research is likely to change our confidence in the estimate of effect and is likely to change the estimate.
- Insufficient = Evidence either is unavailable or does not permit a conclusion.

The evidence grade is based on four primary (required) domains and four optional domains. The required domains are risk of bias, consistency, directness, and precision; the additional domains are dose-response, plausible confounders that would decrease the observed effect, strength of association, and publication bias. Information on the required domains is presented in Table 1 below.

Table 1 Grading the strength of a body of evidence: required domains and their definitions

Domain | Definition and Elements | Score and Application
Risk of Bias | Risk of bias is the degree to which the included studies for a given outcome or comparison have a high likelihood of adequate protection against bias (i.e., good internal validity), assessed through two main elements:; - Study design (e.g., RCTs or observational studies); - Aggregate quality of the studies under consideration.; Information for this determination comes from the rating of quality (good/fair/poor) done for individual studies. | Use one of three levels of aggregate risk of bias:; - Low risk of bias; - Medium risk of bias; - High risk of bias
Consistency | The principal definition of consistency is the degree to which reported effect sizes from included studies appear to have the same direction of effect. This can be assessed through two main elements:; - Effect sizes have the same sign (that is, are on the same side of “no effect”); - The range of effect sizes is narrow. | Use one of three levels of consistency:; - Consistent (i.e., no inconsistency); - Inconsistent; - Unknown or not applicable (e.g., single study); As noted in the text, single-study evidence bases (even megatrials) cannot be judged with respect to consistency. In that instance, use “Consistency unknown (single study).”
Directness | The rating of directness relates to whether the evidence links the interventions directly to health outcomes. For a comparison of two treatments, directness implies that head-to-head trials measure the most important health or ultimate outcomes. Two types of directness, which can coexist , may be of concern: Evidence is indirect if:; - It uses intermediate or surrogate outcomes instead of health outcomes. In this case, one body of evidence links the intervention to intermediate outcomes and another body of evidence links the intermediate to most important (health or ultimate) outcomes.; - It uses two or more bodies of evidence to compare interventions A and B – that is, studies of A versus placebo and B versus placebo, or studies of A versus C and B versus C but not A versus B.; Indirectness always implies that more than one body of evidence is required to link interventions to the most important health outcomes. Directness may be contingent on the outcomes of interest. EPC authors are expected to make clear the outcomes involved when assessing this domain. | Score dichotomously as one of two levels directness; - Direct; - Indirect; If indirect, specify which of the two types of indirectness account for the rating (or both, if that is the case)—namely, use of intermediate/surrogate outcomes rather than health outcomes, and use of indirect comparisons. Comment on the potential weaknesses caused by, or inherent in, the indirect analysis. The EPC should note if both direct and indirect evidence was available, particularly when indirect evidence supports a small body of direct evidence.
Precision | Precision is the degree of certainty surrounding an effect estimate with respect to a given outcome (i.e., for each outcome separately). If a meta-analysis was performed, this will be the confidence interval around the summary effect size. | Score dichotomously as one of two levels of precision:; - Precise; - Imprecise; A precise estimate is an estimate that would allow a clinically useful conclusion. An imprecise estimate is one for which the confidence interval is wide enough to include clinically distinct conclusions. For example, results may be statistically compatible with both clinically important superiority and inferiority (i.e., the direction of effect is unknown), a circumstance that will preclude a valid conclusion.

EPC = Evidence-based Practice Center; RCT = randomized controlled trial

For this systematic review, we focused on the inherent risk of bias in study design (e.g., in general, randomized controlled trials have less bias than observational studies) and within study design, certain aspects of execution and reporting (e.g. proportion lost to followup, baseline differences between the comparison groups). Regarding consistency, we judged the evidence as consistent if, all other factors being equal, a super majority of the studies reported results in the same direction. For directness, we judged the evidence to be direct if, all other factors being equal, studies reported relevant health outcomes such as weight loss, micro or macrovascular complications of diabetes, stroke myocardial infarction, etc. rather than indirect outcomes such as fasting blood sugar or HbA1c. We consider weight loss per se to be a health outcome since it is something patients can feel, although it is also an intermediate towards improvement in comorbid conditions. For precision, we defined the evidence as precise if, all other factors being equal, the data were sufficiently within its 95% confidence interval to support a decision, i.e. if the evidence is on one side of a decision threshold. The most important additional domain was publication bias, because surgeons submitting case series for publication may be unrepresentative of the community as a whole.

## Peer Review and Public Commentary

A draft of this report was prepared in September 2011. The AHRQ Effective Healthcare Program Scientific Resource Center located at Oregon Health Sciences University coordinated peer review by experts and stakeholders. The report was also posted on AHRQ's Web site for a month for public comment. Resulting comments were considered by the EPC in preparation of the final report. Synthesis of the scientific literature presented here does not necessarily represent the views of individual reviewers, and service as a peer reviewer or member of the TEP cannot be construed as endorsement of the report's findings.