# Introduction

In 2010, diabetes affected 25.8 million people in the United States, or 8.3 percent of the population. About 1.9 million people aged 20 years or older were newly diagnosed with diabetes in 2010. In 2005-2008, based on fasting glucose or hemoglobin A1c levels, 35 percent of U.S. adults (79 million people) aged 20 years or older had prediabetes (50 percent of adults aged 65 years or older).1 Among adults with diabetes, the prevalence of individuals considered as overweight or higher (body mass index [BMI] ≥ 25 kg/m^2^) was 80.3 percent; and the prevalence of obesity or higher (BMI >= 30 kg/m^2^) was 49.1 percent.1

Diabetes is considered a chronic, progressive disease. Traditional medical therapy focuses on glycemic control and control of long-term complications such as retinopathy, renal failure, and cardiovascular disease. Management may involve injecting insulin daily or using oral medications for a life time.

Studies show that bariatric surgeries such as laparoscopic adjustable gastric banding (LAGB), Roux-en-Y gastric bypass (RYGB), and biliopancreatic diversion with duodenal switch (BPD) in morbidly obese patients have been found to be far more effective than conventional nonsurgical therapy at improving diabetes in the short term.2 A recent randomized controlled study (RCT) studying a population with BMI >35 kg/m^2^ found that no patients in the medical treatment alone group had resolution of diabetes (defined as HgA1c<6.5 percent and fasting blood glucose<100 mg/dL) compared with 75 percent resolution in RYGB and 95 percent in BPD.3

Improvement in diabetes has been demonstrated to start rapidly after bariatric surgery, especially for patients undergoing RYGB, before significant weight loss has occurred. Additionally, the degree of weight loss achieved may not predict the improvement in hyperglycemia.3 The mechanism of postoperative metabolic improvements has not been fully elucidated and may in part be independent from weight loss, suggesting that bariatric surgery may improve metabolic comorbidities even for patients who are not morbidly obese.

Bariatric surgery is an accepted practice for patients with a BMI of 40 kg/m^2^ or greater, and for patients with a BMI of between 35-40kg/m^2^ who have significant obesity-related comorbidities such as diabetes, hypertension, cardiovascular diseases, dyslipidemia, obstructive sleep apnea, and degenerative arthritis.

In the past few years bariatric surgery has been suggested as an option for lower BMI (at least 30 kg/m^2^ but less than 35 kg/m^2^) patients as a way to treat diabetes and other metabolic conditions. Given a lack of consensus regarding the minimum BMI requirement and uncertainties regarding the comparative effectiveness of different bariatric procedures, especially in the long term, a review of the relative risks and benefits of the various surgical and conservative approaches to treatment of diabetes or impaired glucose tolerance (IGT) in patients whose BMI is at least 30 kg/m^2^ and less than 35 kg/m^2^ was suggested by a constituent group; the topic was refined by the Southern California Evidence-based Practice Center in conjunction with Key Informants, including bariatric surgeons, researchers, consumers, and payers.

## Conventional Therapy for Obesity and Diabetes

Conventional nonsurgical therapy for overweight patients with diabetes or IGT includes diet, exercise, and medications (summarized below). Most interventions combine multiple modalities such as diet and exercise and must be sustained long-term to prevent weight regain.

### Diet

A variety of diets have been proposed to assist obese patients in losing weight. Low calorie diets are typically high in carbohydrates (55 percent – 60 percent of total daily energy intake), low in fat (< 30 percent of energy intake), and produce a negative energy balance. Other strategies focus on decreasing the proportion of carbohydrates or fats. Low carbohydrate, high fat/protein diets (e.g. Atkins) induce weight loss primarily through decreased calorie intake but can have mixed effects on lipid profiles. Very-low-calorie diets (VLCDs) – typically 800 kcal per day – can be effective to induce rapid weight loss, especially when used as a short-term adjunct prior to bariatric surgery. More recently, the Mediterranean diet, which emphasizes eating fruit, vegetables, and whole grains has become popular. Finally, the low glycemic index diet, originally designed for diabetes patients, ranks carbohydrate foods from 1 to 100 according to glucose level, with 100 as the reference for pure glucose.

### Exercise

Aerobic exercise can induce weight loss as well as decrease blood sugar levels for those with impaired glucose tolerance, though it is often difficult for morbidly obese patients due to comorbidities such as osteoarthritis. There is some debate regarding the optimal level of physical activity necessary to induce weight loss. The National Heart, Lung and Blood Institute (NHLBI) Obesity Education Initiative Expert and the United States (U.S.) Preventive Services Task Force guidelines suggest that at least 30 minutes of aerobic activity daily (amounting to an energy expenditure of 2,500 to 3,500 kcal per week) is necessary to promote weight loss and reduce comorbidities.4

### Behavior Modification

These interventions include individual counseling and community-based programs to provide detailed strategies to assist with weight loss. Recommendations may include those regarding diet and exercise, as well as counseling regarding the deleterious effects of obesity and associated comorbidities. Cognitive behavioral therapy, targets specific psychological processes that may interfere with weight loss or maintenance, can be included in a behavior modification program.

### Medications

Anti-obesity medications rely on increasing metabolism, decreasing appetite or altering food absorption. Commonly used drugs have included orlistat, which inhibits pancreatic lipases and prevents fat absorption, and sibutramine, a serotonin-norepinephrine reuptake inhibitor that decreases appetite. The latter was recently withdrawn from the United States and other markets due to increased risks of myocardial infarction and stroke.5 Phentermine, approved for short-term weight loss, is another popular appetite suppressant. Conventional pharmaceutical therapy for weight loss has not been very effective at producing significant and sustained weight loss in obese patients.6,7 The combination of diet and weight loss medications like orlistat results in a mean weight loss of only 3-4 kg at one year.6 Such medications can improve glycemic control and dyslipidemia in obese patients with type 2 diabetes, but this improvement is modest.8

Conventional therapy for diabetes also includes specific medications meant to lower plasma glucose levels. Pharmacotherapy for obese patients with diabetes includes insulin or oral hypoglycemic agents, which work through a variety of mechanisms (e.g. sulfonylureas, which increase insulin secretion; biguanides, which reduce hepatic glucose production; and thiazolidinediones or glitazones, which reduce insulin resistance mainly in the periphery). Medications used for obese patients with diabetes, such as insulin or sulfonylureas (e.g. glyburide), do not produce significant weight loss and can even cause weight gain, exacerbating insulin resistance and glucose intolerance.9 Recently developed GLP-1 receptor agonists such a liraglutide and exenatide treat diabetes by reducing meal-related hyperglycemia by increasing insulin secretion and delaying gastric emptying. These drugs have been shown to cause weight loss in clinical trials.10,11 Cardiovascular risk reduction medications (statins, aspirin, angiotensin converting enzyme inhibitors, etc.) are also mainstays of diabetes management.

## Bariatric Surgery

Bariatric surgery was first introduced in the 1950s and has evolved significantly since that time, leading to some procedures that were initially performed being abandoned due to unacceptably complication rates secondary to malabsorption that led to reduced nutrient intake (e.g. jejunoileal bypass) or poor long-term benefit (i.e., vertical banded gastroplasty). The most common procedures currently performed are RYGB, laparoscopic adjustable gastric banding, and gastric sleeve. These procedures result in weight loss via different mechanisms and most likely involve a combination. Pre-surgery assessments of weight history, food preferences, psychological issues and medical history impact decisions regarding which surgery is most appropriate.

Researchers are still learning about all the specifics of how weight loss is achieved. Two general components employed, alone or in combination, include (1) restricting the size of the stomach to limits the quantity of food a patient can consume at a single meal, and (2) inducing malabsorption which decreases the proportion of nutrients that are absorbed from a meal. These procedures can also produce behavior changes, such as aversions to high carbohydrate foods. As the gastrointestinal tract communicates with the central nervous system, these procedures also appear to lead to hunger control and satiety, the details of which are still being studied. Descriptions of selected bariatric procedures (those performed currently) are provided below.

### Gastric Bypass (RYGB)

The most common bariatric procedure, Roux-en-Y gastric bypass, often referred to as “gastric bypass,” achieves weight loss through complex mechanisms. The surgery involves creating a small gastric pouch (and outlet) along with a proximal intestinal bypass. This small pouch (30 cc) is connected to a segment of the jejunum (which is downstream), thus bypassing the duodenum and very proximal small intestine. Although the procedure generates minimal malabsorption, significant changes in hormones and neural signals to the gastrointestinal tract lead to hunger control and satiety. In addition, following ingestion of high-density carbohydrates, some patients may experience the resultant “dumping” syndrome, whose unpleasant symptoms include flushing, palpitations, abdominal pain, cramping, and diarrhea. As a result, these patients develop an aversion to high-carbohydrate foods that leads to behavior changes in diet and eating habits. RYGB for weight loss has been performed regularly since the early 1980s. It was first performed laparoscopically in the early 1990s and is now one of the most common types of weight loss procedures.

### Laparoscopic Adjustable Gastric Band (LAGB)

Gastric banding achieves weight loss predominately by gastric restriction. The uppermost portion of the stomach is encircled by a band to create a gastric pouch with a capacity of approximately 15 to 30 cubic centimeters (cc). The band consists of an inflatable doughnut-shaped balloon whose diameter can be adjusted in the clinic by adding or removing saline via a reservoir port positioned beneath the skin. The bands are adjustable to allow the size of the gastric outlet to be modified as needed, depending on clinical symptoms and eating behaviors. A full understanding of how weight loss is achieved is still being investigated, but likely includes components of behavioral diet and eating changes as well as inducing satiety through neuropeptide changes. Currently, banding procedures are performed laparoscopically (laparoscopic adjustable gastric banding). While this procedure is technically reversible (e.g., removal of the band for failed weight loss), doing so exposes the patient to potential risks associated with a second operation and, of course, will necessitate identifying an alternative method for weight loss.

### Sleeve Gastrectomy

Also known as gastric sleeve, vertical sleeve gastrectomy, is a relatively new restrictive type of procedure. Approximately 60 to 80 percent of the stomach is removed laparoscopically, leaving a small tube (or “sleeve”) which remains connected to the original stomach outlet. The cutaway part of the stomach is removed, making this procedure irreversible, and no foreign objects are implanted in the body.

The mechanism by which gastric sleeve induces weight loss is not clear. At least one study has demonstrated increased or rapid gastric emptying following gastric sleeve resection, leading to a possible mechanism of neural-hormonal phenomena similar to RYGB. This procedure may also lower plasma ghrelin, a natural hormone, which produces hunger. Originally gastric sleeve surgery was the first stage of two-stage procedure, biliopancreatic diversion with duodenal switch in high risk patients. (discussed below). However, many patients lost sufficient weight after the gastric sleeve such that the second stage surgery was not needed, and it has been gaining popularity as a stand-alone procedure since the early 2000s. In South America, the procedure has been paired with ileal interposition, with very good results reported. However, as that process is considered experimental and rarely performed in the United States, it is beyond the scope of this report.

### Biliopancreatic Diversion/Duodenal Switch (BPD)

BPD involves removing 70 percent of the stomach along with bypassing a significant proportion of small intestine. By reducing the size of the stomach, less acid is produced, but the remaining capacity is generous compared with that achieved with RYGB. As such, patients eat relatively normal-sized meals and do not need to restrict intake severely. Malabsorption is a component of how weight loss is generated, but it has not been clearly established as the main cause. Malabsorption is generated by (1) the diversion of food downstream, decreasing the opportunity for nutrient absorption and (2) reduction in the quantities of enzymes and bile in the bypassed segment, which decreases absorption. Patients develop steatorrhea from the decrease in fat absorption.

Although this procedure is not as commonly performed as either banding procedures or RYGB, the approach is favored by some bariatric surgery specialists. The partial biliopancreatic diversion with duodenal switch is a variant of the BPD procedure that, until recently, was performed mostly in Italy and only rarely performed in the United States. Recently, a number of centers in the United States and Canada have begun to perform this procedure, which involves resection of the greater curvature of the stomach, preservation of the pyloric sphincter, and transection of the duodenum above the ampulla of Vater with a duodeno-ileal anastomosis and a lower ileo-ileal anastomosis.

Newer procedures, gastric sleeve with ileal interposition, duodenal-jejunal bypass, and duodenal-jejunal exclusion, are being studied outside in the United States (one study in the United States in 2008 was conducted but the results were not published). The mechanism of weight loss and metabolic impact are under investigation and they are not standardly performed in the United States currently. Thus, they are beyond the scope of this report.

## Bariatric Surgery in Lower Weight Patients

Currently the standard criteria for bariatric surgery candidates include having a BMI ≥ 40 kg/m^2^ or ≥ 35 kg/m^2^ with significant obesity-related comorbidities. This is based on National Institutes of Health (NIH) guidelines12 and has been endorsed by the Center for Medicare & Medicaid Services (CMS), which covers a variety of bariatric procedures for patients with BMI ≥ 35 kg/m^2^ and comorbidities.13 Bariatric surgery has been shown to improve or resolve metabolic conditions such as diabetes in the short term, at least in part due to the associated weight loss.14 However, there may be other mechanisms involved (particularly for RYGB) as metabolic improvements are often seen rapidly after surgery, before significant weight loss has occurred. Bariatric surgery has therefore been advocated as a treatment for metabolic conditions even for the non-morbidly obese patients. Though experts have suggested that the minimum BMI requirement for bariatric candidates with type 2 diabetes be lowered below 35 kg/m^2^, CMS in 2006 denied coverage for lower BMI patients with diabetes, specifically for open and laparoscopic RYGB, LAGB, and open and laparoscopic BPD/DS.15 In 2011, the International Diabetes Federation recommended that diabetic patients with BMI of at least 30 kg/m^2^ to 35 kg/m^2^ be eligible for bariatric surgery if they have a HbA1c level of > 7.5%.16 More recently, the Food and Drug Administration (FDA) expanded the indications for a specific brand of laparoscopic adjustable gastric banding to include patients with a BMI between 30 kg/m^2^ and 34.9 kg/m^2^ and at least one obesity-related comorbidity.17