# Future Research

Future research should focus on long-term outcomes of bariatric surgery in U.S. patients with diabetes or impaired glucose tolerance and a body mass index of 30 kg/m^2^ to 34.9 kg/m^2^. For this population there is no evidence that bariatric surgery is effective in preventing the clinical consequences of diabetes – microvascular and macrovascular endpoints such as diabetic retinopathy, kidney failure, and myocardial infarction. Studies with followup of five to ten years are needed. Studies in other populations have led to concern about potential for long-term nutritional complications in bariatric surgery patients, so nutritional endpoints should also be measured.

We found only one U.S. cohort study comparing procedures; this study used the BOLD (Bariatric Outcomes Longitudinal Database), a resource created by the Surgical Review Corporation to monitor outcomes from the Bariatric Surgery Center of Excellence (BSCOE) program. As of June 2009, there were 235 patients with diabetes within our BMI range in the BOLD database. The study we identified reported outcomes at 6 to 12 months. Outcomes at 12 to 24 months were reported for only a small number of patients (6.8 percent) presumably because that followup time had not expired for most of the patients. Continued followup of these patients and publication of findings is needed to assess the degree to which bariatric surgery mitigates long-term sequelae of diabetes.

In addition, according to the U.S. clinical trials database, there are several bariatric surgery trials currently being conducted in the target population. In addition to monitoring weight loss, these studies will frequently collect important metabolic data including measures of blood sugar, cholesterol, triglycerides, and blood pressure. Long-term followup of the research subjects, if funded, could add to our knowledge base on the effects of bariatric surgery and cardiovascular morbidity and mortality. Collection and reporting of psychological and quality of life outcomes will also help inform prospective patients and providers.