# Addendum

As part of the preparation of a paper to appear in the Journal of the American Medical Association (JAMA), we added to our analysis two additional elements:

1. We updated our literature search through September 2012. This resulted in including eight additional surgical observational studies (1-8 below).
2. We attempted to compare the weight loss and glucose control outcomes of bariatric surgery with nonsurgical therapy in the two RCTs that directly compared these in patients with diabetes for only those patients with a body mass index (BMI) of 30.0 to 34.9 kg/m^2^. The mean baseline BMI was 37.0 kg/m^2^ in both RCTs. For the trial reported by Schauer and colleagues, we used the results of an analysis presented as supplemental material with their original publication. This analysis found no statistically significant evidence that the study outcomes differed in patients above and below the mean BMI of 37 kg/m^2^. For the trial reported by Dixon and colleagues, we obtained patient-level data from the authors, and compared weight loss and glucose outcomes in the 13 patients included in that trial that had a BMI of less than 35 kg/m^2^. There were statistically significantly better weight loss and glucose control outcomes in the patients treated with bariatric surgery compared to those treated nonsurgically.

These additions did not change our conclusions regarding the effectiveness and safety bariatric surgery in this population.

For further information, see:

Maggard-Gibbons M Maglione M Livhits M Bariatric surgery for weight loss and glycemic control in nonmorbidly obese adults with diabetes: a systematic review. JAMA 2013June 5309 21 2250 2261DOI10.1001/jama.2013.4851 23736734

## References

1 Abbatini F, Capoccia D, Casella G, Coccia F, Leonetti F, Basso N. Type 2 diabetes in obese patients with body mass index of 30-35 kg/m^2^: sleeve gastrectomy versus medical treatment. Surg Obes Relat Dis. Jan-Feb. 2012;8(1):20-4. [pmid: 21924686].
2 Boza C, Munoz R, Salinas J, et al. Safety and efficacy of Roux-en-Y gastric bypass to treat type 2 diabetes mellitus in non-severely obese patients. Obes Surg. Sep. 2011;21(9):1330-6. [pmid: 21744283].
3 Cohen RV, Pinheiro JC, Schiavon CA, Salles JE, Wajchenberg BL, Cummings DE. Effects of gastric bypass surgery in patients with type 2 diabetes and only mild obesity. Diabetes Care. Jul. 2012;35(7):1420-8. [pmid: 22723580].
4 Gianos M, Abdemur A, Fendrich I, Gari V, Szomstein S, Rosenthal RJ. Outcomes of bariatric surgery in patients with body mass index <35 kg/m^2^. Surg Obes Relat Dis. Jan-Feb. 2012;8(1):25-30. [pmid: 22019140].
5 Kim MK, Lee HC, Lee SH, et al. The difference of glucostatic parameters according to the remission of diabetes after Roux-en-Y gastric bypass. Diabetes Metab Res Rev. Jul. 2012;28(5):439-46. [pmid: 22407971].
6 Lee WJ, Hur KY, Lakadawala M, Kasama K, Wong SK, Lee YC. Gastrointestinal metabolic surgery for the treatment of diabetic patients: a multi-institutional international study. J Gastrointest Surg. Jan. 2012;16(1):45-51. discussion -2. [pmid: 22042564].
7 Sun ZC, Yu WS, Na Y, et al. Modified Roux-en-Y gastric bypass for type 2 diabetes mellitus in China. Hepatogastroenterology. Jul. 25. 2012;60(121). [pmid: 22829557].
8 Zhu L, Mo Z, Yang X, et al. Effect of laparoscopic Roux-en-Y gastroenterostomy with BMI < 35 kg/m^2^ in type 2 diabetes mellitus. Obes Surg. Oct. 2012;22(10):1562-7. [pmid: 22692669].