# Acknowledgments

The authors gratefully acknowledge Roberta Shanman, M.L.S., who was instrumental in supporting the EPC team's effort to find and obtain relevant literature. The authors also gratefully acknowledge the following individuals for their contributions to this project:

## Key Informants

- Caroline M. Apovian, M.D., FACP, FACN
  Boston University School of Medicine
  Boston, MA
- Pam Davis, R.N., CBN, CCM
  Centennial Center for the Treatment of Obesity
  Nashville, TN
- Jim Fivecoat, M.B.A.
  Member, Obesity Action Coalition
  Taylors, SC
- Jeff Haaga
  Member, Obesity Action Coalition
  West Jordan, UT
- Monali Misra, M.D., FRCSC, FACS
  Dr. Feiz and Associates
  Beverly Hills, CA
- John Morton, M.D., M.P.H., FACS
  Stanford School of Medicine
  Stanford, CA
- Joe Nadglowski
  President and CEO
  Obesity Action Coalition
  Tampa, FL
- Jamshid Nazarian, M.D., FACS
  Beverly Hills, CA
- Chuck Stemple, M.D.
  Humana
  Cincinnati, OH

## Technical Expert Panel

- Caroline M. Apovian, M.D., FACP, FACN
  Boston University School of Medicine
  Boston, MA
- George Bray, M.D.
  Pennington Biomedical Research Foundation
  Baton Rouge, LA
- John B Dixon, M.B.B.S., Ph.D., FRACGP
  Monash University, Baker IDI Heart and Diabetes Institute
  Melbourne, Australia
- David Heber, M.D.
  Ronald Reagan UCLA Medical Center
  Los Angeles, CA
- Edward Harry Livingston, M.D., FACS, UT
  Southwestern Medical Center
  Dallas, TX
- John Morton, M.D., M.P.H., FACS
  Stanford School of Medicine
  Stanford, CA
- Christine J. Ren-Fielding, M.D.
  NYU Langone Medical Center
  New York, NY
- Bruce Wolfe, M.D.
  Oregon Health & Science University
  Portland, OR

## Peer Reviewers

- David Arterburn, M.D., M.P.H.
  University of Washington
  Seattle, WA
- Alison Avenell, Ph.D.
  University of Aberdeen
  Aberdeen, Scotland, U.K.
- Scott A. Cunneen, M.D.
  Cedars-Sinai Medical Center
  Los Angeles, CA
- Ken Fujioka, M.D.
  Scripps Clinic Del Mar
  San Diego, CA
- James Hill, Ph.D.
  University of Colorado
  Denver, CO
- Joe Nadglowski
  President and CEO
  Obesity Action Coalition
  Tampa, FL