# Excluded Studies

## Reject Background

1 Blackburn GL, Wollner SB, Jones DB. Bariatric surgery as treatment for type 2 diabetes. Curr Diab Rep. Aug. 2010;10(4):261-3. [pmid: 20440583].
2 Caballero MG. Surgery of type 2 diabetes mellitus: the great discovery of bariatric surgery. Nutr Hosp. Sep-Oct. 2010;25(5):693-4. [pmid: 21336421].
3 Campos GM, Rabl C, Roll GR, et al. Better Weight Loss, Resolution of Diabetes, and Quality of Life for Laparoscopic Gastric Bypass vs Banding: Results of a 2-Cohort Pair-Matched Study. Arch Surg. Feb. 2011;146(2):149-55. [pmid: 21339424].
4 Clifton P. Diabetes: treatment of type 2 diabetes mellitus with bariatric surgery. Nat Rev Endocrinol. Apr. 2010;6(4):191-3. [pmid: 20336164].
5 Cummings DE, F DR. Gastrointestinal surgery as a treatment for diabetes. JAMA. Jan. 23. 2008;299(3):341-3. [pmid: 18212321].
6 Deitel M. Surgery for diabetes at lower BMI: some caution. Obes Surg. Oct. 2008;18(10):1211-4. [pmid: 18758867].
7 Ferrannini E, M G. Impact of different bariatric surgical procedures on insulin action and beta-cell function in type 2 diabetes. Diabetes Care. Mar. 2009;32(3):514-20. [pmid: 19246589].
8 Gagner M. Laparoscopic sleeve gastrectomy with ileal interposition (SGIT): a modified duodenal switch for resolution of type 2 diabetes mellitus in lesser obese patients (BMI < 35). World J Surg. Jan. 2011;35(1):109-10. [pmid: 21052995].
9 Gagner M. Surgical treatment of nonseverely obese patients with type 2 diabetes mellitus: sleeve gastrectomy with ileal transposition (SGIT) is the same as the neuroendocrine brake (NEB) procedure or ileal interposition associated with sleeve gastrectomy (II-SG), but ileal interposition with diverted sleeve gastrectomy (II-DSG) is the same as duodenal switch. Surg Endosc. Feb. 2011;25(2):655-6. [pmid: 20614137].
10 Gary TL, B-T M, Bone LR, Yeh HC, Wang NY, Hill-Briggs F, Levine DM, Powe NR, Hill MN, Saudek C, McGuire M, Brancati FL. A randomized controlled trial of the effects of nurse case manager and community health worker team interventions in urban African-Americans with type 2 diabetes. Control Clin Trials. Feb. 2004;25(1):53-66. [pmid: 14980748].
11 Gill RS, Sharma AM, Al-Adra DP, et al. The impact of bariatric surgery in patients with type-2 diabetes mellitus. Curr Diabetes Rev. May. 2011;7(3):185-9. [pmid: 21488837].
12 Inabnet WB. Comment on: Prospective randomized controlled trial comparing 2 versions of laparoscopic ileal interposition associated with sleeve gastrectomy for patients with type 2 diabetes with BMI 2134 kg/m2. Surgery for Obesity and Related Diseases. 2010;6(3):304-5. [pmid: 20189466].
13 Keating CL, D JB, Moodie ML, Peeters A, Playfair J, O'Brien PE. Cost-efficacy of surgically induced weight loss for the management of type 2 diabetes: a randomized controlled trial. Diabetes Care. Apr. 2009;32(4):580-4. [pmid: 19171726].
14 Lautz D, Halperin F, Goebel-Fabbri A, et al. The great debate: Medicine or surgery: What is best for the patient with type 2 diabetes?. Diabetes Care. 2011;34(3):763-70. [pmid: 21357363].
15 Lynis Dohm G, Pories WJ. Bypass of metabolic diseases with surgery. Obesity. 2011;19(7):1323-4. [pmid: 21706037].
16 Nathan DM, B M. Trials that matter: rosiglitazone, ramipril, and the prevention of type 2 diabetes. Ann Intern Med. Mar. 20. 2007;146(6):461-3. [pmid: 17371892].
17 Pories WJ, Mehaffey JH, Staton KM. The surgical treatment of type two diabetes mellitus. Surg Clin North Am. Aug. 2011;91(4):821-36. [pmid: 21787970].
18 Shikora SA. Comment on: diabetes remission and reduced cardiovascular risk after gastric bypass in Asian Indians with body mass index <35 kg/m(2). Surg Obes Relat Dis. Jul-Aug. 2010;6(4):338-9. [pmid: 19914146].
19 Spector D, Shikora S. Neuro-modulation and bariatric surgery for type 2 diabetes mellitus. Int J Clin Pract Suppl. Feb. 2010;(166):53-8. [pmid: 20377665].

## Reject Case Report

1 Friedman MN, S AJ, Magovern GJ. The amelioration of diabetes mellitus following subtotal gastrectomy. Surg Gynecol Obstet. Feb. 1955;100(2):201-4. [pmid: 13238177].
2 Palanivelu C, Praveen Raj P, Senthilnathan P, et al. Surgery for type II diabetes mellitus: Laparoscopic ileal interposition (TYPEI). Surgical Endoscopy and Other Interventional Techniques. 2011;25:S224.
3 Velez JP, Arias RH, Olaya P. Laparoscopic sleeve gastrectomy on heart transplant recipient with body mass index of 34 kg/m(2) and metabolic syndrome. Surg Obes Relat Dis. 2010. Dec. 4. [pmid: 21212027].

## Reject No Diabetes or Impaired Glucose Tolerance

1 Al-Sarraj T, S H, Calle MC, Volek JS, Fernandez ML. Carbohydrate restriction, as a first-line dietary intervention, effectively reduces biomarkers of metabolic syndrome in Emirati adults. J Nutr. Sep. 2009;139(9):1667-76. [pmid: 19587123].
2 Andersen T, B OG, Stokholm KH, Quaade F. Randomized trial of diet and gastroplasty compared with diet alone in morbid obesity. N Engl J Med. Feb. 9. 1984;310(6):352-6. [pmid: 6690963].
3 Andersen T, S KH, Backer OG, Quaade F. Long-term (5-year) results after either horizontal gastroplasty or very-low-calorie diet for morbid obesity. Int J Obes. 1988;12(4):277-84. [pmid: 3058614].
4 Anderson AE, S RT, Scott DH. Gastric bypass for morbid obesity in children and adolescents. J Pediatr Surg. Dec. 1980;15(6):876-81. [pmid: 7463289].
5 Ashley S, B DL, Sugden G, Royston CM. Vertical banded gastroplasty for the treatment of morbid obesity. Br J Surg. Nov. 1993;80(11):1421-3. [pmid: 8252354].
6 Aude YW, A AS, Lopez-Jimenez F, Lieberman EH, Marie Almon, Hansen M, Rojas G, Lamas GA, Hennekens CH. The national cholesterol education program diet vs a diet lower in carbohydrates and higher in protein and monounsaturated fat: a randomized trial. Arch Intern Med. Oct. 25. 2004;164(19):2141-6. [pmid: 15505128].
7 Bacci V, B MS, Greco F, Lamberti R, Elmore U, Restuccia A, Perrotta N, Silecchia G, Bucci A. Modifications of metabolic and cardiovascular risk factors after weight loss induced by laparoscopic gastric banding. Obes Surg. Feb. 2002;12(1):77-82. [pmid: 11868304].
8 Benfield JR, G FL, Bray GA, Barry RE, Lechago J, Mena I, Schedewie H. Experience with jejunoileal bypass for obesity. Surg Gynecol Obstet. Sep. 1976;143(3):401-10. [pmid: 1085495].
9 Berrevoet F, P P, Cardon A, de Ryck F, Hesse UJ, de Hemptinne B. Retrospective analysis of laparoscopic gastric banding technique: short-term and mid-term follow-up. Obes Surg. Jun. 1999;9(3):272-5. [pmid: 10484315].
10 Bradley U, S Michelle, Courtney C. Hamish, McKinley Michelle C, Ennis Cieran N, McCance David R, McEneny Jane, Bell Patrick M, Young Ian S, Hunter Steven J. Low-Fat Versus Low-Carbohydrate Weight Reduction Diets. Diabetes. December. 2009. 2009;58(12):2741-8. [pmid: 19720791].
11 Bravata DM, S-S C, Sundaram V, Gienger AL, Lin N, Lewis R, Stave CD, Olkin I, Sirard JR. Using pedometers to increase physical activity and improve health: a systematic review. JAMA. Nov. 21. 2007;298(19):2296-304. [pmid: 18029834].
12 Brekke HK, J PA, Lenner RA. Long-term (1- and 2-year) effects of lifestyle intervention in type 2 diabetes relatives. Diabetes Res Clin Pract. Dec. 2005;70(3):225-34. [pmid: 15885845].
13 Brown T, A A, Edmunds LD, Moore H, Whittaker V, Avery L, Summerbell C. Systematic review of long-term lifestyle interventions to prevent weight gain and morbidity in adults. Obesity Reviews. 2009;10(6):627-38. [pmid: 19754634].
14 Buckwalter JA. A prospective comparison of the jejunoileal and gastric bypass operations for morbid obesity. World J Surg. Nov. 1977;1(6):757-68. [pmid: 607594].
15 Charles MA, E E, Grandmottet P, Isnard F, Cohen JM, Bensoussan JL, Berche H, Chapiro O, Andre P, Vague P, Juhan-Vague I, Bard JM, Safar M. Treatment with metformin of non-diabetic men with hypertension, hypertriglyceridaemia and central fat distribution: the BIGPRO 1.2 trial. Diabetes Metab Res Rev. Jan-Feb. 2000;16(1):2-7. [pmid: 10707032].
16 Charuzi I, L P, Peiser J, Peled R. Bariatric surgery in morbidly obese sleep-apnea patients: short- and long-term follow-up. Am J Clin Nutr. Feb. 1992;55(2 Suppl):594S-6S. [pmid: 1733135].
17 Chua TY, M RM. Laparoscopic Vertical Banded Gastroplasty: The Milwaukee Experience. Obes Surg. Feb. 1995;5(1):77-80. [pmid: 10733799].
18 Claessens M, vB MA, Monsheimer S, Saris WHM. The effect of a low-fat, high-protein or high-carbohydrate ad libitum diet on weight loss maintenance and metabolic risk factors. Int J Obes. 2009;33(3):296-304.
19 Colles SL, D JB, O'Brien PE. Hunger control and regular physical activity facilitate weight loss after laparoscopic adjustable gastric banding. Obes Surg. Jul. 2008;18(7):833-40. [pmid: 18408982].
20 Contreras J, Villao D, Bravo J, et al. Medium term results of laparoscopic vertical sleeve gastrectomy in 300 obese patients. Obesity Surgery. 2010;20(8):1063.
21 Dansinger ML, T A, Wong JB, Chung M, Balk EM. Meta-analysis: the effect of dietary counseling for weight loss. Ann Intern Med. Jul. 3. 2007;147(1):41-50. [pmid: 17606960].
22 Dastjerdi MS, K F, Najafian A, Mohammady M, Aminorroaya A, Amini M. An open-label pilot study of the combination therapy of metformin and fluoxetine for weight reduction. Int J Obes (Lond). Apr. 2007;31(4):713-7. [pmid: 16969361].
23 Davis JN, V EE, Alexander KE, Salguero LE, Weigensberg MJ, Crespo NC, Spruijt-Metz D, Goran MI. Feasibility of a home-based versus classroom-based nutrition intervention to reduce obesity and type 2 diabetes in Latino youth. Int J Pediatr Obes. 2007;2(1):22-30. [pmid: 17763007].
24 de Rougemont A, N S, Nazare JA, Skilton MR, Sothier M, Vinoy S, Laville M. Beneficial effects of a 5-week low-glycaemic index regimen on weight control and cardiovascular risk factors in overweight non-diabetic subjects. Br J Nutr. Dec. 2007;98(6):1288-98. [pmid: 17617942].
25 de Zwaan M, L KL, Mitchell JE, Howell LM, Monson N, Roerig JL, Crosby RD. Health-related quality of life in morbidly obese patients: effect of gastric bypass surgery. Obes Surg. Dec. 2002;12(6):773-80. [pmid: 12568181].
26 Derosa G, C AF, Murdolo G, Piccinni MN, Fogari E, Bertone G, Ciccarelli L, Fogari R. Efficacy and safety comparative evaluation of orlistat and sibutramine treatment in hypertensive obese patients. Diabetes Obes Metab. Jan. 2005;7(1):47-55. [pmid: 15642075].
27 DeWind LT, P JH. Intestinal bypass surgery for morbid obesity. Long-term results. JAMA. Nov. 15. 1976;236(20):2298-301. [pmid: 989831].
28 Dhabuwala A, C RJ, Stubbs RS. Improvement in co-morbidities following weight loss from gastric bypass surgery. Obes Surg. Oct. 2000;10(5):428-35. [pmid: 11054247].
29 Ditschuneit HH, F-M Marion, Johnson Timothy D, Adler Guido. Metabolic and weight-loss effects of a long-term dietary intervention in obese patients. Am J Clin Nutr. February. 1. 1999. 1999;69(2):198-204. [pmid: 9989680].
30 Dolan K, F G. A comparison of laparoscopic adjustable gastric banding in adolescents and adults. Surg Endosc. Jan. 2004;18(1):45-7. [pmid: 14625730].
31 Due A, L TM, Mu H, Hermansen K, Stender S, Astrup A. Comparison of 3 ad libitum diets for weight-loss maintenance, risk of cardiovascular disease, and diabetes: a 6-mo randomized, controlled trial. Am J Clin Nutr. Nov. 2008;88(5):1232-41. [pmid: 18996857].
32 Eckhout GV, W OL, Moore JT. Vertical ring gastroplasty for morbid obesity. Five year experience with 1,463 patients. Am J Surg. Dec. 1986;152(6):713-6. [pmid: 3789301].
33 Farnsworth E, L ND, Noakes M, Wittert G, Argyiou E, Clifton PM. Effect of a high-protein, energy-restricted diet on body composition, glycemic control, and lipid concentrations in overweight and obese hyperinsulinemic men and women. Am J Clin Nutr. Jul. 2003;78(1):31-9. [pmid: 12816768].
34 Flechtner-Mors M, D Herwig H, Johnson Timothy D, Suchard Mark A, Adler Guido. Metabolic and Weight Loss Effects of Long-Term Dietary Intervention in Obese Patients: Four-Year Results. Obesity. 2000;8(5):399-402.
35 Fobi M, L H, Igwe D, Felahy B, James E, Stanczyk M, Fobi N. Gastric bypass in patients with BMI < 40 but > 32 without life-threatening co-morbidities: preliminary report. Obes Surg. Feb. 2002;12(1):52-6. [pmid: 11868299].
36 Foley EF, B PN, Borlase BC, Hollingshead J, Blackburn GL. Impact of gastric restrictive surgery on hypertension in the morbidly obese. Am J Surg. Mar. 1992;163(3):294-7. [pmid: 1539761].
37 Forsell P, H G. The Swedish Adjustable Gastric Banding (SAGB) for morbid obesity: 9 year experience and a 4-year follow-up of patients operated with a new adjustable band. Obes Surg. Aug. 1997;7(4):345-51. [pmid: 9730522].
38 Frank LL, S BE, Yasui Y, Tworoger SS, Schwartz RS, Ulrich CM, Irwin ML, Rudolph RE, Rajan KB, Stanczyk F, Bowen D, Weigle DS, Potter JD, McTiernan A. Effects of exercise on metabolic risk variables in overweight postmenopausal women: a randomized clinical trial. Obes Res. Mar. 2005;13(3):615-25. [pmid: 15833948].
39 Fransis K, D F, Vanrykel JP, Aelvoet C. Experience with laparoscopic adjustable gastric banding (la-band system) up to 8 years. Acta Chir Belg. Feb. 2005;105(1):69-73. [pmid: 15790206].
40 Freeman JB, B HJ. A comparison of gastric bypass and gastroplasty for morbid obesity. Surgery. Sep. 1980;88(3):433-44. [pmid: 7414518].
41 Frey H. An investigation of the effect of biguanides on glucose tolerance and body weight in overweight individuals without diabetes mellitus. Tidsskr Nor Laegeforen. May. 30. 1972;92(15):1036-8. [pmid: 4555163].
42 Galani C, S H. Prevention and treatment of obesity with lifestyle interventions: review and meta-analysis. Int J Public Health. 2007;52(6):348-59. [pmid: 18368998].
43 Gleysteen JJ. Four-year weight loss Roux-Y gastric bypass: anastomotic reinforcement not additive. Gastroenterol Clin North Am. Sep. 1987;16(3):525-7. [pmid: 3325428].
44 Gomez CA. Gastroplasty in morbid obesity. Surg Clin North Am. Dec. 1979;59(6):1113-20. [pmid: 531744].
45 Grey N, K DM. Effect of diet composition on the hyperinsulinemia of obesity. N Engl J Med. Oct. 7. 1971;285(15):827-31. [pmid: 5570845].
46 Hafner RJ, W JM, Rogers J. Quality of life after gastric bypass for morbid obesity. Int J Obes. Aug. 1991;15(8):555-60. [pmid: 1938099].
47 Hajdukovic Z, J A, Zivotic-Vanovic M, Raden S. Influence of orlistat therapy on serum insulin level and morphological and functional parameters of peripheral arterial circulation in obese patients. Vojnosanit Pregl. Nov. 2005;62(11):803-10. [pmid: 16375203].
48 Hall WD, F Z, George VA, Lewis CE, Oberman A, Huber M, Fouad M, Cutler JA. Low-fat diet: effect on anthropometrics, blood pressure, glucose, and insulin in older women. Ethn Dis. Summer. 2003;13(3):337-43. [pmid: 12894958].
49 Harrison RA, R C, Elton PJ. Does primary care referral to an exercise programme increase physical activity one year later? A randomized controlled trial. J Public Health (Oxf). Mar. 2005;27(1):25-32. [pmid: 15564275].
50 Herbst CA Jr., Buckwalter JA. Weight loss and complications after four gastric operations for morbid obesity. South Med J. Nov. 1982;75(11):1324-8. [pmid: 7146960].
51 Kakoulidis TP, Karringer A, Gloaguen T, et al. Initial results with sleeve gastrectomy for patients with class I obesity (BMI 30-35 kg/m2). Surg Obes Relat Dis. Jul-Aug. 2009;5(4):425-8. [pmid: 18996758].
52 Kasama K, Seki Y, Shimizu H, et al. Anti diabetic effect of laparoscopic sleeve gastrectomy with duodenal jejunal bypass. Obesity Surgery. 2010;20(8):990.
53 Kellum JM, K JF, O'Dorisio TM, Rayford P, Martin D, Engle K, Wolf L, Sugerman HJ. Gastrointestinal hormone responses to meals before and after gastric bypass and vertical banded gastroplasty. Ann Surg. Jun. 1990;211(6):763-70. discussion 70-1. [pmid: 2192696].
54 Kukkonen-Harjula KT, B PT, Nenonen AM, Fogelholm MG. Effects of a weight maintenance program with or without exercise on the metabolic syndrome: a randomized trial in obese men. Prev Med. Sep-Oct. 2005;41(3-4):784-90. [pmid: 16125218].
55 Larsen JF, K JP. Laparoscopic adjustable gastric banding for the treatment of morbid obesity. Six years' experiences. Ugeskr Laeger. May. 2. 2005;167(18):1946-9. [pmid: 15929267].
56 Lee WJ, L YC, Ser KH, Chen JC, Chen SC. Improvement of insulin resistance after obesity surgery: a comparison of gastric banding and bypass procedures. Obes Surg. Sep. 2008;18(9):1119-25. [pmid: 18317853].
57 Lee WJ, W W, Yu PJ, Wei PL, Huang MT. Gastrointestinal quality of life following laparoscopic adjustable gastric banding in Asia. Obes Surg. May. 2006;16(5):586-91. [pmid: 16687026].
58 Lucas CP, B MN, Reaven GM. Effect of orlistat added to diet (30% of calories from fat) on plasma lipids, glucose, and insulin in obese patients with hypercholesterolemia. Am J Cardiol. Apr. 15. 2003;91(8):961-4. [pmid: 12686336].
59 Martinez-Gonzalez MA, dlF-A C, Nunez-Cordoba JM, Basterra-Gortari FJ, Beunza JJ, Vazquez Z, Benito S, Tortosa A, Bes-Rastrollo M. Adherence to Mediterranean diet and risk of developing diabetes: prospective cohort study. BMJ. Jun. 14. 2008;336(7657):1348-51. [pmid: 18511765].
60 McMahon FG, F K, Singh BN, Mendel CM, Rowe E, Rolston K, Johnson F, Mooradian AD. Efficacy and safety of sibutramine in obese white and African American patients with hypertension: a 1-year, double-blind, placebo-controlled, multicenter trial. Arch Intern Med. Jul. 24. 2000;160(14):2185-91. [pmid: 10904462].
61 Melchionda L, Di Domizio S, Pasqui F, Nuccitelli C, Migliorini S, Baraldi L, Natale S, Manini R, Bellini M, Belsito C, Forlani G, Marchesini G. Cognitive behavioural therapy for obesity: one-year follow-up in a clinical setting. Eat Weight Disord. Sep. 2003;8(3):188-93. [pmid: 14649781].
62 Moon Han S, K WW, Oh JH. Results of laparoscopic sleeve gastrectomy (LSG) at 1 year in morbidly obese Korean patients. Obes Surg. Nov-Dec. 2005;15(10):1469-75. [pmid: 16354529].
63 Morino M, T M, Garrone C. Disappointing long-term results of laparoscopic adjustable silicone gastric banding. Br J Surg. Jun. 1997;84(6):868-9. [pmid: 9189114].
64 Morino M, T M, Garrone C, Morino F. Laparoscopic adjustable silicone gastric banding for the treatment of morbid obesity. Br J Surg. Aug. 1994;81(8):1169-70. [pmid: 7953351].
65 Narayan KM, H M, Kozak D, Kriska AM, Hanson RL, Pettitt DJ, Nagi DK, Bennett PH, Knowler WC. Randomized clinical trial of lifestyle interventions in Pima Indians: a pilot study. Diabet Med. Jan. 1998;15(1):66-72. [pmid: 9472866].
66 Nedelnikova K, S S, Haas T, Matoulek M, Fried M. Influence of metabolic state and diabetes on the outcome at the end of first year after gastric banding. Obes Surg. Aug. 2000;10(4):372-5. [pmid: 11007633].
67 Nicklas B, JD KE, Berman DM, Sorkin J, Ryan AS, Goldberg AP. Lifestyle intervention of hypocaloric dieting and walking reduces abdominal obesity and improves coronary heart disease risk factors in obese, postmenopausal, African-American and Caucasian women. J Gerontol A Biol Sci Med Sci. Feb. 2003;58(2):181-9. [pmid: 12586858].
68 Nilsson PML LH, Schersten BF. Life style changes improve insulin resistance in hyperinsulinaemic subjects: a one-year intervention study of hypertensives and normotensives in Dalby. J Hypertens. Sep. 1992;10(9):1071-8. [pmid: 1328367].
69 Olsson SA, N-E P, Pettersson BG, Sorbris R. Gastroplasty as a treatment for massive obesity. A clinical and biochemical evaluation. Scand J Gastroenterol. Mar. 1985;20(2):215-21. [pmid: 3992180].
70 Olsson SA, R O, Danielsson A, Nilsson-Ehle P. Weight reduction after gastroplasty: the predictive value of surgical, metabolic, and psychological variables. Int J Obes. 1984;8(3):245-58. [pmid: 6746192].
71 Owen ER, A R, Kark AE. Gastroplasty for morbid obesity: technique, complications and results in 60 cases. Br J Surg. Feb. 1989;76(2):131-5. [pmid: 2702443].
72 Payne JH, D L, Schwab CE, Kern WH. Surgical treatment of morbid obesity. Sixteen years of experience. Arch Surg. Apr. 1973;106(4):432-7. [pmid: 4696715].
73 Peiser J, L P, Ovnat A, Charuzi I. Sleep apnea syndrome in the morbidly obese as an indication for weight reduction surgery. Ann Surg. Jan. 1984;199(1):112-5. [pmid: 6691724].
74 Pereira MA, S J, Goldfine AB, Rifai N, Ludwig DS. Effects of a low-glycemic load diet on resting energy expenditure and heart disease risk factors during weight loss. JAMA. Nov. 24. 2004;292(20):2482-90. [pmid: 15562127].
75 Peterson CM, J-P L. Randomized crossover study of 40% vs. 55% carbohydrate weight loss strategies in women with previous gestational diabetes mellitus and non-diabetic women of 130-200% ideal body weight. J Am Coll Nutr. Aug. 1995;14(4):369-75. [pmid: 8568114].
76 Pittas AG, R SB, Das SK, Gilhooly CH, Saltzman E, Golden J, Stark PC, Greenberg AS. The effects of the dietary glycemic load on type 2 diabetes risk factors during weight loss. Obesity (Silver Spring). Dec. 2006;14(12):2200-9. [pmid: 17189547].
77 Rabast U, S J, Kasper H. Dietetic treatment of obesity with low and high-carbohydrate diets: comparative studies and clinical results. Int J Obes. 1979;3(3):201-11. [pmid: 395115].
78 Ramsey-Stewart G. Vertical banded gastroplasty for morbid obesity: weight loss at short and long-term follow up. Aust N Z J Surg. Jan. 1995;65(1):4-7. [pmid: 7818421].
79 Reinhold RB. Critical analysis of long term weight loss following gastric bypass. Surg Gynecol Obstet. Sep. 1982;155(3):385-94. [pmid: 7051382].
80 Rokling-Andersen MH, R JE, Veierod MB, Anderssen SA, Jacobs DR Jr., Urdal P, Jansson JO, Drevon CA. Effects of long-term exercise and diet intervention on plasma adipokine concentrations. Am J Clin Nutr. Nov. 2007;86(5):1293-301. [pmid: 17991638].
81 Ross R, D D, Jones PJ, Smith H, Paddags A, Hudson R, Janssen I. Reduction in obesity and related comorbid conditions after diet-induced weight loss or exercise-induced weight loss in men. A randomized, controlled trial. Ann Intern Med. Jul. 18. 2000;133(2):92-103. [pmid: 10896648].
82 Ross R, J I. Physical activity, total and regional obesity: dose-response considerations. Med Sci Sports Exerc. Jun. 2001;33(6 Suppl):S521-7. discussion S8-9. [pmid: 11427779].
83 Rucker RD Jr., Horstmann J, Schneider PD, Varco RL, Buchwald H. Comparisons between jejunoileal and gastric bypass operations for morbid obesity. Surgery. Aug. 1982;92(2):241-9. [pmid: 7101125].
84 Ryden O, O SA, Danielsson A, Nilsson-Ehle P. Weight loss after gastroplasty: psychological sequelae in relation to clinical and metabolic observations. J Am Coll Nutr. Feb. 1989;8(1):15-23. [pmid: 2538497].
85 Schwarz A, B M, Usinger K, Rieger H, Glasbrenner B, Friess H, Kunz R, Beger HG. Importance of the duodenal passage and pouch volume after total gastrectomy and reconstruction with the Ulm pouch: prospective randomized clinical study. World J Surg. Jan. 1996;20(1):60-6. discussion 6-7. [pmid: 8588415].
86 Shah M, S V, Garg A. Review: long-term impact of bariatric surgery on body weight, comorbidities, and nutritional status. J Clin Endocrinol Metab. Nov. 2006;91(11):4223-31. [pmid: 16954156].
87 Toft UN, K LH, Aadahl M, von Huth Smith L, Pisinger C, Jorgensen T. Diet and exercise intervention in a general population--mediators of participation and adherence: the Inter99 study. Eur J Public Health. Oct. 2007;17(5):455-63. [pmid: 17170019].
88 Tweddle EA, W S, Blamey S. Laparoscopic gastric banding: safe and modestly successful. ANZ J Surg. Apr. 2004;74(4):191-4. [pmid: 15043723].
89 Vishne TH, R E, Alper D, Avraham Z, Seror D, Dreznik Z. Long-term follow-up and factors influencing success of silastic ring vertical gastroplasty. Dig Surg. 2004;21(2):134-40. discussion 40-1. [pmid: 15044814].
90 Weiner RA. Surgical treatment of the metabolic syndrome. Viszeralmedizin: Gastrointestinal Medicine and Surgery. 2010;26(1):8-12.
91 Weissgerber TL, W LA, Davies GA, Mottola MF. Exercise in the prevention and treatment of maternal-fetal disease: a review of the literature. Appl Physiol Nutr Metab. Dec. 2006;31(6):661-74. [pmid: 17213880].
92 Wickremesekera K, M G, Naotunne TD, Knowles G, Stubbs RS. Loss of insulin resistance after Roux-en-Y gastric bypass surgery: a time course study. Obes Surg. Apr. 2005;15(4):474-81. [pmid: 15946424].
93 Wing RR, J RW. Effect of modest weight loss on changes in cardiovascular risk factors: are there differences between men and women or between weight loss and maintenance?. Int J Obes Relat Metab Disord. Jan. 1995;19(1):67-73. [pmid: 7719395].
94 Yates BT. Survey comparison of success, morbidity, mortality, fees and psychological benefits and costs of 3,146 patients receiving jejunoileal or gastric bypass. Am J Clin Nutr. Feb. 1980;33(2 Suppl):518-22. [pmid: 7355832].

## Reject BMI > 35

1 Abbatini F, Rizzello M, Casella G, et al. Long-term effects of laparoscopic sleeve gastrectomy, gastric bypass, and adjustable gastric banding on type 2 diabetes. Surg Endosc. May. 2010;24(5):1005-10. [pmid: 19866235].
2 Adami GF, C R, Camerini G, Marinari GM, Scopinaro N. Long-term normalization of insulin sensitivity following biliopancreatic diversion for obesity. Int J Obes Relat Metab Disord. May. 2004;28(5):671-3. [pmid: 15024397].
3 Adams TD, G RE, Smith SC, Halverson RC, Simper SC, Rosamond WD, Lamonte MJ, Stroup AM, Hunt SC. Long-term mortality after gastric bypass surgery. N Engl J Med. Aug. 23. 2007;357(8):753-61. [pmid: 17715409].
4 Agren G, N K, Naslund I, Sjostrom L, Peltonen M. Long-term effects of weight loss on pharmaceutical costs in obese subjects. A report from the SOS intervention study. Int J Obes Relat Metab Disord. Feb. 2002;26(2):184-92. [pmid: 11850749].
5 Agren G, N I. A prospective randomized comparison of vertical banded gastroplasty (VBG), loop gastric bypass (GBY) and gastric banding (GB). Int J Obes. 1989;13:595.
6 Alekseeva RI, S KhKh, Plotnikova OA, Meshcheriakova VA, Mal'tsev GIu, Kulakova SN. Effects of diet therapy including eiconol on clinical and metabolic parameters in patients with type 2 diabetes mellitus. Vopr Pitan. 2000;69(5):36-9. [pmid: 11247166].
7 Almbrand B, J M, Sjostrand B, Malmberg K, Ryden L. Cost-effectiveness of intense insulin treatment after acute myocardial infarction in patients with diabetes mellitus; results from the DIGAMI study. Eur Heart J. May. 2000;21(9):733-9. [pmid: 10739728].
8 Anderson JW, C SB, Nicholas AS. One hundred pound weight losses with an intensive behavioral program: changes in risk factors in 118 patients with long-term follow-up. Am J Clin Nutr. Aug. 2007;86(2):301-7. [pmid: 17684198].
9 Angrisani L, A M, Basso N, Belvederesi N, Campanile F, Capizzi FD, D'Atri C, Di Cosmo L, Doldi SB, Favretti F, Forestieri P, Furbetta F, Giacomelli F, Giardiello C, Iuppa A, Lesti G, Lucchese M, Puglisi F, Scipioni L, Toppino M, Turicchia GU, Veneziani A, Docimo C, Borrelli V, Lorenzo M. Laparoscopic Italian experience with the Lap-Band. Obes Surg. Jun. 2001;11(3):307-10. [pmid: 11433906].
10 Angrisani LD, L N, Favretti F, Furbetta F, Iuppa A, Doldi SB, Paganelli M, Basso N, Lucchese M, Zappa M, Lesti G, Capizzi FD, Giardiello C, Paganini A, Di Cosmo L, Veneziani A, Lacitignola S, Silecchia G, Alkilani M, Forestieri P, Puglisi F, Gardinazzi A, Toppino M, Campanile F, Marzano B, Bernante P, Perrotta G, Borrelli V, Lorenzo M. The Italian Group for LAP-BAND: predictive value of initial body mass index for weight loss after 5 years of follow-up. Surg Endosc. Oct. 2004;18(10):1524-7. [pmid: 15791382].
11 Angrisani L, F F, Doldi SB, Basso N, Lucchese M, Giacomelli F, Zappa M, Di Cosmo L, Veneziani A, Turicchia GU, Alkilani M, Forestieri P, Lesti G, Puglisi F, Toppino M, Campanile F, Capizzi FD, D'Atri C, Sciptoni L, Giardiello C, Di Lorenzo N, Lacitignola S, Belvederesi N, Marzano B, Bernate P, Iuppa A, Borrelli V, Lorenzo M. Lap Band adjustable gastric banding system: the Italian experience with 1863 patients operated on 6 years. Surg Endosc. Mar. 2003;17(3):409-12. [pmid: 12457216].
12 Angrisani L, L M, Borrelli V. Laparoscopic adjustable gastric banding versus Roux-en-Y gastric bypass: 5-year results of a prospective randomized trial. Surg Obes Relat Dis. Mar-Apr. 2007;3(2):127-32. discussion 32-3. [pmid: 17331805].
13 Aronne L, F K, Aroda V, Chen K, Halseth A, Kesty NC, Burns C, Lush CW, Weyer C. Progressive reduction in body weight after treatment with the amylin analog pramlintide in obese subjects: a phase 2, randomized, placebo-controlled, dose-escalation study. J Clin Endocrinol Metab. Aug. 2007;92(8):2977-83. [pmid: 17504894].
14 Ashrafian H, Athanasiou T, Li JV, et al. Diabetes resolution and hyperinsulinaemia after metabolic Roux-en-Y gastric bypass. Obes Rev. May. 2011;12(5):e257-72. [pmid: 20880129].
15 Ashy AR, M AA. A prospective study comparing vertical banded gastroplasty versus laparoscopic adjustable gastric banding in the treatment of morbid and super-obesity. Int Surg. Apr-Jun. 1998;83(2):108-10. [pmid: 9851324].
16 Avenell A, B J, Brown TJ, Poobalan A, Aucott L, Stearns SC, Smith WC, Jung RT, Campbell MK, Grant AM. Systematic review of the long-term effects and economic consequences of treatments for obesity and implications for health improvement. Health Technol Assess. May. 2004;8(21):iii-iv. 1. 182. [pmid: 15147610].
17 Babio N, B M, Salas-Salvado J. Mediterranean diet and metabolic syndrome: the evidence. Public Health Nutr. Sep. 2009;12(9A):1607-17. [pmid: 19689829].
18 Balducci S, Z S, Fernando F, Fallucca S, Fallucca F, Pugliese G. Physical activity/exercise training in type 2 diabetes. The role of the Italian Diabetes and Exercise Study. Diabetes Metab Res Rev. Sep. Suppl 1. 2009;25:S29-33. [pmid: 19662617].
19 Baltasar A, B R, Miro J, et al. Roux-en-Y laparoscopic gastric bypass in patients with morbid obesity. Revista Espanola de Enfermedades Digestivas. 2000;92:661-8.
20 Barnard RJ, M MR, Cherny S, O'Brien LT, Pritikin N. Long-term use of a high-complex-carbohydrate, high-fiber, low-fat diet and exercise in the treatment of NIDDM patients. Diabetes Care. May-Jun. 1983;6(3):268-73. [pmid: 6307614].
21 Basdevant A, P M, Rodde-Dunet MH, Marty M, Nogues F, Slim K, Chevallier JM. A nationwide survey on bariatric surgery in France: two years prospective follow-up. Obes Surg. Jan. 2007;17(1):39-44. [pmid: 17355767].
22 Basso N, Casella G, Rizzello M, et al. T2DM and sleeve gastrectomy: Diabetes duration as prognostic factor of cure. Obesity Surgery. 2010;20(8):980.
23 Batsis JA, R-C A, Collazo-Clavell ML, Sarr MG, Somers VK, Lopez-Jimenez F. Effect of bariatric surgery on the metabolic syndrome: a population-based, long-term controlled study. Mayo Clin Proc. Aug. 2008;83(8):897-907. [pmid: 18674474].
24 Beaser SB, H FM. Partial remission of diabetes mellitus after oral antidiabetic therapy. Postgrad Med. Mar. 1971;49(3):101-5. [pmid: 5547891].
25 Belachew M, J P, Lardinois F, Karler C. Vertical Banded Gastroplasty vs Adjustable Silicone Gastric Banding in the Treatment of Morbid Obesity: a Preliminary Report. Obes Surg. Aug. 1993;3(3):275-8. [pmid: 10757933].
26 Belachew M, L MJ, Vincent V, Defechereux TH, Jourdan JL, Monami B, Jacquet N. Laparoscopic placement of adjustable silicone gastric banding in the treatment of morbid obesity. Obes Surg. 1992;5:66-9. [pmid: 10733796].
27 Belalcazar LM, R David M, Haffner Steven M, Reeves Rebecca S, Schwenke Dawn C, Hoogeveen Ron C, Pi-Sunyer F. Xavier, Ballantyne Christie M. Marine ω-3 Fatty Acid Intake. Diabetes Care. January. 2010. 2010;33(1):197-9. [pmid: 19841042].
28 Benaiges Boix D, Goday Arno A, Pedro-Botet J. Bariatric surgery for the treatment of type 2 diabetes mellitus. Med Clin (Barc). 2011. Jun. 20. [pmid: 21696780].
29 Berry M, Lionel U, Guixe C, et al. Sleeve gastrectomy in type 2 diabetic obese patients. Surgical Endoscopy and Other Interventional Techniques. 2011;25:S254.
30 Best JH, B KS, Rubin RR, Cao D, Kim TH, Peyrot M. Improved treatment satisfaction and weight-related quality of life with exenatide once weekly or twice daily. Diabet Med. Jul. 2009;26(7):722-8. [pmid: 19573122].
31 Bischoff SC, Damms-Machado A, Betz C, et al. Multicenter evaluation of an interdisciplinary 52-week weight loss program for obesity with regard to body weight, comorbidities and quality of life-a prospective study. Int J Obes (Lond). 2011. Jun. 14. [pmid: 21673653].
32 Bjorntorp P, K M. Exercise treatment in diabetes mellitus. Acta Med Scand. 1985;217(1):3-7. [pmid: 3883702].
33 Boule NG, H E, Kenny GP, Wells GA, Sigal RJ. Effects of exercise on glycemic control and body mass in type 2 diabetes mellitus: a meta-analysis of controlled clinical trials. JAMA. Sep. 12. 2001;286(10):1218-27. [pmid: 11559268].
34 Boza C, Gamboa C, Awruch D, et al. Laparoscopic Roux-en-Y gastric bypass versus laparoscopic adjustable gastric banding: Five years of follow-up. Surgery for Obesity and Related Diseases. 2010;6(5):470-5. [pmid: 20702146].
35 Boza C, Gamboa C, Viscido G, et al. Laparoscopic sleeve gastrectomy as a primary bariatric procedure. Results in 1000 consecutive patients. Obesity Surgery. 2010;20(8):989.
36 Bradshaw C, Collins W, Hakky S, et al. Surgical morbidity associated with laparoscopic bariatric surgery in type 1 and type 2 diabetics. Obesity Surgery. 2010;20(8):1010.
37 Bray GA. Baseline characteristics of the randomised cohort from the Look AHEAD (Action for Health in Diabetes) study. Diabetes and Vascular Disease Research. December. 1. 2006. 2006;3(3):202-15. [pmid: 17160917].
38 Bray GA. Lifestyle and pharmacological approaches to weight loss: efficacy and safety. J Clin Endocrinol Metab. Nov. 2008;93(11 Suppl 1):S81-8. [pmid: 18987274].
39 Brehm BJ, L BL, Summer SS, Boback JA, Gilchrist GM, Jandacek RJ, D'Alessio DA. One-year comparison of a high-monounsaturated fat diet with a high-carbohydrate diet in type 2 diabetes. Diabetes Care. Feb. 2009;32(2):215-20. [pmid: 18957534].
40 Breum L, B U, Bak JF, Jacobsen S, Astrup A. Long-term effects of fluoxetine on glycemic control in obese patients with non-insulin-dependent diabetes mellitus or glucose intolerance: influence on muscle glycogen synthase and insulin receptor kinase activity. Metabolism. Dec. 1995;44(12):1570-6. [pmid: 8786726].
41 Briatore L, S B, Andraghetti G, Danovaro C, Sferrazzo E, Scopinaro N, Adami GF, Maggi D, Cordera R. Restoration of acute insulin response in T2DM subjects 1 month after biliopancreatic diversion. Obesity (Silver Spring). Jan. 2008;16(1):77-81. [pmid: 18223616].
42 Brolin RE. Bariatric surgery and long-term control of morbid obesity. JAMA. Dec. 11. 2002;288(22):2793-6. [pmid: 12472304].
43 Brolin RE, K HA, Wilson AC, Kuo PT, Cody RP. Serum lipids after gastric bypass surgery for morbid obesity. Int J Obes. Nov. 1990;14(11):939-50. [pmid: 2276855].
44 Buchwald H, E R, Fahrbach K, Banel D, Jensen MD, Pories WJ, Bantle JP, Sledge I. Weight and type 2 diabetes after bariatric surgery: systematic review and meta-analysis. Am J Med. Mar. 2009;122(3):248-56 e5. [pmid: 19272486].
45 Buchwald H, V RL. A bypass operation for obese hyperlipidemic patients. Surgery. Jul. 1971;70(1):62-70. [pmid: 5092117].
46 Buchwald H, V RL, Matts JP, Long JM, Fitch LL, Campbell GS, Pearce MB, Yellin AE, Edmiston WA, Smink RD Jr., et al. Effect of partial ileal bypass surgery on mortality and morbidity from coronary heart disease in patients with hypercholesterolemia. Report of the Program on the Surgical Control of the Hyperlipidemias (POSCH). N Engl J Med. Oct. 4. 1990;323(14):946-55. [pmid: 2205799].
47 Buffington CK, C GS Jr., Smith H. Significant Changes in the Lipid-Lipoprotein Status of Premenopausal Morbidly Obese Females following Gastric Bypass Surgery. Obes Surg. Nov. 1994;4(4):328-35. [pmid: 10742796].
48 Buffington CK, M RT. Ethnic differences in obesity and surgical weight loss between African-American and Caucasian females. Obes Surg. Feb. 2006;16(2):159-65. [pmid: 16469217].
49 Busetto L, P C, Rinaldi D, Longhin PL, Segato G, De Marchi F, Foletto M, Favretti F, Lise M, Enzi G. Variation in lipid levels in morbidly obese patients operated with the LAP-BAND adjustable gastric banding system: effects of different levels of weight loss. Obes Surg. Dec. 2000;10(6):569-77. [pmid: 11175968].
50 Butner K, N-R Sharon, Clark Susan, Ramp Warren, Herbert William. A Review of Weight Loss Following Roux-en-Y Gastric Bypass vs Restrictive Bariatric Surgery: Impact on Adiponectin and Insulin. Obesity Surgery. 2010;20(5):559-68. [pmid: 20177811].
51 Cabrera A, Sabench F, Hernandez M, et al. Analysis ofthe weight-reducing and metabolic efficacy of laparascopic sleeve gastrectomy. Surgical Endoscopy and Other Interventional Techniques. 2011;25:S124.
52 Caiazzo R, Arnalsteen L, Pigeyre M, et al. Long-term metabolic outcome and quality of life after laparoscopic adjustable gastric banding in obese patients with type 2 diabetes mellitus or impaired fasting glucose. Br J Surg. Jun. 2010;97(6):884-91. [pmid: 20473998].
53 Carey DG, P GJ, Raymond RL. Body composition and metabolic changes following bariatric surgery: effects on fat mass, lean mass and basal metabolic rate: six months to one-year follow-up. Obes Surg. Dec. 2006;16(12):1602-8. [pmid: 17217636].
54 Cariani S, N D, Grani S, Vittimberga G, Lucchi A, Amenta E. Complications after gastroplasty and gastric bypass as a primary operation and as a reoperation. Obes Surg. Aug. 2001;11(4):487-90. [pmid: 11501361].
55 Carlson LA, O J. Effect of chlorpropamide treatment on serum lipid levels in diabetes mellitus. Acta Med Scand. Nov. 1961;170:561-4. [pmid: 13876642].
56 Caro JJ, K WS, Raggio G, Kavanagh PL, O'Brien JA, Shomphe LA, Flegel KM, Copley-Merriman C, Sigler C. Economic assessment of troglitazone as an adjunct to sulfonylurea therapy in the treatment of type 2 diabetes. Clin Ther. Jan. 2000;22(1):116-27. [pmid: 10688395].
57 Carson JL, R ME, Duff AE, Holmes NJ, Cody RP, Brolin RE. The effect of gastric bypass surgery on hypertension in morbidly obese patients. Arch Intern Med. Jan. 24. 1994;154(2):193-200. [pmid: 8285814].
58 Case CC, J PH, Nelson K, O'Brian Smith E, Ballantyne CM. Impact of weight loss on the metabolic syndrome. Diabetes Obes Metab. Nov. 2002;4(6):407-14. [pmid: 12406040].
59 Catona A, G M, Mussini G, La Manna L, De Bastiani T, Armeni E. Videolaparoscopic Vertical Banded Gastroplasty. Obes Surg. Aug. 1995;5(3):323-6. [pmid: 10733820].
60 CDC Diabetes Cost-effectiveness Group Research Support. Cost-effectiveness of intensive glycemic control, intensified hypertension control, and serum cholesterol level reduction for type 2 diabetes. JAMA. May. 15. 2002;287(19):2542-51. [pmid: 12020335].
61 Ceelen W, W J, Cardon A, Van Renterghem K, Hesse U, El Malt M, Pattyn P. Surgical treatment of severe obesity with a low-pressure adjustable gastric band: experimental data and clinical results in 625 patients. Ann Surg. Jan. 2003;237(1):10-6. [pmid: 12496524].
62 Champagne CM. Magnesium in hypertension, cardiovascular disease, metabolic syndrome, and other conditions: a review. Nutr Clin Pract. Apr-May. 2008;23(2):142-51. [pmid: 18390781].
63 Champagne CM. The usefulness of a Mediterranean-based diet in individuals with type 2 diabetes. Curr Diab Rep. Oct. 2009;9(5):389-95. [pmid: 19793509].
64 Chapman AE, K G, Game P, Foster B, O'Brien P, Ham J, Maddern GJ. Laparoscopic adjustable gastric banding in the treatment of obesity: a systematic literature review. Surgery. Mar. 2004;135(3):326-51. [pmid: 14976485].
65 Charbonnel B, K A, Liu J, Wu M, Meininger G. Efficacy and safety of the dipeptidyl peptidase-4 inhibitor sitagliptin added to ongoing metformin therapy in patients with type 2 diabetes inadequately controlled with metformin alone. Diabetes Care. Dec. 2006;29(12):2638-43. [pmid: 17130197].
66 Chau WY, S HJ, Kouli W, Davis D, Wasielewski A, Ballantyne GH. Patient characteristics impacting excess weight loss following laparoscopic adjustable gastric banding. Obes Surg. Mar. 2005;15(3):346-50. [pmid: 15826467].
67 Chen JF. A hemorrheological study on the effect of acupuncture in treating diabetes mellitus. J Tradit Chin Med. Jun. 1987;7(2):95-100. [pmid: 3448402].
68 Chen KM, L WJ, Lai HS, Chen WJ. Fifteen years' experience with gastric partitioning for obesity treatment. J Formos Med Assoc. Jun. 1998;97(6):381-6. [pmid: 9650465].
69 Cheskin LJ, M AM, Jhaveri AD, Mitola AH, Davis LM, Lewis RA, Yep MA, Lycan TW. Efficacy of meal replacements versus a standard food-based diet for weight loss in type 2 diabetes: a controlled clinical trial. Diabetes Educ. Jan-Feb. 2008;34(1):118-27. [pmid: 18267998].
70 Chevallier JM, P M, Rodde-Dunet MH, Marty M, Nogues F, Slim K, Basdevant A. Predictive factors of outcome after gastric banding: a nationwide survey on the role of center activity and patients' behavior. Ann Surg. Dec. 2007;246(6):1034-9. [pmid: 18043107].
71 Chiasson JL. Acarbose for the prevention of diabetes, hypertension, and cardiovascular disease in subjects with impaired glucose tolerance: the Study to Prevent Non-Insulin-Dependent Diabetes Mellitus (STOP-NIDDM) Trial. Endocr Pract. Jan-Feb. Suppl 1. 2006;12:25-30. [pmid: 16627376].
72 Chiasson JL, G R, Hanefeld M, Josse RG, Karasik A, Laakso M. The STOP-NIDDM Trial: an international study on the efficacy of an alpha-glucosidase inhibitor to prevent type 2 diabetes in a population with impaired glucose tolerance: rationale, design, and preliminary screening data. Study to Prevent Non-Insulin-Dependent Diabetes Mellitus. Diabetes Care. Oct. 1998;21(10):1720-5. [pmid: 9773737].
73 Chikunguwo S, D Patricia W, Meador Jill G, Wolfe Luke G, Baugh Nancy, Kellum John M, Maher James W. PL-101: Durable resolution of diabetes after Roux-en-Y gastric bypass is associated with maintenance of weight loss. Surgery for Obesity and Related Diseases. 2009;5(3, Supplement 1):S1-S. [pmid: 19764118].
74 Christou NV, S JS, Liberman M, Look D, Auger S, McLean AP, MacLean LD. Surgery decreases long-term mortality, morbidity, and health care use in morbidly obese patients. Ann Surg. Sep. 2004;240(3):416-23. discussion 23-4. [pmid: 15319713].
75 Clegg A, S M, Colquitt J, et al. Clinical and cost effectiveness of surgery for people with morbid obesity Wessex Institute for Health and Research and Development. Southhampton. 2001.
76 Closset J, M A, Barea M, Buedts K, Gelin M, Houben JJ. Results of silastic ring vertical gastroplasty more than 6 years after surgery: analysis of a cohort of 214 patients. Obes Surg. Oct. 2004;14(9):1233-6. [pmid: 15527640].
77 Cohen BE, C AA, Grady D, Kanaya AM. Restorative yoga in adults with metabolic syndrome: a randomized, controlled pilot trial. Metab Syndr Relat Disord. Fall. 2008;6(3):223-9. [pmid: 18710330].
78 Coleman J, Phillips S. Bariatric surgery: a cutting-edge cure for Type 2 diabetes?. N Z Med J. Mar. 19. 2010;123(1311):65-8. [pmid: 20360798].
79 Colle B, B S. Cardiovascular risk reduction: impact of an international project. Ann Ig. May-Jun. 2008;20(3 Suppl 1):43-8. [pmid: 18773604].
80 Collet D, R A, Sa Cunha A, Larroude D, Masson B. Laparoscopic adjustable gastric banding results after 2 years with two different band types. Obes Surg. Jun-Jul. 2005;15(6):853-7. [pmid: 15978158].
81 Contreras J, Villao D, Bravo J, et al. Improvement and remission in type 2 diabetes mellitus after laparoscopic vertical sleeve gastrectomy in obese patients. Obesity Surgery. 2010;20(8):981-2.
82 Cottam DR, A J, Anderson A, Grace B, Fisher B. A case-controlled matched-pair cohort study of laparoscopic Roux-en-Y gastric bypass and Lap-Band patients in a single US center with three-year follow-up. Obes Surg. May. 2006;16(5):534-40. [pmid: 16687018].
83 Cowan GS Jr., Buffington CK. Significant changes in blood pressure, glucose, and lipids with gastric bypass surgery. World J Surg. Sep. 1998;22(9):987-92. [pmid: 9717426].
84 Cramer JS, S RF, Bartlett DP, Kahn LS, Loffredo L. An adaptation of the diabetes prevention program for use with high-risk, minority patients with type 2 diabetes. Diabetes Educ. May-Jun. 2007;33(3):503-8. [pmid: 17570881].
85 Crampton NA, I V, Stubbs RS. Silastic ring gastric bypass: a comparison of two ring sizes: a preliminary report. Obes Surg. Dec. 1997;7(6):495-9. [pmid: 9730507].
86 Cranor CW, B BA, Christensen DB. The Asheville Project: long-term clinical and economic outcomes of a community pharmacy diabetes care program. J Am Pharm Assoc (Wash). Mar-Apr. 2003;43(2):173-84. [pmid: 12688435].
87 Cremieux PY, Ledoux S, Clerici C, et al. The impact of bariatric surgery on comorbidities and medication use among obese patients. Obes Surg. Jul. 2010;20(7):861-70. [pmid: 20440579].
88 Cummings DE, W DS, Frayo RS, Breen PA, Ma MK, Dellinger EP, Purnell JQ. Plasma ghrelin levels after diet-induced weight loss or gastric bypass surgery. N Engl J Med. May. 23. 2002;346(21):1623-30. [pmid: 12023994].
89 Cunneen SA. Review of meta-analytic comparisons of bariatric surgery with a focus on laparoscopic adjustable gastric banding. Surg Obes Relat Dis. May-Jun. 2008;4(3 Suppl):S47-55. [pmid: 18501315].
90 Cunneen SA, P E, Fielding G, Banel D, Estok R, Fahrbach K, Sledge I. Studies of Swedish adjustable gastric band and Lap-Band: systematic review and meta-analysis. Surg Obes Relat Dis. Mar-Apr. 2008;4(2):174-85. [pmid: 18243061].
91 Dan D, Harnanan D, Singh Y, et al. Effects of bariatric surgery on Type-2 Diabetes Mellitus in a Caribbean setting. Int J Surg. 2011;9(5):386-91. [pmid: 21420513].
92 Dapri G, C GB, Himpens J. Reinforcing the staple line during laparoscopic sleeve gastrectomy: prospective randomized clinical study comparing three different techniques. Obes Surg. Apr. 2010;20(4):462-7. [pmid: 20012507].
93 Dasgupta K, G SA, Da Costa D, Lowensteyn I, Yale JF, Rahme E. Impact of modified glucose target and exercise interventions on vascular risk factors. Diabetes Res Clin Pract. Apr. 2006;72(1):53-60. [pmid: 16256242].
94 Davidson JA, S AJ, Howlett HC. Tolerability profile of metformin/glibenclamide combination tablets (Glucovance): a new treatment for the management of type 2 diabetes mellitus. Drug Saf. 2004;27(15):1205-16. [pmid: 15588116].
95 Davila-Cervantes A, B D, Dominguez-Cherit G, Gamino R, Vargas-Vorackova F, Gonzalez-Barranco J, Herrera MF. Open versus laparoscopic vertical banded gastroplasty: a randomized controlled double blind trial. Obes Surg. Dec. 2002;12(6):812-8. [pmid: 12568187].
96 Davis-Smith YM, B JM, Seale JP, Shellenberger S, Blalock T, Tobin B. Implementing a diabetes prevention program in a rural African-American church. J Natl Med Assoc. Apr. 2007;99(4):440-6. [pmid: 17444435].
97 Davis NJ, T N, Schechter C, Isasi CR, Segal-Isaacson CJ, Stein D, Zonszein J, Wylie-Rosett J. Comparative study of the effects of a 1-year dietary intervention of a low-carbohydrate diet versus a low-fat diet on weight and glycemic control in type 2 diabetes. Diabetes Care. Jul. 2009;32(7):1147-52. [pmid: 19366978].
98 Davis TM, Coleman C. Laparoscopic adjustable gastric banding in patients with insulin-treated type 2 diabetes. Med J Aust. Apr. 18. 2011;194(8):427-8. [pmid: 21495950].
99 de Gordejuela AG, Pujol Gebelli J, Garcia NV, et al. Is sleeve gastrectomy as effective as gastric bypass for remission of type 2 diabetes in morbidly obese patients?. Surg Obes Relat Dis. Jul-Aug. 2011;7(4):506-9. [pmid: 21411376].
100 de la Cruz-Munoz N, Messiah SE, Arheart KL, et al. Bariatric surgery significantly decreases the prevalence of type 2 diabetes mellitus and pre-diabetes among morbidly obese multiethnic adults: long-term results. J Am Coll Surg. Apr. 2011;212(4):505-11. discussion 12-3. [pmid: 21463779].
101 de Paula AL, M AL, Prudente AS, Queiroz L, Schraibman V, Pinus J. Laparoscopic sleeve gastrectomy with ileal interposition (“neuroendocrine brake”)--pilot study of a new operation. Surg Obes Relat Dis. Jul-Aug. 2006;2(4):464-7. [pmid: 16925382].
102 Deakin T, M CE, Cade JE, Williams RD. Group based training for self-management strategies in people with type 2 diabetes mellitus. Cochrane Database Syst Rev. 2005;(2):CD003417. [pmid: 15846663].
103 Del Castillo D. Analysis of the weight-reducing and metabolic efficacy of laparascopic sleeve gastrectomy. Obesity Surgery. 2010;20(8):1047-8.
104 Delea TE, E JS, Hagiwara M, Oste G, Phillips LS. Use of thiazolidinediones and risk of heart failure in people with type 2 diabetes: a retrospective cohort study. Diabetes Care. Nov. 2003;26(11):2983-9. [pmid: 14578227].
105 Delgado H, L T, Bobbioni-Harsch E, Ybarra J, Golay A. Acarbose improves indirectly both insulin resistance and secretion in obese type 2 diabetic patients. Diabetes Metab. Jun. 2002;28(3):195-200. [pmid: 12149599].
106 DeMaria EJ, S HJ. A critical look at laparoscopic adjustable silicone gastric banding for surgical treatment of morbid obesity: does it measure up?. Surg Endosc. Aug. 2000;14(8):697-9. [pmid: 10954811].
107 Demssie YN, Jawaheer J, Farook S, et al. Weight and glycaemic outcomes following bariatric surgery in people with type 2 diabetes. Endocrine Abstracts. 2010;21:P161.
108 DePaula AL, Stival AR, Halpern A, et al. Surgical treatment of morbid obesity: mid-term outcomes of the laparoscopic ileal interposition associated to a sleeve gastrectomy in 120 patients. Obes Surg. May. 2011;21(5):668-75. [pmid: 20652440].
109 Desaive C. A critical review of a personal series of 1000 gastroplasties. Int J Obes Relat Metab Disord. Sep. Suppl 3. 1995;19:S56-60. [pmid: 8581079].
110 Dibble CT, G EV, Cannon CP. Rimonabant: the role of endocannabinoid type 1 receptor antagonism in modulating the weight and lipid profile of obese patients. Curr Atheroscler Rep. Nov. 2007;9(5):359-66. [pmid: 18001618].
111 Dietary measures for type 2 diabetes. Weight loss and a Mediterranean-type diet, with no foods off-limits. Prescrire Int. Oct. 2009;18(103):224. [pmid: 19882798].
112 DiGiorgi M, Rosen DJ, Choi JJ, et al. Re-emergence of diabetes after gastric bypass in patients with mid- to long-term follow-up. Surg Obes Relat Dis. May-Jun. 2010;6(3):249-53. [pmid: 20510288].
113 DiGiorgi M, C Jenny Jee-Eun, Milone Luca, Schrope Beth, Olivero-Rivera Lorraine, Restuccia Nancy, Urban-Skuro Meredith C, Inabnet William B, Bessler Marc. PL-213: Recurrence of diabetes after gastric bypass in patients with mid to long-term follow up. Surgery for Obesity and Related Diseases. 2009;5(3, Supplement 1):S13-S.
114 Dixon J, Oefelein M, Okersonf T. Resolution of hypertension after adjustable gastric banding - 1 year interim results of the lap-band AP(registered trademark) experience (APEX) study. Journal of Clinical Hypertension. 2011;13(4):A150-A1.
115 Dixon JB, D ME, O'Brien PE. Quality of life after lap-band placement: influence of time, weight loss, and comorbidities. Obes Res. Nov. 2001;9(11):713-21. [pmid: 11707538].
116 Dixon JB, OB PE. Changes in comorbidities and improvements in quality of life after LAP-BAND placement. Am J Surg. Dec. 2002;184(6B):51S-4S. [pmid: 12527352].
117 Dixon JB, OB PE. Health outcomes of severely obese type 2 diabetic subjects 1 year after laparoscopic adjustable gastric banding. Diabetes Care. Feb. 2002;25(2):358-63. [pmid: 11815510].
118 Dixon JB, OB PE. Lipid profile in the severely obese: changes with weight loss after lap-band surgery. Obes Res. Sep. 2002;10(9):903-10. [pmid: 12226139].
119 Dixon JB, P WJ, O'Brien PE, Schauer PR, Zimmet P. Surgery as an effective early intervention for diabesity: why the reluctance?. Diabetes Care. Feb. 2005;28(2):472-4. [pmid: 15677819].
120 Doar JW, W CE, Thompson ME, Sewell PF. Influence of treatment with diet alone on oral glucose-tolerance test and plasma sugar and insulin levels in patients with maturity-onset diabetes mellitus. Lancet. Jun. 7. 1975;1(7919):1263-6. [pmid: 48896].
121 Dolan K, B R, Fielding G. Treating diabetes in the morbidly obese by laparoscopic gastric banding. Obes Surg. Jun. 2003;13(3):439-43. [pmid: 12841908].
122 Dowse GK, G H, Alberti KG, Zimmet P, Tuomilehto J, Purran A, Fareed D, Chitson P, Collins VR. Changes in population cholesterol concentrations and other cardiovascular risk factor levels after five years of the non-communicable disease intervention programme in Mauritius. Mauritius Non-communicable Disease Study Group. BMJ. Nov. 11. 1995;311(7015):1255-9. [pmid: 7496233].
123 Durbin RJ. Thiazolidinedione therapy in the prevention/delay of type 2 diabetes in patients with impaired glucose tolerance and insulin resistance. Diabetes Obes Metab. Jul. 2004;6(4):280-5. [pmid: 15171752].
124 Dyson PA, B S, Matthews DR. A low-carbohydrate diet is more effective in reducing body weight than healthy eating in both diabetic and non-diabetic subjects. Diabet Med. Dec. 2007;24(12):1430-5. [pmid: 17971178].
125 Eastman RC, J JC, Herman WH, Dasbach EJ, Copley-Merriman C, Maier W, Dong F, Manninen D, Zbrozek AS, Kotsanos J, Garfield SA, Harris M. Model of complications of NIDDM. II. Analysis of the health benefits and cost-effectiveness of treating NIDDM with the goal of normoglycemia. Diabetes Care. May. 1997;20(5):735-44. [pmid: 9135935].
126 Edelson PK, Dumon KR, Sonnad SS, et al. Robotic vs. conventional laparoscopic gastric banding: A comparison of 407 cases. Surgical Endoscopy and Other Interventional Techniques. 2011;25(5):1402-8. [pmid: 20976498].
127 Egan R, Higgs SM, Mason K, et al. Mmotility and weight loss after gastric banding is comparible between diabetics and thier non-diabetic counterparts at one year. Obesity Surgery. 2010;20(8):1045.
128 Elmore U, R A, Perrotta N, et al. Laparoscopic adjustable silicone gastric banding (LASGB) - analysis of 64 consecutive patients. Obes Surg. 1998;8:399. (abstract).
129 Encinosa WE, B DM, Chen CC, Steiner CA. Healthcare utilization and outcomes after bariatric surgery. Med Care. Aug. 2006;44(8):706-12. [pmid: 16862031].
130 Encinosa WE, B DM, Du D, Steiner CA. Recent improvements in bariatric surgery outcomes. Med Care. May. 2009;47(5):531-5. [pmid: 19318997].
131 Favretti F, S G, Ashton D, Busetto L, De Luca M, Mazza M, Ceoloni A, Banzato O, Calo E, Enzi G. Laparoscopic adjustable gastric banding in 1,791 consecutive obese patients: 12-year results. Obes Surg. Feb. 2007;17(2):168-75. [pmid: 17476867].
132 Fayez R, Court O, Christou N. Laparscopic adjustable gastric banding: Long term results and complications, a single center experiance. Surgical Endoscopy and Other Interventional Techniques. 2011;25:S257.
133 Fera T, B BM, Ellis WM, Schaller CW, Garrett DG. The Diabetes Ten City Challenge: interim clinical and humanistic outcomes of a multisite community pharmacy diabetes care program. J Am Pharm Assoc (2003). Mar-Apr. 2008;48(2):181-90. [pmid: 18359731].
134 Ferchak CV, M LF. Obesity, bariatric surgery and type 2 diabetes--a systematic review. Diabetes Metab Res Rev. Nov-Dec. 2004;20(6):438-45. [pmid: 15386803].
135 Fernandez AZ Jr., DeMaria EJ, Tichansky DS, Kellum JM, Wolfe LG, Meador J, Sugerman HJ. Experience with over 3,000 open and laparoscopic bariatric procedures: multivariate analysis of factors related to leak and resultant mortality. Surg Endosc. Feb. 2004;18(2):193-7. [pmid: 14691697].
136 Fica S, Sirbu A, Copaescu C, et al. Significant improvement in metabolic status 6 months after bariatric surgery. Diabetes Technology and Therapeutics. 2011;13(2):223-4.
137 Fielding GA, D Jennifer E. Laparoscopic adjustable gastric banding in severely obese adolescents. Surgery for Obesity and Related Diseases. 1(4):399-405. [pmid: 16925257].
138 Finer N, R DH, Renz CL, Hewkin AC. Prediction of response to sibutramine therapy in obese non-diabetic and diabetic patients. Diabetes Obes Metab. Mar. 2006;8(2):206-13. [pmid: 16448525].
139 Fleischman A, S SE, Bernier R, Goldfine AB. Salsalate improves glycemia and inflammatory parameters in obese young adults. Diabetes Care. Feb. 2008;31(2):289-94. [pmid: 17959861].
140 Flum DR, D EP. Impact of gastric bypass operation on survival: a population-based analysis. J Am Coll Surg. Oct. 2004;199(4):543-51. [pmid: 15454136].
141 Flum DR, S L, Elrod JA, Dellinger EP, Cheadle A, Chan L. Early mortality among Medicare beneficiaries undergoing bariatric surgical procedures. JAMA. Oct. 19. 2005;294(15):1903-8. [pmid: 16234496].
142 Fobi MA, L H, Igwe D Jr., Stanczyk M, Tambi JN. Prospective comparative evaluation of stapled versus transected silastic ring gastric bypass: 6-year follow-up. Obes Surg. Feb. 2001;11(1):18-24. [pmid: 11361162].
143 Fobi MA, L H. SILASTIC ring vertical banded gastric bypass for the treatment of obesity: two years of follow-up in 84 patients [corrected]. J Natl Med Assoc. Feb. 1994;86(2):125-8. [pmid: 8169987].
144 Fontbonne A, A P, Eschwege E. BIGPRO (biguanides and the prevention of the risk of obesity): study design. A randomized trial of metformin versus placebo in the correction of the metabolic abnormalities associated with insulin resistance. Diabete Metab. May. 1991;17(1 Pt 2):249-54. [pmid: 1936485].
145 Foster GD, B KE, Vander Veur SS, Leh Shantz K, Dilks RJ, Goldbacher EM, Oliver TL, Lagrotte CA, Homko C, Satz W. The effects of a commercially available weight loss program among obese patients with type 2 diabetes: a randomized study. Postgrad Med. Sep. 2009;121(5):113-8. [pmid: 19820280].
146 Foster GD, B Kelley E, Sanders Mark H, Millman Richard, Zammit Gary, Newman Anne B, Wadden Thomas A, Kelley David, Wing Rena R, Pi-Sunyer F Xavier, Reboussin David, Kuna Samuel T, for the Sleep AHEAD Research Group of the Look AHEAD Research Group. A Randomized Study on the Effect of Weight Loss on Obstructive Sleep Apnea Among Obese Patients With Type 2 Diabetes: The Sleep AHEAD Study. Arch Intern Med. September. 28. 2009. 2009;169(17):1619-26. [pmid: 19786682].
147 Foster GD, W HR, Hill JO, McGuckin BG, Brill C, Mohammed BS, Szapary PO, Rader DJ, Edman JS, Klein S. A randomized trial of a low-carbohydrate diet for obesity. N Engl J Med. May. 22. 2003;348(21):2082-90. [pmid: 12761365].
148 Fox SR, O KH, Fox K. Vertical Banded Gastroplasty and Distal Gastric Bypass as Primary Procedures: A Comparison. Obes Surg. Oct. 1996;6(5):421-5. [pmid: 10729888].
149 Fragasso GP, M PM, Monti L, Palloshi A, Setola E, Puccetti P, Calori G, Lopaschuk GD, Margonato A. Short- and long-term beneficial effects of trimetazidine in patients with diabetes and ischemic cardiomyopathy. Am Heart J. Nov. 2003;146(5):E18. [pmid: 14597947].
150 Frenken M, Cho EY. Four-year results after BPD-DS in patients with insulin-dependent type 2 diabetes mellitus. Obesity Surgery. 2010;20(8):980-1.
151 Freys SM, T H, Heimbucher J, Fuchs KH, Fein M, Thiede A. Quality of life following laparoscopic gastric banding in patients with morbid obesity. J Gastrointest Surg. Jul-Aug. 2001;5(4):401-7. [pmid: 11985982].
152 Frost G, D A. The relevance of the glycaemic index to our understanding of dietary carbohydrates. Diabet Med. May. 2000;17(5):336-45. [pmid: 10872531].
153 Frutos MD, L J, Hernandez Q, Valero G, Parrilla P. Results of laparoscopic gastric bypass in patients > or =55 years old. Obes Surg. Apr. 2006;16(4):461-4. [pmid: 16608611].
154 Furbetta F, G G, Robortella EM. 28-month experience with the lap-band technique: results and critical points of the method. Obes Surg. Feb. 1999;9(1):56-8. [pmid: 10065585].
155 Gaede PH, J PV, Larsen JN, Jensen GV, Parving HH, Pedersen OB. The Steno-2 study. Intensive multifactorial intervention reduces the occurrence of cardiovascular disease in patients with type 2 diabetes. Ugeskr Laeger. Jun. 23. 2003;165(26):2658-61. [pmid: 12886549].
156 Gaede P, V P, Larsen N, Jensen GV, Parving HH, Pedersen O. Multifactorial intervention and cardiovascular disease in patients with type 2 diabetes. N Engl J Med. Jan. 30. 2003;348(5):383-93. [pmid: 12556541].
157 Gan SSH, T Michael L, Jorgensen John O. EFFICACY OF SURGERY IN THE MANAGEMENT OF OBESITY-RELATED TYPE 2 DIABETES MELLITUS. ANZ Journal of Surgery. 2007;77(11):958-62. [pmid: 17931257].
158 Ganesh R, L T, Rao AD, Baladas HG. Laparoscopic adjustable gastric banding for severe obesity. Singapore Med J. Aug. 2006;47(8):661-9. [pmid: 16865204].
159 Gannon MC, N FQ, Saeed A, Jordan K, Hoover H. An increase in dietary protein improves the blood glucose response in persons with type 2 diabetes. Am J Clin Nutr. Oct. 2003;78(4):734-41. [pmid: 14522731].
160 Garcia-Fuentes E, G-A JM, Garcia-Arnes J, Rivas-Marin J, Gallego-Perales JL, Gonzalez-Jimenez B, Cardona I, Garcia-Serrano S, Garriga MJ, Gonzalo M, de Adana MS, Soriguer F. Morbidly obese individuals with impaired fasting glucose have a specific pattern of insulin secretion and sensitivity: effect of weight loss after bariatric surgery. Obes Surg. Sep. 2006;16(9):1179-88. [pmid: 16989702].
161 Garcia R, S R. Diabetes education in the elderly: a 5-year follow-up of an interactive approach. Patient Educ Couns. Oct. 1996;29(1):87-97. [pmid: 9006225].
162 Garciacaballero M, Martinez-Moreno JM, Mata JM, et al. Diabetes resolution in morbid and non morbid obese after one anastomosis gastric bypass. Obesity Surgery. 2010;20(8):1034.
163 Garg A, B JP, Henry RR, Coulston AM, Griver KA, Raatz SK, Brinkley L, Chen YD, Grundy SM, Huet BA, et al. Effects of varying carbohydrate content of diet in patients with non-insulin-dependent diabetes mellitus. JAMA. May. 11. 1994;271(18):1421-8. [pmid: 7848401].
164 Garrett DG, B BM. Patient self-management program for diabetes: first-year clinical, humanistic, and economic outcomes. J Am Pharm Assoc (2003). Mar-Apr. 2005;45(2):130-7. [pmid: 15868754].
165 Gautier JF, S A, Lefebvre PJ. Exercise in the management of non-insulin-dependent (type 2) diabetes mellitus. Int J Obes Relat Metab Disord. Oct. Suppl 4. 1995;19:S58-61. [pmid: 8581097].
166 Geloneze B, G SR, Fiori C, Stabe C, Tambascia MA, Chaim EA, Astiarraga BD, Pareja JC. Surgery for nonobese type 2 diabetic patients: an interventional study with duodenal-jejunal exclusion. Obes Surg. Aug. 2009;19(8):1077-83. [pmid: 19475464].
167 Genuth S. Supplemented fasting in the treatment of obesity and diabetes. Am J Clin Nutr. Dec. 1979;32(12):2579-86. [pmid: 506979].
168 Gerhard GT, A A, Meeuws K, McMurry MP, Duell PB, Connor WE. Effects of a low-fat diet compared with those of a high-monounsaturated fat diet on body weight, plasma lipids and lipoproteins, and glycemic control in type 2 diabetes. Am J Clin Nutr. Sep. 2004;80(3):668-73. [pmid: 15321807].
169 Ghiassi S, Morton J, Bellatorre N, et al. Short-term medication cost savings for treating hypertension and diabetes after gastric bypass. Surg Obes Relat Dis. 2011. May. 27. [pmid: 21723203].
170 Gill RS, Birch DW, Shi X, et al. Sleeve gastrectomy and type 2 diabetes mellitus: A systematic review. Canadian Journal of Diabetes. 2011;35(2):150.
171 Glasgow RE, N CC, Kearney KA, Reid R, Ritzwoller DP, Strecher VJ, Couper MP, Green B, Wildenhaus K. Reach, engagement, and retention in an Internet-based weight loss program in a multi-site randomized controlled trial. J Med Internet Res. 2007;9(2):e11. [pmid: 17513282].
172 Gleysteen JJ. Results of surgery: long-term effects on hyperlipidemia. Am J Clin Nutr. Feb. 1992;55(2 Suppl):591S-3S. [pmid: 1733134].
173 Gleysteen JJ, B JJ, Sasse EA. Sustained coronary-risk-factor reduction after gastric bypass for morbid obesity. Am J Clin Nutr. May. 1990;51(5):774-8. [pmid: 2333834].
174 Gokcel A, K H, Ertorer EM, Tanaci N, Tutuncu NB, Guvener N. Effects of sibutramine in obese female subjects with type 2 diabetes and poor blood glucose control. Diabetes Care. Nov. 2001;24(11):1957-60. [pmid: 11679464].
175 Gonzalez R, L E, Mattar SG, Venkatesh KR, Smith CD. Gastric bypass for morbid obesity in patients 50 years or older: is laparoscopic technique safer?. Am Surg. Jul. 2003;69(7):547-53. discussion 53-4. [pmid: 12889614].
176 Gorin AA, N HM, Hogan P, Coday M, Davis C, DiLillo VG, Gluck ME, Wadden TA, West DS, Williamson D, Yanovski SZ. Binge eating and weight loss outcomes in overweight and obese individuals with type 2 diabetes: results from the Look AHEAD trial. Arch Gen Psychiatry. Dec. 2008;65(12):1447-55. [pmid: 19047532].
177 Gray A, R M, McGuire A, Fenn P, Stevens R, Cull C, Stratton I, Adler A, Holman R, Turner R. Cost effectiveness of an intensive blood glucose control policy in patients with type 2 diabetes: economic analysis alongside randomised controlled trial (UKPDS 41). United Kingdom Prospective Diabetes Study Group. BMJ. May. 20. 2000;320(7246):1373-8. [pmid: 10818026].
178 Gray DS, F K, Devine W, Bray GA. A randomized double-blind clinical trial of fluoxetine in obese diabetics. Int J Obes Relat Metab Disord. Dec. Suppl 4. 1992;16:S67-72. [pmid: 1338389].
179 Grey M, B D, Davidson M, Galasso P, Gustafson E, Melkus G. Preliminary testing of a program to prevent type 2 diabetes among high-risk youth. J Sch Health. Jan. 2004;74(1):10-5. [pmid: 15022370].
180 Grunberger G, J KL, Artiss JD. The benefits of early intervention in obese diabetic patients with FBCx: a new dietary fibre. Diabetes Metab Res Rev. Jan. 2007;23(1):56-62. [pmid: 17013969].
181 Guidone C, M M, Valera-Mora E, Iaconelli A, Gniuli D, Mari A, Nanni G, Castagneto M, Calvani M, Mingrone G. Mechanisms of recovery from type 2 diabetes after malabsorptive bariatric surgery. Diabetes. Jul. 2006;55(7):2025-31. [pmid: 16804072].
182 Gumbiner B, L CC, Reaven PD. Effects of a monounsaturated fatty acid-enriched hypocaloric diet on cardiovascular risk factors in obese patients with type 2 diabetes. Diabetes Care. Jan. 1998;21(1):9-15. [pmid: 9538963].
183 Gumbiner B, W JA, McDermott MP. Effects of diet composition and ketosis on glycemia during very-low-energy-diet therapy in obese patients with non-insulin-dependent diabetes mellitus. Am J Clin Nutr. Jan. 1996;63(1):110-5. [pmid: 8604657].
184 Gupta AK, B George A, Greenway Frank L, Martin Corby K, Johnson William D, Smith Steven R. Pioglitazone, but not metformin, reduces liver fat in Type-2 diabetes mellitus independent of weight changes. Journal of Diabetes and its Complications. In Press, Corrected Proof.
185 Hamilton EC, S TL, Hamilton TT, Mullican MA, Jones DB, Provost DA. Clinical predictors of leak after laparoscopic Roux-en-Y gastric bypass for morbid obesity. Surg Endosc. May. 2003;17(5):679-84. [pmid: 12618940].
186 Han SH, G C, Mehran A, Basa N, Hines J, Suleman L, Vira D, Dutson E. Improved outcomes using a systematic and evidence-based approach to the laparoscopic Roux-en-Y gastric bypass in a single academic institution. Am Surg. Oct. 2007;73(10):955-8. [pmid: 17983055].
187 Harland J, W M, Drinkwater C, Chinn D, Farr L, Howel D. The Newcastle exercise project: a randomised controlled trial of methods to promote physical activity in primary care. BMJ. Sep. 25. 1999;319(7213):828-32. [pmid: 10496829].
187 Hartweg J, P R, Montori V, Dinneen S, Neil HA, Farmer A. Omega-3 polyunsaturated fatty acids (PUFA) for type 2 diabetes mellitus. Cochrane Database Syst Rev. 2008;(1):CD003205. [pmid: 18254017].
189 Havas S. The ACCORD Trial and control of blood glucose level in type 2 diabetes mellitus: time to challenge conventional wisdom. Arch Intern Med. Jan. 26. 2009;169(2):150-4. [pmid: 19171811].
190 Hayes C, K A. Role of physical activity in diabetes management and prevention. J Am Diet Assoc. Apr. 2008;108(4 Suppl 1):S19-23. [pmid: 18358249].
191 Hell E, M KA, Moorehead MK, Norman S. Evaluation of health status and quality of life after bariatric surgery: comparison of standard Roux-en-Y gastric bypass, vertical banded gastroplasty and laparoscopic adjustable silicone gastric banding. Obes Surg. Jun. 2000;10(3):214-9. [pmid: 10929151].
192 Henness S. Pharmacological interventions in the prevention of type 2 diabetes. Curr Opin Endocrinol Diabetes Obes. Apr. 2007;14(2):166-9. [pmid: 17940436].
193 Henry RR, S L, Olefsky JM. Glycemic effects of intensive caloric restriction and isocaloric refeeding in noninsulin-dependent diabetes mellitus. J Clin Endocrinol Metab. Nov. 1985;61(5):917-25. [pmid: 4044780].
194 Herman WH, H TJ, Brandle M, Hicks K, Sorensen S, Zhang P, Hamman RF, Ackermann RT, Engelgau MM, Ratner RE. The cost-effectiveness of lifestyle modification or metformin in preventing type 2 diabetes in adults with impaired glucose tolerance. Ann Intern Med. Mar. 1. 2005;142(5):323-32. [pmid: 15738451].
195 Hermann LS, S B, Melander A. Antihyperglycaemic efficacy, response prediction and dose-response relations of treatment with metformin and sulphonylurea, alone and in primary combination. Diabet Med. Dec. 1994;11(10):953-60. [pmid: 7895460].
196 Hertzman P. The cost effectiveness of orlistat in a 1-year weight-management programme for treating overweight and obese patients in Sweden : a treatment responder approach. Pharmacoeconomics. 2005;23(10):1007-20. [pmid: 16235974].
197 Heymsfield SB, S KR, Hauptman J, Lucas CP, Boldrin MN, Rissanen A, Wilding JP, Sjostrom L. Effects of weight loss with orlistat on glucose tolerance and progression to type 2 diabetes in obese adults. Arch Intern Med. May. 8. 2000;160(9):1321-6. [pmid: 10809036].
198 Higa KD, B KB, Ho T. Complications of the laparoscopic Roux-en-Y gastric bypass: 1,040 patients--what have we learned?. Obes Surg. Dec. 2000;10(6):509-13. [pmid: 11175957].
199 Himpens J, Dobbeleir J, Peeters G. Long-term results of laparoscopic sleeve gastrectomy for obesity. Ann Surg. Aug. 2010;252(2):319-24. [pmid: 20622654].
200 Himpens J, D G, Cadiere GB. A prospective randomized study between laparoscopic gastric banding and laparoscopic isolated sleeve gastrectomy: results after 1 and 3 years. Obes Surg. Nov. 2006;16(11):1450-6. [pmid: 17132410].
201 Hofstetter AM, Kerr JL. Bariatric surgery for the treatment of type 2 diabetes mellitus: What are the Options?. U.S. Pharmacist. 2011;36(5).
202 Huisman S, dG V, Maes S, Schroevers M, Chatrou M, Haak H. Self-regulation and weight reduction in patients with type 2 diabetes: a pilot intervention study. Patient Educ Couns. Apr. 2009;75(1):84-90. [pmid: 19097740].
203 Hutter MM, R S, Khuri SF, Henderson WG, Abbott WM, Warshaw AL. Laparoscopic versus open gastric bypass for morbid obesity: a multicenter, prospective, risk-adjusted analysis from the National Surgical Quality Improvement Program. Ann Surg. May. 2006;243(5):657-62. discussion 62-6. [pmid: 16633001].
204 Iannelli A, Anty R, Schneck AS, et al. Inflammation, insulin resistance, lipid disturbances, anthropometrics, and metabolic syndrome in morbidly obese patients: a case control study comparing laparoscopic Roux-en-Y gastric bypass and laparoscopic sleeve gastrectomy. Surgery. Mar. 2011;149(3):364-70. [pmid: 20932542].
205 Inge T, Jenkins T, Dolan L, et al. Improved insulin sensitivity and decreased insulin secretion in adolescents undergoing gastric bypass. Journal of Laparoendoscopic and Advanced Surgical Techniques. 2011;21(4):A14-A5.
206 Iordache N, V R, Iorgulescu A, Zmeu B, Iordache M. Laparoscopic adjustable gastric-banding treatment for morbid obesity our first year experience. Chirurgia (Bucur). Mar-Apr. 2003;98(2):135-42. [pmid: 14992134].
207 James Hanowell E, Pallati PK, Srinivasan A, et al. Laparoscopic versus open bilio-pancreatic diversion with duodenal switch: Comparable weight loss with decreased long term morbidity. Surgical Endoscopy and Other Interventional Techniques. 2011;25:S250.
208 Jones KB Jr., Afram JD, Benotti PN, Capella RF, Cooper CG, Flanagan L, Hendrick S, Howell LM, Jaroch MT, Kole K, Lirio OC, Sapala JA, Schuhknecht MP, Shapiro RP, Sweet WA, Wood MH. Open versus laparoscopic Roux-en-Y gastric bypass: a comparative study of over 25,000 open cases and the major laparoscopic bariatric reported series. Obes Surg. Jun. 2006;16(6):721-7. [pmid: 16756731].
209 Jootun N, Filgate R, Munro W, et al. Reversal of metabolic syndrome by laparoscopic gastric banding in patients with type 2 diabetes. Internal Medicine Journal. 2010;40:178.
210 Kalfarentzos F, D A, Kehagias I, Loukidi A, Mead N. Vertical banded gastroplasty versus standard or distal Roux-en-Y gastric bypass based on specific selection criteria in the morbidly obese: preliminary results. Obes Surg. Oct. 1999;9(5):433-42. [pmid: 10605899].
211 Kalinowski P, Paluszkiewicz R, Remiszewski P, et al. Effect of Roux-en-Y gastric bypass on metabolic syndrome. Obesity Surgery. 2010;20(8):1010-1.
212 Karastergiou K, K JC. Medical management of the diabetic patient with coronary artery disease. Curr Pharm Des. 2008;14(25):2527-36. [pmid: 18991670].
213 Karlsson J, S L, Sullivan M. Swedish obese subjects (SOS)--an intervention study of obesity. Two-year follow-up of health-related quality of life (HRQL) and eating behavior after gastric surgery for severe obesity. Int J Obes Relat Metab Disord. Feb. 1998;22(2):113-26. [pmid: 9504319].
214 Karter AJ, M HH, Liu J, Parker MM, Ahmed AT, Go AS, Selby JV. Glycemic response to newly initiated diabetes therapies. Am J Manag Care. Nov. 2007;13(11):598-606. [pmid: 17988185].
215 Kasalicky M, Pohnan R, Haluzikova D, et al. Influence of the laparoscopic sleeve gastrectomy on the metabolic syndrome. Obesity Surgery. 2010;20(6):815-6.
216 Kasalicky M, Pohnan R, Housova J, et al. Effect of the laparoscopic sleeve gastrectomy - 4 years experience. Surgical Endoscopy and Other Interventional Techniques. 2011;25:S123.
217 Kaukua JK, P TA, Rissanen AM. Health-related quality of life in a randomised placebo-controlled trial of sibutramine in obese patients with type II diabetes. Int J Obes Relat Metab Disord. Apr. 2004;28(4):600-5. [pmid: 14770192].
218 Keating C, Dixon J, Moodie M, et al. Cost-effectiveness of surgically induced weight loss for the management of type 2 diabetes: Modelled lifetime analysis. Obesity Reviews. 2010;11:45.
219 Keech A, C D, Best J, Kirby A, Simes RJ, Hunt D, Hague W, Beller E, Arulchelvam M, Baker J, Tonkin A. Secondary prevention of cardiovascular events with long-term pravastatin in patients with diabetes or impaired fasting glucose: results from the LIPID trial. Diabetes Care. Oct. 2003;26(10):2713-21. [pmid: 14514569].
220 Keidar A, Hershkop K, Schweiger C, et al. Preliminary results of prospective randomized controlled study of the effect of laparoscopic sleeve gastrectomy versus laparoscopic Roux-en-Y gastric bypass on resolution of type 2 diabetes mellitus. Obesity Surgery. 2010;20(6):810.
221 Kelley DE. Action for health in diabetes: the look AHEAD clinical trial. Curr Diab Rep. Jun. 2002;2(3):207-9. [pmid: 12643174].
222 Kelley DE, B GA, Pi-Sunyer FX, Klein S, Hill J, Miles J, Hollander P. Clinical efficacy of orlistat therapy in overweight and obese patients with insulin-treated type 2 diabetes: A 1-year randomized controlled trial. Diabetes Care. Jun. 2002;25(6):1033-41. [pmid: 12032111].
223 Kelly TM, J SB. Changes in serum lipids after gastric bypass surgery. Lack of a relationship to weight loss. Int J Obes. 1986;10(6):443-52. [pmid: 3804561].
224 Keyserling TC, A AS, Samuel-Hodge CD, Ingram AF, Skelly AH, Elasy TA, Johnston LF, Cole AS, Henriquez-Roldan CF. A diabetes management program for African American women with type 2 diabetes. Diabetes Educ. Sep-Oct. 2000;26(5):796-805. [pmid: 11140007].
225 Khan MA, SP JV, Breen GA, Hartley GG, Vessey JT. Diabetes disease stage predicts weight loss outcomes with long-term appetite suppressants. Obes Res. Jan. 2000;8(1):43-8. [pmid: 10678258].
226 Kim D, M L, Zhuang D, Kothare PA, Trautmann M, Fineman M, Taylor K. Effects of once-weekly dosing of a long-acting release formulation of exenatide on glucose control and body weight in subjects with type 2 diabetes. Diabetes Care. Jun. 2007;30(6):1487-93. [pmid: 17353504].
227 Kim S, Richards WO. Long-term follow-up of the metabolic profiles in obese patients with type 2 diabetes mellitus after Roux-en-Y gastric bypass. Ann Surg. Jun. 2010;251(6):1049-55. [pmid: 20485144].
228 Kim Z, Hur KY. Laparoscopic mini-gastric bypass for type 2 diabetes: the preliminary report. World J Surg. Mar. 2011;35(3):631-6. [pmid: 21165621].
229 Kiong KL, Ganesh R, Cheng AK, et al. Early improvement in type 2 diabetes mellitus post Roux-en-Y gastric bypass in Asian patients. Singapore Med J. Dec. 2010;51(12):937-43. [pmid: 21221498].
230 Klein S, S NF, Pi-Sunyer X, Daly A, Wylie-Rosett J, Kulkarni K, Clark NG. Weight management through lifestyle modification for the prevention and management of type 2 diabetes: rationale and strategies: a statement of the American Diabetes Association, the North American Association for the Study of Obesity, and the American Society for Clinical Nutrition. Diabetes Care. Aug. 2004;27(8):2067-73. [pmid: 15277443].
231 Knowler WC, N KM, Hanson RL, Nelson RG, Bennett PH, Tuomilehto J, Schersten B, Pettitt DJ. Preventing non-insulin-dependent diabetes. Diabetes. May. 1995;44(5):483-8. [pmid: 7729603].
232 Knowler WC, S G, Melander A, Schersten B. Glucose tolerance and mortality, including a substudy of tolbutamide treatment. Diabetologia. Jun. 1997;40(6):680-6. [pmid: 9222648].
233 Korenkov M, S S, Sauerland S, Duenschede F, Junginger Th. Impact of Laparoscopic Adjustable Gastric Banding on Obesity Co-morbidities in the Medium- and Long-Term. Obesity Surgery. 2007;17(5):679-83. [pmid: 17658030].
234 Korner J, I W, Conwell IM, Taveras C, Daud A, Olivero-Rivera L, Restuccia NL, Bessler M. Differential effects of gastric bypass and banding on circulating gut hormone and leptin levels. Obesity (Silver Spring). Sep. 2006;14(9):1553-61. [pmid: 17030966].
235 Kothari SN, D EJ, Sugerman HJ, Kellum JM, Meador J, Wolfe L. Lap-band failures: conversion to gastric bypass and their preliminary outcomes. Surgery. Jun. 2002;131(6):625-9. [pmid: 12075174].
236 Kramer MK, M R, Venditti E, Orchard T. Group Lifestyle Intervention for Diabetes Prevention in those with Metabolic Syndrome in Primary Care Practice. Diabetes Care. 2006;55((suppl.)):A517.
237 Kriska AM, B SN, Pereira MA. The potential role of physical activity in the prevention of non-insulin-dependent diabetes mellitus: the epidemiological evidence. Exerc Sport Sci Rev. 1994;22:121-43. [pmid: 7925541].
238 Kushner RF, S Melissa. Prevention of Weight Gain in Adult Patients With Type 2 Diabetes Treated With Pioglitazone. Obesity. 2009;17(5):1017-22. [pmid: 19180065].
239 Kuzmak LI, Y IS, McGuire L, Dixon JS, Young MP. Surgery for morbid obesity. Using an inflatable gastric band. AORN J. May. 1990;51(5):1307-24. [pmid: 2344182].
240 La Londe MA, G CL, Falko JM, Snow RJ, Spencer K, Caulin-Glaser T. Effect of a weight management program on the determinants and prevalence of metabolic syndrome. Obesity (Silver Spring). Mar. 2008;16(3):637-42. [pmid: 18239562].
241 Lacey LA, W A, O'Shea D, Erny S, Ruof J. Cost-effectiveness of orlistat for the treatment of overweight and obese patients in Ireland. Int J Obes (Lond). Aug. 2005;29(8):975-82. [pmid: 15852050].
242 Laferrere B, Reilly D, Arias S, et al. Differential metabolic impact of gastric bypass surgery versus dietary intervention in obese diabetic subjects despite identical weight loss. Sci Transl Med. Apr. 27. 2011;3(80):80re2. [pmid: 21525399].
243 Laferrere B, T J, McGinty J, Tran H, Egger JR, Colarusso A, Kovack B, Bawa B, Koshy N, Lee H, Yapp K, Olivan B. Effect of weight loss by gastric bypass surgery versus hypocaloric diet on glucose and incretin levels in patients with type 2 diabetes. J Clin Endocrinol Metab. Jul. 2008;93(7):2479-85. [pmid: 18430778].
244 Lakka TA, L DE. Physical activity in prevention and treatment of the metabolic syndrome. Appl Physiol Nutr Metab. Feb. 2007;32(1):76-88. [pmid: 17332786].
245 Lancaster RT, H MM. Bands and bypasses: 30-day morbidity and mortality of bariatric surgical procedures as assessed by prospective, multi-center, risk-adjusted ACS-NSQIP data. Surg Endosc. Dec. 2008;22(12):2554-63. [pmid: 18806945].
246 Lankisch M, L P, Rizza RA, DiMagno EP. Acute postprandial gastrointestinal and metabolic effects of wheat amylase inhibitor (WAI) in normal, obese, and diabetic humans. Pancreas. Aug. 1998;17(2):176-81. [pmid: 9700950].
247 Lau DCW. Is surgery an option in the treatment of type 2 diabetes?. Canadian Journal of Diabetes. 2011;35(2):85-6.
248 Lee A, M JE. Metformin decreases food consumption and induces weight loss in subjects with obesity with type II non-insulin-dependent diabetes. Obes Res. Jan. 1998;6(1):47-53. [pmid: 9526970].
249 Lee HJ, P KY. Body weight, cardiovascular risk factors, and self-efficacy of diabetic control among obese type II diabetic patients. Taehan Kanho Hakhoe Chi. Aug. 2005;35(5):787-97. [pmid: 16208074].
250 Lee WJ, H MT, Wang W, Lin CM, Chen TC, Lai IR. Effects of obesity surgery on the metabolic syndrome. Arch Surg. Oct. 2004;139(10):1088-92. [pmid: 15492149].
251 Lee WJ, L IR, Huang MT, et al. Laparoscopic versus open vertical banded gastroplasty for the treatment of morbid obesity. Surg Laparosc Endosc Percut Techn. 2001;11:9-13.
252 Lee WJ, W W. Bariatric surgery: Asia-Pacific perspective. Obes Surg. Jun-Jul. 2005;15(6):751-7. [pmid: 15978141].
253 Lee WJ, W W, Wei PL, Huang MT. Weight loss and improvement of obesity-related illness following laparoscopic adjustable gastric banding procedure for morbidly obese patients in Taiwan. J Formos Med Assoc. Nov. 2006;105(11):887-94. [pmid: 17098690].
254 Leichman JG, A D, King TM, Mehta S, Majka C, Scarborough T, Wilson EB, Taegtmeyer H. Improvements in systemic metabolism, anthropometrics, and left ventricular geometry 3 months after bariatric surgery. Surg Obes Relat Dis. Nov-Dec. 2006;2(6):592-9. [pmid: 17138229].
255 Levy P, F M, Santini F, Finer N. The comparative effects of bariatric surgery on weight and type 2 diabetes. Obes Surg. Sep. 2007;17(9):1248-56. [pmid: 18074502].
256 Li YX. Role of gastric surgery in treating obese patients with type 2 diabetes. Zhongguo Yi Xue Ke Xue Yuan Xue Bao. Feb. 2010;32(1):13-5. [pmid: 20236580].
257 Lim P, K OT. Metformin compared with tolbutamide in the treatment of maturity-onset diabetes mellitus. Med J Aust. Feb. 7. 1970;1(6):271-3. [pmid: 5440868].
258 Livingston EH, H S, Arthur D, Lee S, De Shields S, Heber D. Male gender is a predictor of morbidity and age a predictor of mortality for patients undergoing gastric bypass surgery. Ann Surg. Nov. 2002;236(5):576-82. [pmid: 12409663].
259 Lonroth H, D J, Haglind E, Josefsson K, Olbe L, Fagevik Olsen M, Lundell L. Vertical banded gastroplasty by laparoscopic technique in the treatment of morbid obesity. Surg Laparosc Endosc. Apr. 1996;6(2):102-7. [pmid: 8680631].
260 Look AHEAD Research Group. Reduction in Weight and Cardiovascular Disease Risk Factors in Individuals With Type 2 Diabetes. Diabetes Care. June. 2007. 2007;30(6):1374-83. [pmid: 17363746].
261 Low CC, G EB, Gumbiner B. Potentiation of effects of weight loss by monounsaturated fatty acids in obese NIDDM patients. Diabetes. May. 1996;45(5):569-75. [pmid: 8621005].
262 Lujan JA, F MD, Hernandez Q, Liron R, Cuenca JR, Valero G, Parrilla P. Laparoscopic versus open gastric bypass in the treatment of morbid obesity: a randomized prospective study. Ann Surg. Apr. 2004;239(4):433-7. [pmid: 15024302].
263 Ma J, K Abby, Wilson Sandra, Xiao Lan, Stafford Randall. Evaluation of lifestyle interventions to treat elevated cardiometabolic risk in primary care (E-LITE): a randomized controlled trial. BMC Family Practice. 2009;10(1):71. [doi: 10.1186/1471-2296-10-71]. [pmid: 19909549].
264 Ma Y, O BC, Merriam PA, Chiriboga DE, Culver AL, Li W, Hebert JR, Ockene IS, Griffith JA, Pagoto SL. A randomized clinical trial comparing low-glycemic index versus ADA dietary education among individuals with type 2 diabetes. Nutrition. Jan. 2008;24(1):45-56. [pmid: 18070658].
265 MacDonald KG Jr., Long SD, Swanson MS, Brown BM, Morris P, Dohm GL, Pories WJ. The gastric bypass operation reduces the progression and mortality of non-insulin-dependent diabetes mellitus. J Gastrointest Surg. May-Jun. 1997;1(3):213-20. discussion 20. [pmid: 9834350].
266 Macgregor AM, R CS. Gastric surgery in morbid obesity. Outcome in patients aged 55 years and older. Arch Surg. Oct. 1993;128(10):1153-7. [pmid: 8215875].
267 Maciejewski ML, Livingston EH, Kahwati LC, et al. Discontinuation of diabetes and lipid-lowering medications after bariatric surgery at Veterans Affairs medical centers. Surg Obes Relat Dis. Nov-Dec. 2010;6(6):601-7. [pmid: 20965791].
268 MacLean LD, R BM, Nohr CW. Late outcome of isolated gastric bypass. Ann Surg. Apr. 2000;231(4):524-8. [pmid: 10749613].
269 Madan AK, O W, Ternovits CA, Tichansky DS. Metabolic syndrome: yet another co-morbidity gastric bypass helps cure. Surg Obes Relat Dis. Jan-Feb. 2006;2(1):48-51. discussion. [pmid: 16925317].
270 Madan AK, W JD, Fain JN, Beech BM, Ternovits CA, Menachery S, Tichansky DS. Are African-Americans as successful as Caucasians after laparoscopic gastric bypass?. Obes Surg. Apr. 2007;17(4):460-4. [pmid: 17608257].
271 Maetzel A, R J, Covington M, Wolf A. Economic evaluation of orlistat in overweight and obese patients with type 2 diabetes mellitus. Pharmacoeconomics. 2003;21(7):501-12. [pmid: 12696990].
272 Maggio CA, P-S FX. The prevention and treatment of obesity. Application to type 2 diabetes. Diabetes Care. Nov. 1997;20(11):1744-66. [pmid: 9353619].
273 Makary MA, Clarke JM, Shore AD, et al. Medication utilization and annual health care costs in patients with type 2 diabetes mellitus before and after bariatric surgery. Arch Surg. Aug. 2010;145(8):726-31. [pmid: 20713923].
274 Marceau P, H FS, Simard S, Lebel S, Bourque RA, Potvin M, Biron S. Biliopancreatic diversion with duodenal switch. World J Surg. Sep. 1998;22(9):947-54. [pmid: 9717420].
275 Marinari GM, P FS, Briatore L, Adami G, Scopinaro N. Type 2 diabetes and weight loss following biliopancreatic diversion for obesity. Obes Surg. Nov. 2006;16(11):1440-4. [pmid: 17132408].
276 Marjanovic G, Winkler K, Schewe T, et al. Metabolic surgery and remission of type 2 diabetes. Dtsch Med Wochenschr. May. 2010;135(20):1020-4. [pmid: 20461659].
277 Mason EE, P KJ, Blommers TJ, Scott DH. Gastric bypass for obesity after ten years experience. Int J Obes. 1978;2(2):197-206. [pmid: 711364].
278 Masoudi FA, I SE, Wang Y, Havranek EP, Foody JM, Krumholz HM. Thiazolidinediones, metformin, and outcomes in older patients with diabetes and heart failure: an observational study. Circulation. Feb. 8. 2005;111(5):583-90. [pmid: 15699279].
279 Mathus-Vliegen EM. Long-term health and psychosocial outcomes from surgically induced weight loss: results obtained in patients not attending protocolled follow-up visits. Int J Obes (Lond). Feb. 2007;31(2):299-307. [pmid: 16755282].
280 Mattar SG, V LM, Rabinovitz M, Demetris AJ, Krasinskas AM, Barinas-Mitchell E, Eid GM, Ramanathan R, Taylor DS, Schauer PR. Surgically-induced weight loss significantly improves nonalcoholic fatty liver disease and the metabolic syndrome. Ann Surg. Oct. 2005;242(4):610-7. discussion 8-20. [pmid: 16192822].
281 Matvienko OA, H James D. A Lifestyle Intervention Study in Patients with Diabetes or Impaired Glucose Tolerance: Translation of a Research Intervention into Practice. J Am Board Fam Med. September. 1. 2009. 2009;22(5):535-43. [pmid: 19734400].
282 Mayer-Davis EJ, DA A, Martin M, Wandersman A, Parra-Medina D, Schulz R. Pilot study of strategies for effective weight management in type 2 diabetes: Pounds Off with Empowerment (POWER). Fam Community Health. Jul. 2001;24(2):27-35. [pmid: 11373164].
283 Mayer-Davis EJ, DA AM, Smith SM, Kirkner G, Levin Martin S, Parra-Medina D, Schultz R. Pounds off with empowerment (POWER): a clinical trial of weight management strategies for black and white adults with diabetes who live in medically underserved rural communities. Am J Public Health. Oct. 2004;94(10):1736-42. [pmid: 15451743].
284 McAuley KA, H CM, Smith KJ, McLay RT, Williams SM, Taylor RW, Mann JI. Comparison of high-fat and high-protein diets with a high-carbohydrate diet in insulin-resistant obese women. Diabetologia. Jan. 2005;48(1):8-16. [pmid: 15616799].
285 McNabb WL, Q MT, Rosing L. Weight loss program for inner-city black women with non-insulin-dependent diabetes mellitus: PATHWAYS. J Am Diet Assoc. Jan. 1993;93(1):75-7. [pmid: 8417099].
286 McNeely W, G KL. Sibutramine. A review of its contribution to the management of obesity. Drugs. Dec. 1998;56(6):1093-124. [pmid: 9878996].
287 McNulty SJ, U E, Williams G. A randomized trial of sibutramine in the management of obese type 2 diabetic patients treated with metformin. Diabetes Care. Jan. 2003;26(1):125-31. [pmid: 12502668].
288 McTigue KM, C Molly B, Bigi Lori, Murphy Cynthia, McNeil Melissa. Weight Loss Through Living Well: Translating an Effective Lifestyle Intervention Into Clinical Practice. The Diabetes Educator. March. 1. 2009. 2009;35(2):199-208. [pmid: 19321806].
289 McTigue KM, H R, Ziouras J. Obesity in older adults: a systematic review of the evidence for diagnosis and treatment. Obesity (Silver Spring). Sep. 2006;14(9):1485-97. [pmid: 17030958].
290 Meece J. Pancreatic islet dysfunction in type 2 diabetes: a rational target for incretin-based therapies. Curr Med Res Opin. Apr. 2007;23(4):933-44. [pmid: 17407650].
291 Meijer RI, van Wagensveld BA, Siegert CE, et al. Bariatric surgery as a novel treatment for type 2 diabetes mellitus: a systematic review. Arch Surg. Jun. 2011;146(6):744-50. [pmid: 21690453].
292 Meneghini LF, F CV. Obesity, bariatric surgery and type 2 diabetes - a systematic review. Diabetes/Metabolism Research and Reviews. 2004;20(6):438-45. [pmid: 15386803].
293 Meshcheriakova VA, P OA, Sharafetdinov KhKh, Iatsyshina TA. The use of the combined food products with soy protein in diet therapy for patients with diabetes mellitus type 2. Vopr Pitan. 2002;71(5):19-24. [pmid: 12599994].
294 Meyer L, R S, Becker J, Pradignac A, Meyer C, Schlienger JL, Simon C. Retrospective study of laparoscopic adjustable silicone gastric banding for the treatment of morbid obesity: results and complications in 127 patients. Diabetes Metab. Feb. 2004;30(1):53-60. [pmid: 15029098].
295 Mijailovic V, M D, Mijailovic M. Effects of a one-year weight reduction program and physical activity on obesity and comorbid conditions. Med Pregl. Jan-Feb. 2004;57(1-2):55-9. [pmid: 15327191].
296 Miles JM, L L, Hollander P, Wadden T, Anderson JW, Doyle M, Foreyt J, Aronne L, Klein S. Effect of orlistat in overweight and obese patients with type 2 diabetes treated with metformin. Diabetes Care. Jul. 2002;25(7):1123-8. [pmid: 12087008].
297 Miller K, M E, Pichler M, Hell E. Quality-of-life outcomes of patients with the Lap-Band registered versus non-operative treatment of obesity. Preliminary results of an ongoing long-term follow-up study. Obes Surg. 1997;7:280.
298 Miller YD, D DW. The effectiveness of physical activity interventions for the treatment of overweight and obesity and type 2 diabetes. J Sci Med Sport. Apr. 2004;7(1 Suppl):52-9. [pmid: 15214602].
299 Mingrone G, DeGaetano A, Greco AV, et al. Reversibility of insulin resistance in obese diabetic patients: role of plasma lipids. Diabetologia. May. 1997;40(5):599-605. [pmid: 9165230].
300 Mittermair RP, W H, Nehoda H, Kirchmayr W, Aigner F. Laparoscopic Swedish adjustable gastric banding: 6-year follow-up and comparison to other laparoscopic bariatric procedures. Obes Surg. Jun. 2003;13(3):412-7. [pmid: 12841903].
301 Mohos E, Schmaldienst E, Prager M. Quality of life parameters, weight change and improvement of co-morbidities after laparoscopic Roux Y gastric bypass and laparoscopic gastric sleeve resection--comparative study. Obes Surg. Mar. 2011;21(3):288-94. [pmid: 20628831].
302 Moo TA, R F. Gastrointestinal surgery as treatment for type 2 diabetes. Curr Opin Endocrinol Diabetes Obes. Apr. 2008;15(2):153-8. [pmid: 18316951].
303 Morinigo R, C R, Delgado S, Lacy A, Deulofeu R, Conget I, Barcelo-Batllori S, Gomis R, Vidal J. Insulin resistance, inflammation, and the metabolic syndrome following Roux-en-Y gastric bypass surgery in severely obese subjects. Diabetes Care. Jul. 2007;30(7):1906-8. [pmid: 17468354].
304 Morinigo R, V J, Lacy AM, Delgado S, Casamitjana R, Gomis R. Circulating peptide YY, weight loss, and glucose homeostasis after gastric bypass surgery in morbidly obese subjects. Ann Surg. Feb. 2008;247(2):270-5. [pmid: 18216532].
305 Morino M, T M, Forestieri P, Angrisani L, Allaix ME, Scopinaro N. Mortality after bariatric surgery: analysis of 13,871 morbidly obese patients from a national registry. Ann Surg. Dec. 2007;246(6):1002-7. discussion 7-9. [pmid: 18043102].
306 Morris JH, W DA, Bolinger RE. Effect of Oral Sulfonylurea on Plasma Triglycerides in Diabetics. Diabetes. Jan-Feb. 1964;13:87-9. [pmid: 14104182].
307 Morris M, Jackson S, Johnson AB. Reality bites! Experiences of one year Post-Laparoscopic Gastric Banding (LAGB) for people with and without type 2 diabetes. Diabetic Medicine. 2010;27(2):2-3.
308 Mumme DE, Mathiason MA, Kallies KJ, et al. Effect of laparoscopic Roux-en-Y gastric bypass surgery on hemoglobin A1c levels in diabetic patients: a matched-cohort analysis. Surg Obes Relat Dis. Jan-Feb. 2009;5(1):4-10. [pmid: 19161932].
309 Murr MM, S MR, Sarr MG. Results of Bariatric Surgery for Morbid Obesity in Patients Older than 50 Years. Obes Surg. Nov. 1995;5(4):399-402. [pmid: 10733835].
310 Muscelli E, M G, Camastra S, Manco M, Pereira JA, Pareja JC, Ferrannini E. Differential effect of weight loss on insulin resistance in surgically treated obese patients. Am J Med. Jan. 2005;118(1):51-7. [pmid: 15639210].
311 Nain P, Virk S, Ahuja A, et al. To compare the weight and metabolic parameters before and after laparoscopic sleeve gastrectomy in 74 bariatric patients. Surgical Endoscopy and Other Interventional Techniques. 2011;25:S243.
312 Navarrete SA, Leyba JL, Llopis SN. Laparoscopic sleeve gastrectomy with duodenojejunal bypass for the treatment of type 2 diabetes in non-obese patients: technique and preliminary results. Obes Surg. May. 2011;21(5):663-7. [pmid: 21336559].
313 Nehoda H, H K, Sauper T, Mittermair R, Lanthaler M, Aigner F, Weiss H. Laparoscopic gastric banding in older patients. Arch Surg. Oct. 2001;136(10):1171-6. [pmid: 11585511].
314 Nelson RH, M JM. The use of orlistat in the treatment of obesity, dyslipidaemia and Type 2 diabetes. Expert Opin Pharmacother. Nov. 2005;6(14):2483-91. [pmid: 16259579].
315 Nguyen DA, Kim GJ, Liu CD. Diabetic patients have less lean body mass which is correlated with less excess weight loss in laparoscopic adjustable gastric banding (LAGB) over three years, N=601. Gastroenterology. 2011;140(5):S1058.
316 Nguyen NT, Masoomi H, Magno CP, et al. Trends in use of bariatric surgery, 2003-2008. Journal of the American College of Surgeons. 2011;213(2):261-6. [pmid: 21624841].
317 Nguyen NT, H M, Fayad C, Varela E, Wilson SE. Use and outcomes of laparoscopic versus open gastric bypass at academic medical centers. J Am Coll Surg. Aug. 2007;205(2):248-55. [pmid: 17660071].
318 Nguyen NT, V E, Sabio A, Tran CL, Stamos M, Wilson SE. Resolution of hyperlipidemia after laparoscopic Roux-en-Y gastric bypass. J Am Coll Surg. Jul. 2006;203(1):24-9. [pmid: 16798484].
319 Nield L, M HJ, Hooper L, Cruickshank JK, Vyas A, Whittaker V, Summerbell CD. Dietary advice for treatment of type 2 diabetes mellitus in adults. Cochrane Database Syst Rev. 2007;(3):CD004097. [pmid: 17636747].
320 Nielsen JV, J E. Low-carbohydrate diet in type 2 diabetes. Stable improvement of bodyweight and glycemic control during 22 months follow-up. Nutr Metab (Lond). 2006;3:22. [pmid: 16774674].
321 Nielsen JV, J EA. Low-carbohydrate diet in type 2 diabetes: stable improvement of bodyweight and glycemic control during 44 months follow-up. Nutr Metab (Lond). 2008;5:14. [pmid: 18495047].
322 Nienhuijs SW, de Zoete JP, Berende CA, et al. Evaluation of laparoscopic sleeve gastrectomy on weight loss and co-morbidity. Int J Surg. 2010;8(4):302-4. [pmid: 20304112].
323 Nightengale ML, S MG, Kelly KA, Jensen MD, Zinsmeister AR, Palumbo PJ. Prospective evaluation of vertical banded gastroplasty as the primary operation for morbid obesity. Mayo Clin Proc. Aug. 1991;66(8):773-82. [pmid: 1861548].
324 Nijhawan S, Majid SF, Sedrak M, et al. First human NOTES(registered trademark) experience for sleeve gastrectomy at University of California at San Diego (UCSD). Gastrointestinal Endoscopy. 2011;73(4):AB147.
325 Nilsell K, T A, Sjostedt S, Apelman J, Pettersson N. Prospective randomised comparison of adjustable gastric banding and vertical banded gastroplasty for morbid obesity. Eur J Surg. Jul. 2001;167(7):504-9. [pmid: 11560385].
326 Nugent C, B C, Elariny H, Gopalakrishnan P, Quigley C, Garone M Jr., Afendy M, Chan O, Wheeler A, Afendy A, Younossi ZM. Metabolic syndrome after laparoscopic bariatric surgery. Obes Surg. Oct. 2008;18(10):1278-86. [pmid: 18401668].
327 Nuttall FQ, G MC, Saeed A, Jordan K, Hoover H. The metabolic response of subjects with type 2 diabetes to a high-protein, weight-maintenance diet. J Clin Endocrinol Metab. Aug. 2003;88(8):3577-83. [pmid: 12915639].
328 Nwobu CO, J CC. Targeting obesity to reduce the risk for type 2 diabetes and other co-morbidities in African American youth: a review of the literature and recommendations for prevention. Diab Vasc Dis Res. Dec. 2007;4(4):311-9. [pmid: 18158701].
329 O'Brien PE, D JB. Lap-band: outcomes and results. J Laparoendosc Adv Surg Tech A. Aug. 2003;13(4):265-70. [pmid: 14561255].
330 O'Brien PE, D JB. Laparoscopic adjustable gastric banding in the treatment of morbid obesity. Arch Surg. Apr. 2003;138(4):376-82. [pmid: 12686523].
331 O'Kane M, W PG, Wales JK. Fluoxetine in the treatment of obese type 2 diabetic patients. Diabet Med. Jan-Feb. 1994;11(1):105-10. [pmid: 8181239].
332 Ohta M, Hirashita T, Iwashita Y, et al. Japanese experience in laparoscopic adjustable gastric banding: 5-year results. Surgical Endoscopy and Other Interventional Techniques. 2011;25:S244.
333 Olbers T, B S, Lindroos A, Maleckas A, Lonn L, Sjostrom L, Lonroth H. Body composition, dietary intake, and energy expenditure after laparoscopic Roux-en-Y gastric bypass and laparoscopic vertical banded gastroplasty: a randomized clinical trial. Ann Surg. Nov. 2006;244(5):715-22. [pmid: 17060764].
334 Olbers T, L H, Dalenback J, Haglind E, Lundell L. Laparoscopic vertical banded gastroplasty--an effective long-term therapy for morbidly obese patients?. Obes Surg. Dec. 2001;11(6):726-30. [pmid: 11775570].
335 Olivan B MD, T Julio M. D., Bose Mousumi PhD, Bawa Baani B. A., Chang Tangel M. S., Summe Heather M. S., Lee Hongchan M. D., Laferrere Blandine M. D. Effect of Weight Loss by Diet or Gastric Bypass Surgery on Peptide YY3-36 Levels. Ann Surg. 2009;249(6):948-53. [pmid: 19474685].
336 Omana JJ, Nguyen SQ, Herron D, et al. Comparison of comorbidity resolution and improvement between laparoscopic sleeve gastrectomy and laparoscopic adjustable gastric banding. Surg Endosc. Oct. 2010;24(10):2513-7. [pmid: 20339873].
337 Padwal RS, M SR. Drug treatments for obesity: orlistat, sibutramine, and rimonabant. Lancet. Jan. 6. 2007;369(9555):71-7. [pmid: 17208644].
338 Paisey RB, F J, Harvey P, Paisey A, Bower L, Paisey RM, Taylor P, Belka I. Five year results of a prospective very low calorie diet or conventional weight loss programme in type 2 diabetes. J Hum Nutr Diet. Apr. 2002;15(2):121-7. [pmid: 11972741].
339 Paisey RB, H P, Rice S, Belka I, Bower L, Dunn M, Taylor P, Paisey RM, Frost J, Ash I. An intensive weight loss programme in established type 2 diabetes and controls: effects on weight and atherosclerosis risk factors at 1 year. Diabet Med. Jan. 1998;15(1):73-9. [pmid: 9472867].
340 Paran H, S Liat, shwartz Ivan, Gutman Mordechai. Long-term Follow-up on the Effect of Silastic Ring Vertical Gastroplasty on Weight and Co-Morbidities. Obesity Surgery. 2007;17(6):737-41. [pmid: 17879571].
341 Parikh M, Helen L, Chang Christopher, Collings Dinee, Fielding George, Ren Christine. Comparison of outcomes after laparoscopic adjustable gastric banding in African-Americans and whites. Surgery for Obesity and Related Diseases. 2(6):607-10. [pmid: 17023220].
342 Pascale RW, W RR, Butler BA, Mullen M, Bononi P. Effects of a behavioral weight loss program stressing calorie restriction versus calorie plus fat restriction in obese individuals with NIDDM or a family history of diabetes. Diabetes Care. Sep. 1995;18(9):1241-8. [pmid: 8612437].
343 Pasnik K, K J, Stanowski E. Vertical banded gastroplasty: 6 years experience at a center in Poland. Obes Surg. Feb. 2005;15(2):223-7. [pmid: 15802065].
344 Patti ME, Goldfine AB. Hypoglycaemia following gastric bypass surgery--diabetes remission in the extreme?. Diabetologia. Nov. 2010;53(11):2276-9. [pmid: 20730413].
345 Paxton JH, M JB. The cost effectiveness of laparoscopic versus open gastric bypass surgery. Obes Surg. Jan. 2005;15(1):24-34. [pmid: 15760496].
346 Pedersen O, G P. Intensified multifactorial intervention and cardiovascular outcome in type 2 diabetes: the Steno-2 study. Metabolism. Aug. 2003;52(8 Suppl 1):19-23. [pmid: 12939735].
347 Pedersen SD, K J, Kline GA. Portion control plate for weight loss in obese patients with type 2 diabetes mellitus: a controlled clinical trial. Arch Intern Med. Jun. 25. 2007;167(12):1277-83. [pmid: 17592101].
348 Penn L, W Martin, Oldroyd John, Walker Mark, Alberti K George, Mathers John. Prevention of type 2 diabetes in adults with impaired glucose tolerance: the European Diabetes Prevention RCT in Newcastle upon Tyne, UK. BMC Public Health. 2009;9(1):342. PMID. [doi: 10.1186/1471-2458-9-342]. [pmid: 19758428].
349 Peterli R, Beglinger C, Von Flue M, et al. Improved glucose metabolism 1 year after bariatric surgery: Comparison of laparoscopic Roux-en-Y gastric bypass (LRYGB) and laparoscopic sleeve gastrectomy (LSG)-a prospective randomized trial. Obesity Surgery. 2010;20(6):823.
350 Phelan S, W TA, Berkowitz RI, Sarwer DB, Womble LG, Cato RK, Rothman R. Impact of weight loss on the metabolic syndrome. Int J Obes (Lond). Sep. 2007;31(9):1442-8. [pmid: 17356528].
351 Pi-Sunyer FX, A LJ, Heshmati HM, Devin J, Rosenstock J. Effect of rimonabant, a cannabinoid-1 receptor blocker, on weight and cardiometabolic risk factors in overweight or obese patients: RIO-North America: a randomized controlled trial. JAMA. Feb. 15. 2006;295(7):761-75. [pmid: 16478899].
352 Pi-Sunyer X, B G, Brancati FL, Bray GA, Bright R, Clark JM, Curtis JM, Espeland MA, Foreyt JP, Graves K, Haffner SM, Harrison B, Hill JO, Horton ES, Jakicic J, Jeffery RW, Johnson KC, Kahn S, Kelley DE, Kitabchi AE, Knowler WC, Lewis CE, Maschak-Carey BJ, Montgomery B, Nathan DM, Patricio J, Peters A, Redmon JB, Reeves RS, Ryan DH, Safford M, Van Dorsten B, Wadden TA, Wagenknecht L, Wesche-Thobaben J, Wing RR, Yanovski SZ. Reduction in weight and cardiovascular disease risk factors in individuals with type 2 diabetes: one-year results of the look AHEAD trial. Diabetes Care. Jun. 2007;30(6):1374-83. [pmid: 17363746].
353 Pignone M. Bariatric surgery reduces the need for glycemic control medications and related health care costs. Clinical Diabetes. 2011;29(1):34-5.
354 Pinkey J. Bariatric surgery for diabetes: gastric banding is simple and safe. Br J Diabetes Vasc Dis. 2010;10:139-42.
355 Pinkney JH, S CD, Gale EA. Should surgeons treat diabetes in severely obese people?. Lancet. Apr. 28. 2001;357(9265):1357-9. [pmid: 11343762].
356 Pinkney J, K D. Current status of bariatric surgery in the treatment of type 2 diabetes. Obes Rev. Feb. 2004;5(1):69-78. [pmid: 14969508].
357 Podnos YD, J JC, Wilson SE, Stevens CM, Nguyen NT. Complications after laparoscopic gastric bypass: a review of 3464 cases. Arch Surg. Sep. 2003;138(9):957-61. [pmid: 12963651].
358 Ponce J, H B, Paynter S, Fromm R, Lindsey B, Shafer A, Manahan E, Sutterfield C. Effect of Lap-Band-induced weight loss on type 2 diabetes mellitus and hypertension. Obes Surg. Nov-Dec. 2004;14(10):1335-42. [pmid: 15603648].
359 Pories WJ, M KG Jr., Morgan EJ, Sinha MK, Dohm GL, Swanson MS, Barakat HA, Khazanie PG, Leggett-Frazier N, Long SD, et al. Surgical treatment of obesity and its effect on diabetes: 10-y follow-up. Am J Clin Nutr. Feb. 1992;55(2 Suppl):582S-5S. [pmid: 1733132].
360 Pories WJ, S MS, MacDonald KG, Long SB, Morris PG, Brown BM, Barakat HA, deRamon RA, Israel G, Dolezal JM, et al. Who would have thought it? An operation proves to be the most effective therapy for adult-onset diabetes mellitus. Ann Surg. Sep. 1995;222(3):339-50. discussion 50-2. [pmid: 7677463].
361 Pournaras DJ, Osborne A, Hawkins SC, et al. Remission of type 2 diabetes after gastric bypass and banding: mechanisms and 2 year outcomes. Ann Surg. Dec. 2010;252(6):966-71. [pmid: 21107106].
362 Puzziferri N, A-S IT, Wolfe BM, Wilson SE, Nguyen NT. Three-year follow-up of a prospective randomized trial comparing laparoscopic versus open gastric bypass. Ann Surg. Feb. 2006;243(2):181-8. [pmid: 16432350].
363 Rae A, B D, Evans S, North F, Roberman B, Walters B. A randomised controlled trial of dietary energy restriction in the management of obese women with gestational diabetes. Aust N Z J Obstet Gynaecol. Nov. 2000;40(4):416-22. [pmid: 11194427].
364 Raynor HA, J RW, Ruggiero AM, Clark JM, Delahanty LM. Weight loss strategies associated with BMI in overweight adults with type 2 diabetes at entry into the Look AHEAD (Action for Health in Diabetes) trial. Diabetes Care. Jul. 2008;31(7):1299-304. [pmid: 18375417].
365 Raz I, H M, Xu L, Caria C, Williams-Herman D, Khatami H. Efficacy and safety of the dipeptidyl peptidase-4 inhibitor sitagliptin as monotherapy in patients with type 2 diabetes mellitus. Diabetologia. Nov. 2006;49(11):2564-71. [pmid: 17001471].
366 Reaven G, S K, Hauptman J, Boldrin M, Lucas C. Effect of orlistat-assisted weight loss in decreasing coronary heart disease risk in patients with syndrome X. Am J Cardiol. Apr. 1. 2001;87(7):827-31. [pmid: 11274935].
367 Redmon JB, B AG, Connelly S, Fenney PA, Glasser S, Glick H, Greenway F, Hesson LA, Lawlor MS, Montez M, Montgomery B. Effect of the Look AHEAD Study Intervention on Medication Use and Related Cost to Treat Cardiovascular Disease Risk Factors in Individuals with Type 2 Diabetes. Diabetes Care. 2010. Mar. 23. [pmid: 20332353].
368 Redmon JB, R SK, Reck KP, Swanson JE, Kwong CA, Fan Q, Thomas W, Bantle JP. One-year outcome of a combination of weight loss therapies for subjects with type 2 diabetes: a randomized trial. Diabetes Care. Sep. 2003;26(9):2505-11. [pmid: 12941710].
369 Redmon JB, R SK, Kwong CA, Swanson JE, Thomas W, Bantle JP. Pharmacologic induction of weight loss to treat type 2 diabetes. Diabetes Care. Jun. 1999;22(6):896-903. [pmid: 10372238].
370 Redmon JB, R KP, Raatz SK, Swanson JE, Kwong CA, Ji H, Thomas W, Bantle JP. Two-year outcome of a combination of weight loss therapies for type 2 diabetes. Diabetes Care. Jun. 2005;28(6):1311-5. [pmid: 15920044].
371 Reinhold RB. Late results of gastric bypass surgery for morbid obesity. J Am Coll Nutr. Aug. 1994;13(4):326-31. [pmid: 7963136].
372 Ricciardi R, T RJ, Kellogg TA, Ikramuddin S, Baxter NN. Outcomes after open versus laparoscopic gastric bypass. Surg Laparosc Endosc Percutan Tech. Oct. 2006;16(5):317-20. [pmid: 17057571].
373 Richardson DW, Elizabeth Mason M, Vinik AI. Update: Metabolic and Cardiovascular Consequences of Bariatric Surgery. Endocrinology and Metabolism Clinics of North America. 2011;40(1):81-96. [pmid: 21349412].
374 Richelsen B, T S, Rossner S, Toubro S, Niskanen L, Madsbad S, Mustajoki P, Rissanen A. Effect of orlistat on weight regain and cardiovascular risk factors following a very-low-energy diet in abdominally obese patients: a 3-year randomized, placebo-controlled study. Diabetes Care. Jan. 2007;30(1):27-32. [pmid: 17192328].
375 Riddle M, F J, Zhang B, Maier H, Brown C, Lutz K, Kolterman O. Pramlintide improved glycemic control and reduced weight in patients with type 2 diabetes using basal insulin. Diabetes Care. Nov. 2007;30(11):2794-9. [pmid: 17698615].
376 Rizzello M, Abbatini F, Casella G, et al. Early postoperative insulin-resistance changes after sleeve gastrectomy. Obes Surg. Jan. 2010;20(1):50-5. [pmid: 19916040].
377 Robinson JC, F AR, Nabulsi AA, Watson R, Brancati FL, Cai J. Can postmenopausal hormone replacement improve plasma lipids in women with diabetes? The Atherosclerosis Risk in Communities Study Investigators. Diabetes Care. May. 1996;19(5):480-5. [pmid: 8732713].
378 Rodriguez LR, Eliana Fagalde, Pilar Oltra, Maria Soledad, Saba Jorge, Aylwin Carmen, Gloria Prieto, Carolina Ramos, Almino Galvao, Manoel Gersin, Keith S, Sorli Christopher. Pilot Clinical Study of an Endoscopic, Removable Duodenal-Jejunal Bypass Liner for the Treatment of Type 2 Diabetes. Diabetes Technology & Therapeutics. 2009;11(11):725-32. [pmid: 19905889].
379 Rosenstock J, H P, Gadde KM, Sun X, Strauss R, Leung A. A randomized, double-blind, placebo-controlled, multicenter study to assess the efficacy and safety of topiramate controlled release in the treatment of obese type 2 diabetic patients. Diabetes Care. Jun. 2007;30(6):1480-6. [pmid: 17363756].
380 Roslin MS, O Jonathan H, Yatco Edward, Shah Paresh C. PL-205: Abnormal glucose tolerance testing following gastric bypass. Surgery for Obesity and Related Diseases. 2009;5(3, Supplement 1):S10-S.
381 Ross R. Does exercise without weight loss improve insulin sensitivity?. Diabetes Care. Mar. 2003;26(3):944-5. [pmid: 12610063].
382 Ross R, F JA, Janssen I. Exercise alone is an effective strategy for reducing obesity and related comorbidities. Exerc Sport Sci Rev. Oct. 2000;28(4):165-70. [pmid: 11064850].
383 Rubenstein RB. Laparoscopic adjustable gastric banding at a U.S. center with up to 3-year follow-up. Obes Surg. Jun. 2002;12(3):380-4. [pmid: 12082892].
384 Rutledge R. Subjective vs. objective resolution of diabetes mellitus following mini-gastric bypass: Patients' subjective assessment of resolution lags 1-3 years behind objective resolution. Obesity Surgery. 2010;20(8):1041-2.
385 Ryan DH, E MA, Foster GD, Haffner SM, Hubbard VS, Johnson KC, Kahn SE, Knowler WC, Yanovski SZ. Look AHEAD (Action for Health in Diabetes): design and methods for a clinical trial of weight loss for the prevention of cardiovascular disease in type 2 diabetes. Control Clin Trials. Oct. 2003;24(5):610-28. [pmid: 14500058].
386 Saenz A, F-E I, Mataix A, Ausejo M, Roque M, Moher D. Metformin monotherapy for type 2 diabetes mellitus. Cochrane Database Syst Rev. 2005;(3):CD002966. [pmid: 16034881].
387 Sahay BK. Yoga and diabetes. J Assoc Physicians India. Sep. 1986;34(9):645-8. [pmid: 3793701].
388 Salas M, W A, Caro J. Health and economic effects of adding nateglinide to metformin to achieve dual control of glycosylated hemoglobin and postprandial glucose levels in a model of type 2 diabetes mellitus. Clin Ther. Oct. 2002;24(10):1690-705. [pmid: 12462297].
389 Salmela S, P M, Kasila K, Vahasarja K, Vanhala M. Transtheoretical model-based dietary interventions in primary care: a review of the evidence in diabetes. Health Educ Res. Apr. 2009;24(2):237-52. [pmid: 18408218].
390 Salmon PA. The results of small intestine bypass operations for the treatment of obesity. Surg Gynecol Obstet. Jun. 1971;132(6):965-79. [pmid: 5578437].
391 Sampalis JS, L M, Auger S, Christou NV. The impact of weight reduction surgery on health-care costs in morbidly obese patients. Obes Surg. Aug. 2004;14(7):939-47. [pmid: 15329183].
392 Sanchez-Pernaute A, Rubio MA, Martin E, et al. Metabolic results and weight loss outcome after single anastomosis duodeno-ileal bypass with sleeve gastrectomy (SADI-S). Threeyear results. Obesity Surgery. 2010;20(6):826.
393 Sartorelli DS, S EC, Franco LJ, Cardoso MA. Beneficial effects of short-term nutritional counselling at the primary health-care level among Brazilian adults. Public Health Nutr. Oct. 2005;8(7):820-5. [pmid: 16277797].
394 Schachter M. Metabolic effects of moxonidine and other centrally acting antihypertensives. Diabetes Obes Metab. Nov. 1999;1(6):317-22. [pmid: 11225647].
395 Schauer PR, B B, Ikramuddin S, Cottam D, Gourash W, Hamad G, Eid GM, Mattar S, Ramanathan R, Barinas-Mitchel E, Rao RH, Kuller L, Kelley D. Effect of laparoscopic Roux-en Y gastric bypass on type 2 diabetes mellitus. Ann Surg. Oct. 2003;238(4):467-84. discussion 84-5. [pmid: 14530719].
396 Schauer PR, I S, Gourash W, Ramanathan R, Luketich J. Outcomes after laparoscopic Roux-en-Y gastric bypass for morbid obesity. Ann Surg. Oct. 2000;232(4):515-29. [pmid: 10998650].
397 Scheen AJ. Info-congress. Prevention of type 2 diabetes in obese patients: first results with orlistat in the XENDOS study. Rev Med Liege. Sep. 2002;57(9):617-21. [pmid: 12440353].
398 Scheen AJ, E P. New antiobesity agents in type 2 diabetes: overview of clinical trials with sibutramine and orlistat. Diabetes Metab. Dec. 2002;28(6 Pt 1):437-45. [pmid: 12522323].
399 Scheen AJ, VG LF. Cardiometabolic effects of rimonabant in obese/overweight subjects with dyslipidaemia or type 2 diabetes. Rev Med Liege. Feb. 2007;62(2):81-5. [pmid: 17461296].
400 Schindler K, P G, Ballaban T, Kretschmer S, Riener R, Buranyi B, Maier C, Luger A, Ludvik B. Impact of laparoscopic adjustable gastric banding on plasma ghrelin, eating behaviour and body weight. Eur J Clin Invest. Aug. 2004;34(8):549-54. [pmid: 15305889].
401 Schok M, G R, van Antwerpen T, de Wit P, Brand N, van Ramshorst B. Quality of life after laparoscopic adjustable gastric banding for severe obesity: postoperative and retrospective preoperative evaluations. Obes Surg. Dec. 2000;10(6):502-8. [pmid: 11175956].
402 Schouten R MD, R Carianne S M. D., Bouvy Nicole D M. D. PhD, Hameeteman Wim M. D. PhD, Koek Ger H M. D. PhD, Janssen Ignace M C. M. D., Greve Jan-Willem M M. D. PhD. A Multicenter, Randomized Efficacy Study of the EndoBarrier Gastrointestinal Liner for Presurgical Weight Loss Prior to Bariatric Surgery. [Miscellaneous Article]. Ann Surg. 2010;251(2):236-43. [pmid: 19858703].
403 Schouten R, vD FM, Greve JW. Re-operation after laparoscopic adjustable gastric banding leads to a further decrease in BMI and obesity-related co-morbidities: results in 33 patients. Obes Surg. Jul. 2006;16(7):821-8. [pmid: 16839477].
404 Schouten R, W D, van Dielen F, Greve J. Laparoscopic adjustable gastric banding (LAGB) versus open vertical banded gastroplasty (VBG): long-term results of a prospective randomized trial. Obes Surg. 2008;18:459.
405 Scopinaro N, M GM, Camerini GB, Papadia FS, Adami GF. Specific effects of biliopancreatic diversion on the major components of metabolic syndrome: a long-term follow-up study. Diabetes Care. Oct. 2005;28(10):2406-11. [pmid: 16186271].
406 Scopinaro N, P F, Camerini G, Marinari G, Civalleri D, Gian Franco A. A comparison of a personal series of biliopancreatic diversion and literature data on gastric bypass help to explain the mechanisms of resolution of type 2 diabetes by the two operations. Obes Surg. Aug. 2008;18(8):1035-8. [pmid: 18463931].
407 Scott WR, Batterham RL. Roux-en-Y gastric bypass and laparoscopic sleeve gastrectomy: understanding weight loss and improvements in type 2 diabetes after bariatric surgery. Am J Physiol Regul Integr Comp Physiol. Jul. 2011;301(1):R15-27. [pmid: 21474429].
408 See C, C PL, Elliott D, Mullenix P, Eggebroten W, Porter C, Watts D. An institutional experience with laparoscopic gastric bypass complications seen in the first year compared with open gastric bypass complications during the same period. Am J Surg. May. 2002;183(5):533-8. [pmid: 12034387].
409 Segal JB, C JM, Shore AD, Dominici F, Magnuson T, Richards TM, Weiner JP, Bass EB, Wu AW, Makary MA. Prompt Reducation in Use of Medications for Comorbid Conditions After Bariatric Surgery. (Prepared by Johns Hopkins University DEcIDE Center under Contract No. HHSA29020050034-1TO2). Agency for Healthcare Research and Quality. Rockville, MD. June. 2010. http://effectivehealthcare.ahrq.gov/reports/final.cfm.
410 Segal JB, D SM, Millman EA, Herbert R, Bass EB, Wu AW. Who Uses Exenatide for Glucose Control in Diabetes Mellitus? A Retrospective Cohort Study of a New Therapy. (Prepared by Johns Hopkins University DEcIDE Center under Contract No. 290-2005-0034-1). Agency for Healthcare Research and Quality. Rockville, MD. July. 2010. http://effectivehealthcare.ahrq.gov/reports/final.cfm.
411 Segato G, Busetto L, De Luca M, et al. Weight loss and changes in use of antidiabetic medication in obese type 2 diabetics after laparoscopic gastric banding. Surg Obes Relat Dis. Mar. 4. 2010;6(2):132-7. [pmid: 19926528].
412 Selby JV, E B, Swain BE, Brown JB. First 20 months' experience with use of metformin for type 2 diabetes in a large health maintenance organization. Diabetes Care. Jan. 1999;22(1):38-44. [pmid: 10333901].
413 Serra-Majem L, R B, Estruch R. Scientific evidence of interventions using the Mediterranean diet: a systematic review. Nutr Rev. Feb. 2006;64(2 Pt 2):S27-47. [pmid: 16532897].
414 Shah PS, Todkar JS, Shah SS. Effectiveness of laparoscopic sleeve gastrectomy on glycemic control in obese Indians with type 2 diabetes mellitus. Surg Obes Relat Dis. Mar. 4. 2010;6(2):138-41. [pmid: 19733515].
415 Shah PS, T Jayashree S, Shah Shashank S. PL-214: Behavior of type 2 diabetes mellitus in obese Indian patients submitted to sleeve gastrectomy. Surgery for Obesity and Related Diseases. 2009;5(3, Supplement 1):S13-S4.
416 Shakeri-Manesch S, Ludvik B, Bohdjalian A, et al. Efficacy of bariatric surgery in the treatment of obesity-related type ii diabetes mellitus - 24 months follow up. Obesity Surgery. 2010;20(8):1038-9.
417 Singer DL, H D. Long-term experience with sulfonylureas and placebo. N Engl J Med. Aug. 31. 1967;277(9):450-6. [pmid: 5340346].
418 Sjostrom CD, P M, Sjostrom L. Blood pressure and pulse pressure during long-term weight loss in the obese: the Swedish Obese Subjects (SOS) Intervention Study. Obes Res. Mar. 2001;9(3):188-95. [pmid: 11323444].
419 Sjostrom L. Analysis of the XENDOS study (Xenical in the Prevention of Diabetes in Obese Subjects). Endocr Pract. Jan-Feb. Suppl 1. 2006;12:31-3. [pmid: 16627377].
420 Sjostrom L, L AK, Peltonen M, Torgerson J, Bouchard C, Carlsson B, Dahlgren S, Larsson B, Narbro K, Sjostrom CD, Sullivan M, Wedel H. Lifestyle, diabetes, and cardiovascular risk factors 10 years after bariatric surgery. N Engl J Med. Dec. 23. 2004;351(26):2683-93. [pmid: 15616203].
421 Sjostrom L, R A, Andersen T, Boldrin M, Golay A, Koppeschaar HP, Krempf M. Randomised placebo-controlled trial of orlistat for weight loss and prevention of weight regain in obese patients. European Multicentre Orlistat Study Group. Lancet. Jul. 18. 1998;352(9123):167-72. [pmid: 9683204].
422 Skroubis G, A S, Kehagias I, Mead N, Vagenas K, Kalfarentzos F. Roux-en-Y gastric bypass versus a variant of biliopancreatic diversion in a non-superobese population: prospective comparison of the efficacy and the incidence of metabolic deficiencies. Obes Surg. Apr. 2006;16(4):488-95. [pmid: 16608616].
423 Slim K, B J, Kwiatkowski F, Lescure G, Pezet D, Chipponi J. Quality of life before and after laparoscopic fundoplication. Am J Surg. Jul. 2000;180(1):41-5. [pmid: 11036138].
424 Smith DE, W RR. Diminished weight loss and behavioral compliance during repeated diets in obese patients with type II diabetes. Health Psychol. 1991;10(6):378-83. [pmid: 1765032].
425 Smith SC, E CB, Goodman GN. Changes in Diabetic Management After Roux-en-Y Gastric Bypass. Obes Surg. Aug. 1996;6(4):345-8. [pmid: 10729876].
426 Sosa JL, P H, Pallavicini H, Ruiz-Rodriguez M. Laparoscopic gastric bypass beyond age 60. Obes Surg. Nov-Dec. 2004;14(10):1398-401. [pmid: 15603658].
427 Souto SB, Souto EB, Braga DC, et al. Prevention and current onset delay approaches of type 2 diabetes mellitus (T2DM). European Journal of Clinical Pharmacology. 2011;67(7):653-61. [pmid: 21468743].
428 Sovik TT, Aasheim ET, Taha O, et al. Weight loss, cardiovascular risk factors, and quality of life after gastric bypass and duodenal switch: a randomized trial. Ann Intern Med. Sep. 6. 2011;155(5):281-91. [pmid: 21893621].
429 Sovik TT, Irandoust B, Birkeland KI, et al. Type 2 diabetes and metabolic syndrome before and after gastric bypass. Tidsskr Nor Laegeforen. Jul. 1. 2010;130(13):1347-50. [pmid: 20596116].
430 St Peter SD, C RO, Tiede JL, Swain JM. Impact of advanced age on weight loss and health benefits after laparoscopic gastric bypass. Arch Surg. Feb. 2005;140(2):165-8. [pmid: 15723998].
431 Stenlof K, R S, Vercruysse F, Kumar A, Fitchet M, Sjostrom L. Topiramate in the treatment of obese subjects with drug-naive type 2 diabetes. Diabetes Obes Metab. May. 2007;9(3):360-8. [pmid: 17391164].
432 Stern L, I N, Seshadri P, Chicano KL, Daily DA, McGrory J, Williams M, Gracely EJ, Samaha FF. The effects of low-carbohydrate versus conventional weight loss diets in severely obese adults: one-year follow-up of a randomized trial. Ann Intern Med. May. 18. 2004;140(10):778-85. [pmid: 15148064].
433 Stoeckli R, C R, Langer I, Keller U. Changes of body weight and plasma ghrelin levels after gastric banding and gastric bypass. Obes Res. Feb. 2004;12(2):346-50. [pmid: 14981228].
434 Stumvoll M, N N, Perriello G, Dailey G, Gerich JE. Metabolic effects of metformin in non-insulin-dependent diabetes mellitus. N Engl J Med. Aug. 31. 1995;333(9):550-4. [pmid: 7623903].
435 Su Y, Su YH, Lee WJ, et al. C-peptide predicts the remission of type ii diabetes (T2DM) after sleeve gastrectomy. Obesity Surgery. 2010;20(8):979.
436 Sucharda P. Metabolic surgery--the most effective diabetes treatment. Vnitr Lek. Apr. 2011;57(4):396-401. [pmid: 21612067].
437 Sugerman HJ, K JM Jr., DeMaria EJ, Reines HD. Conversion of failed or complicated vertical banded gastroplasty to gastric bypass in morbid obesity. Am J Surg. Feb. 1996;171(2):263-9. [pmid: 8619465].
438 Sugerman HJ, L GL, Kellum JM, Wolf L, Liszka T, Engle KM, Birkenhauer R, Starkey JV. Weight loss with vertical banded gastroplasty and Roux-Y gastric bypass for morbid obesity with selective versus random assignment. Am J Surg. Jan. 1989;157(1):93-102. [pmid: 2910132].
439 Sugerman HJ, W LG, Sica DA, Clore JN. Diabetes and hypertension in severe obesity and effects of gastric bypass-induced weight loss. Ann Surg. Jun. 2003;237(6):751-6. discussion 7-8. [pmid: 12796570].
440 Sultan S, Gupta D, Parikh M, et al. Five-year outcomes of patients with type 2 diabetes who underwent laparoscopic adjustable gastric banding. Surg Obes Relat Dis. Jul-Aug. 2010;6(4):373-6. [pmid: 20627708].
441 Summerbell CD, W C, Higgins JP, Garrow JS. Randomised controlled trial of novel, simple, and well supervised weight reducing diets in outpatients. BMJ. Nov. 28. 1998;317(7171):1487-9. [pmid: 9831574].
442 Super P, Kitchen M, Krempic A, et al. Medium term metabolic outcomes of obese diabetic patients following laparoscopic adjustable gastric banding. Obesity Surgery. 2010;20(6):820.
443 Suter M, Donadini A, Romy S, et al. Laparoscopic Roux-En-Y gastric bypass: Significant long-term weight loss, improvement of obesity-related comorbidities and quality of life. Annals of Surgery. 2011;254(2):267-73. [pmid: 21772127].
444 Suter M, G V, Worreth M, Heraief E, Calmes JM. Laparoscopic gastric banding: a prospective, randomized study comparing the Lapband and the SAGB: early results. Ann Surg. Jan. 2005;241(1):55-62. [pmid: 15621991].
445 Tan JT, K S, Wijeratne T, Chandraratna HS. Diagnosis and management of gastric leaks after laparoscopic sleeve gastrectomy for morbid obesity. Obes Surg. Apr. 2010;20(4):403-9. [pmid: 19936855].
446 Tarnoff M, R L, Escalona A, Ramos A, Neto M, Alamo M, Reyes E, Pimentel F, Ibanez L. Open label, prospective, randomized controlled trial of an endoscopic duodenal-jejunal bypass sleeve versus low calorie diet for pre-operative weight loss in bariatric surgery. Surgical Endoscopy. 2009;23(3):650-6. [pmid: 19067075].
447 Taskin M, Z K, Apaydin BB, Unal E. Laparoscopy in Turkish bariatric surgery: initial experience. Obes Surg. Jun. 2000;10(3):263-5. [pmid: 10932258].
448 Taylor C, L Laurent. Laparoscopic Adjustable Gastric Banding in Patients ≥60 Years Old: Is it Worthwhile?. Obesity Surgery. 2006;16(12):1579-83. [pmid: 17217633].
449 Tayyem RM, Ali A. Short term outcome and health related quality of life of laparoscopic adjustable gastric band versus laparoscopic sleeve gastrectomy. Surgical Endoscopy and Other Interventional Techniques. 2011;25:S37.
450 Temple PC, T B, Sachs L, Strasser S, Choban P, Flancbaum L. Functioning and well-being of patients before and after elective surgical procedures. J Am Coll Surg. Jul. 1995;181(1):17-25. [pmid: 7599766].
451 The Danish Obesity Project. Randomised trial of jejunoileal bypass versus medical treatment in morbid obesity. Lancet. Dec. 15. 1979;2(8155):1255-8. [pmid: 93179].
452 The Diabetes Control and Complications Trial Research Group. Lifetime benefits and costs of intensive therapy as practiced in the diabetes control and complications trial. JAMA. Nov. 6. 1996;276(17):1409-15. [pmid: 8892716].
453 The Diabetes Prevention Program. Design and methods for a clinical trial in the prevention of type 2 diabetes. Diabetes Care. Apr. 1999;22(4):623-34. [pmid: 10189543].
454 Thomas DE, E EJ, Naughton GA. Exercise for type 2 diabetes mellitus. Cochrane Database Syst Rev. 2006;3:CD002968. [pmid: 16855995].
455 Tinker LF, B DE, Margolis KL, Manson JE, Howard BV, Larson J, Perri MG, Beresford SA, Robinson JG, Rodriguez B, Safford MM, Wenger NK, Stevens VJ, Parker LM. Low-fat dietary pattern and risk of treated diabetes mellitus in postmenopausal women: the Women's Health Initiative randomized controlled dietary modification trial. Arch Intern Med. Jul. 28. 2008;168(14):1500-11. [pmid: 18663162].
456 Titi M, J JT, Modak P, Galloway DJ. Quality of life and alteration in comorbidity following laparoscopic adjustable gastric banding. Postgrad Med J. Jul. 2007;83(981):487-91. [pmid: 17621620].
457 Todkar JS, Shah SS, Shah PS, et al. Long-term effects of laparoscopic sleeve gastrectomy in morbidly obese subjects with type 2 diabetes mellitus. Surg Obes Relat Dis. Mar. 4. 2010;6(2):142-5. [pmid: 19733513].
458 Toplak H, H A, Moore R, Masson E, Gorska M, Vercruysse F, Sun X, Fitchet M. Efficacy and safety of topiramate in combination with metformin in the treatment of obese subjects with type 2 diabetes: a randomized, double-blind, placebo-controlled study. Int J Obes (Lond). Jan. 2007;31(1):138-46. [pmid: 16703004].
459 Toplak H, M K. Reduction of obesity and improvement in metabolic parameters by inhibition of intestinal lipases: current results with orlistat. Acta Med Austriaca. 1998;25(4-5):142-5. [pmid: 9879390].
460 Toppino M, M M, Bonnet G, Nigra I, Siliquini R. Laparoscopic surgery for morbid obesity: preliminary results from SICE registry (Italian Society of Endoscopic and Minimally Invasive Surgery). Obes Surg. Feb. 1999;9(1):62-5. [pmid: 10065587].
461 Torgerson JS, H J, Boldrin MN, Sjostrom L. XENical in the prevention of diabetes in obese subjects (XENDOS) study: a randomized study of orlistat as an adjunct to lifestyle changes for the prevention of type 2 diabetes in obese patients. Diabetes Care. Jan. 2004;27(1):155-61. [pmid: 14693982].
462 Torquati A, L R, Abumrad N, Richards WO. Is Roux-en-Y gastric bypass surgery the most effective treatment for type 2 diabetes mellitus in morbidly obese patients?. J Gastrointest Surg. Nov. 2005;9(8):1112-6. discussion 7-8. [pmid: 16269382].
463 Torquati A, W K, Melvin W, Richards W. Effect of gastric bypass operation on Framingham and actual risk of cardiovascular events in class II to III obesity. J Am Coll Surg. May. 2007;204(5):776-82. discussion 82-3. [pmid: 17481482].
464 Trakhtenbroit MA, L JG, Algahim MF, Miller CC 3rd, Moody FG, Lux TR, Taegtmeyer H. Body weight, insulin resistance, and serum adipokine levels 2 years after 2 types of bariatric surgery. Am J Med. May. 2009;122(5):435-42. [pmid: 19375553].
465 Tsujiuchi T, K H, Yoshiuchi K, He D, Tsujiuchi Y, Kuboki T, Suematsu H, Hirao K. The effect of Qi-gong relaxation exercise on the control of type 2 diabetes mellitus: a randomized controlled trial. Diabetes Care. Jan. 2002;25(1):241-2. [pmid: 11772923].
466 Turnin MC, B O, Cathelineau G, Leguerrier AM, Halimi S, Sandre-Banon D, Coliche V, Breux M, Verlet E, Labrousse F, Bensoussan D, Grenier JL, Poncet MF, Tordjmann F, Brun JM, Blickle JF, Mattei C, Bolzonella C, Buisson JC, Fabre D, Tauber JP, Hanaire-Broutin H. Multicenter randomized evaluation of a nutritional education software in obese patients. Diabetes Metab. Apr. 2001;27(2 Pt 1):139-47. [pmid: 11353880].
467 Tuthill A, Q A, McColgan D, McKenna M, O'Shea D, McKenna TJ. A prospective randomized controlled trial of lifestyle intervention on quality of life and cardiovascular risk score in patients with obesity and type 2 diabetes. Diabetes Obes Metab. Nov. 2007;9(6):917-9. [pmid: 17451423].
468 Umeda LM, Silva EA, Carneiro G, et al. Early Improvement in Glycemic Control After Bariatric Surgery and Its Relationships with Insulin, GLP-1, and Glucagon Secretion in Type 2 Diabetic Patients. Obes Surg. Jul. 2011;21(7):896-901. [pmid: 21559794].
469 Umpierrez GE, C WS, Steen MT. Sulfonylurea treatment prevents recurrence of hyperglycemia in obese African-American patients with a history of hyperglycemic crises. Diabetes Care. Apr. 1997;20(4):479-83. [pmid: 9096964].
470 Valera-Mora ME, S B, Gagliardi L, Scarfone A, Nanni G, Castagneto M, Manco M, Mingrone G, Ferrannini E. Predictors of weight loss and reversal of comorbidities in malabsorptive bariatric surgery. Am J Clin Nutr. Jun. 2005;81(6):1292-7. [pmid: 15941878].
471 van Dam HA, vdH FG, Knoops L, Ryckman RM, Crebolder HF, van den Borne BH. Social support in diabetes: a systematic review of controlled intervention studies. Patient Educ Couns. Oct. 2005;59(1):1-12. [pmid: 16198213].
472 van Dielen FM, S PB, de Brauw LM, Greve JW. Laparoscopic adjustable gastric banding versus open vertical banded gastroplasty: a prospective randomized trial. Obes Surg. Oct. 2005;15(9):1292-8. [pmid: 16259890].
473 Van Gaal LF, R AM, Scheen AJ, Ziegler O, Rossner S. Effects of the cannabinoid-1 receptor blocker rimonabant on weight reduction and cardiovascular risk factors in overweight patients: 1-year experience from the RIO-Europe study. Lancet. Apr. 16-22. 2005;365(9468):1389-97. [pmid: 15836887].
474 van Gemert WG, A EM, Kop M, Vos G, Greve JW, Soeters PB. A prospective cost-effectiveness analysis of vertical banded gastroplasty for the treatment of morbid obesity. Obes Surg. Oct. 1999;9(5):484-91. [pmid: 10605908].
475 van Gemert WG, A EM, Greve JW, Soeters PB. Quality of life assessment of morbidly obese patients: effect of weight-reducing surgery. Am J Clin Nutr. Feb. 1998;67(2):197-201. [pmid: 9459366].
476 Vasudevan AR, B A, Fonseca VA. The effectiveness of intensive glycemic control for the prevention of vascular complications in diabetes mellitus. Treat Endocrinol. 2006;5(5):273-86. [pmid: 17002487].
477 Vertruyen M. Experience with Lap-band System up to 7 years. Obes Surg. Aug. 2002;12(4):569-72. [pmid: 12194553].
478 Vetter ML, C S, Rickels MR, Iqbal N. Narrative review: effect of bariatric surgery on type 2 diabetes mellitus. Ann Intern Med. Jan. 20. 2009;150(2):94-103. [pmid: 19153412].
479 Vidal J, I A, Nicolau J, Vidov M, Delgado S, Martinez G, Balust J, Morinigo R, Lacy A. Short-term effects of sleeve gastrectomy on type 2 diabetes mellitus in severely obese subjects. Obes Surg. Aug. 2007;17(8):1069-74. [pmid: 17953241].
480 Vijgen SM, H M, Baan CA, de Wit GA, Limburg W, Feenstra TL. Cost effectiveness of preventive interventions in type 2 diabetes mellitus: a systematic literature review. Pharmacoeconomics. 2006;24(5):425-41. [pmid: 16706569].
481 Vogel JA, F BA, Zalesin KC, Trivax JE, Krause KR, Chengelis DL, McCullough PA. Reduction in predicted coronary heart disease risk after substantial weight reduction after bariatric surgery. Am J Cardiol. Jan. 15. 2007;99(2):222-6. [pmid: 17223422].
482 Volokh MA, Gubochkin NG, Shapovalov VM, et al. Surgical complications following operative treatment of abdominal obesity in type 2 diabetes mellitus patients. Vestn Khir Im I I Grek. 2011;170(1):18-21. [pmid: 21506349].
483 Wadden TA, W DS, Delahanty L, Jakicic J, Rejeski J, Williamson D, Berkowitz RI, Kelley DE, Tomchee C, Hill JO, Kumanyika S. The Look AHEAD study: a description of the lifestyle intervention and the evidence supporting it. Obesity (Silver Spring). May. 2006;14(5):737-52. [pmid: 16855180].
484 Walker EA, M M, Kramer MK, Kahn S, Ma Y, Edelstein S, Smith K, Johnson MK, Kitabchi A, Crandall J. Adherence to preventive medications: predictors and outcomes in the Diabetes Prevention Program. Diabetes Care. Sep. 2006;29(9):1997-2002. [pmid: 16936143].
485 Walton SJ, Date RS. Surgical cure for type II diabetes: Myth or reality?. Annals of Surgery. 2011;254(1):180-1. [pmid: 21617583].
486 Weiner RA, K M, Matzig E, Weiner S, Karcz WK, Junginger T. Early results with a new telemetrically adjustable gastric banding. Obes Surg. Jun. 2007;17(6):717-21. [pmid: 17879567].
487 Weinstock RS, D H, Wadden TA. Diet and exercise in the treatment of obesity: effects of 3 interventions on insulin resistance. Arch Intern Med. Dec. 7-21. 1998;158(22):2477-83. [pmid: 9855386].
488 West DS, D V, Bursac Z, Gore SA, Greene PG. Motivational interviewing improves weight loss in women with type 2 diabetes. Diabetes Care. May. 2007;30(5):1081-7. [pmid: 17337504].
489 White S, B E, Jurikova L, Stubbs RS. Long-term outcomes after gastric bypass. Obes Surg. Feb. 2005;15(2):155-63. [pmid: 15802056].
490 Wilding JV, G L, Rissanen A, Vercruysse F, Fitchet M. A randomized double-blind placebo-controlled study of the long-term efficacy and safety of topiramate in the treatment of obese subjects. Int J Obes Relat Metab Disord. Nov. 2004;28(11):1399-410. [pmid: 15486569].
491 Williams KV, K DE. Metabolic consequences of weight loss on glucose metabolism and insulin action in type 2 diabetes. Diabetes Obes Metab. Jun. 2000;2(3):121-9. [pmid: 11220547].
492 Williamson DA, R Jack, Lang Wei, Van Dorsten Brent, Fabricatore Anthony N, Toledo Katie, for the Look AHEAD Research Group. Impact of a Weight Management Program on Health-Related Quality of Life in Overweight Adults With Type 2 Diabetes. Arch Intern Med. January. 26. 2009. 2009;169(2):163-71. [pmid: 19171813].
493 Wing RR, A K. Effectiveness of a behavioral weight control program for blacks and whites with NIDDM. Diabetes Care. May. 1996;19(5):409-13. [pmid: 8732700].
494 Wing RR, B EH, Bononi P, Marcus MD, Watanabe R, Bergman RN. Caloric restriction per se is a significant factor in improvements in glycemic control and insulin sensitivity during weight loss in obese NIDDM patients. Diabetes Care. Jan. 1994;17(1):30-6. [pmid: 8112186].
495 Wing RR, B E, Marcus M, Epstein LH. Harvey J. Year-long weight loss treatment for obese patients with type II diabetes: does including an intermittent very-low-calorie diet improve outcome?. Am J Med. Oct. 1994;97(4):354-62. [pmid: 7942937].
496 Wing RR, E LH, Paternostro-Bayles M, Kriska A, Nowalk MP, Gooding W. Exercise in a behavioural weight control programme for obese patients with Type 2 (non-insulin-dependent) diabetes. Diabetologia. Dec. 1988;31(12):902-9. [pmid: 3071485].
497 Wing RR, M MD, Salata R, Epstein LH, Miaskiewicz S, Blair EH. Effects of a very-low-calorie diet on long-term glycemic control in obese type 2 diabetic subjects. Arch Intern Med. Jul. 1991;151(7):1334-40. [pmid: 2064484].
498 Wing RR, M MD, Epstein LH, Jawad A. A “family-based” approach to the treatment of obese type II diabetic patients. J Consult Clin Psychol. Feb. 1991;59(1):156-62. [pmid: 2002132].
499 Wing RR, S M, Marcus MD, McDermott M, Gooding W. Variables associated with weight loss and improvements in glycemic control in type II diabetic patients in behavioral weight control programs. Int J Obes. Jun. 1990;14(6):495-503. [pmid: 2401586].
500 Wing RR, V E, Jakicic JM, Polley BA, Lang W. Lifestyle intervention in overweight individuals with a family history of diabetes. Diabetes Care. Mar. 1998;21(3):350-9. [pmid: 9540015].
501 Wittgrove AC, C GW. Laparoscopic gastric bypass, Roux-en-Y- 500 patients: technique and results, with 3-60 month follow-up. Obes Surg. Jun. 2000;10(3):233-9. [pmid: 10929154].
502 Wittgrove AC, C GW. Laparoscopic Gastric Bypass, Roux-en-Y: Experience of 27 Cases, with 3-18 Months Follow-up. Obes Surg. Feb. 1996;6(1):54-7. [pmid: 10731251].
503 Wittgrove AC, C GW, Tremblay LJ. Laparoscopic Gastric Bypass, Roux-en-Y: Preliminary Report of Five Cases. Obes Surg. Nov. 1994;4(4):353-7. [pmid: 10742801].
504 Wittgrove AC, C GW, Schubert KR. Laparoscopic Gastric Bypass, Roux-en-Y: Technique and Results in 75 Patients With 3-30 Months Follow-up. Obes Surg. Dec. 1996;6(6):500-4. [pmid: 10729899].
505 Woelnerhanssen B, Peterli R, Steinert RE, et al. Effects of postbariatric surgery weight loss on adipokines and metabolic parameters: comparison of laparoscopic Roux-en-Y gastric bypass and laparoscopic sleeve gastrectomy-a prospective randomized trial. Surg Obes Relat Dis. 2011. Mar. 21. [pmid: 21429816].
506 Wolf AM, B U, Kortner B, Kuhlmann HW. Does gastric restriction surgery reduce the risks of metabolic diseases?. Obes Surg. Feb. 1998;8(1):9-13. [pmid: 9562480].
507 Wolf AM, C MR, Crowther JQ, Hazen KY, L. Nadler J, Oneida B, Bovbjerg VE. Translating lifestyle intervention to practice in obese patients with type 2 diabetes: Improving Control with Activity and Nutrition (ICAN) study. Diabetes Care. Jul. 2004;27(7):1570-6. [pmid: 15220230].
508 Wolf AM, K HW. Reoperation Due to Complications after Gastric Restriction Operation. Obes Surg. May. 1995;5(2):171-8. [pmid: 10733807].
509 Wolfe BM. Surgical treatment for diabetes mellitus type 2. Inflammation Research. 2010;59:s146.
510 Yang JG, Wang CC, Hu YZ, et al. Treatment of obesity and type 2 diabetes mellitus by laparoscopic Roux-en-Y gastric bypass. Zhonghua Wei Chang Wai Ke Za Zhi. Aug. 2010;13(8):594-7. [pmid: 20737312].
511 Yang K. A review of yoga programs for four leading risk factors of chronic diseases. Evid Based Complement Alternat Med. Dec. 2007;4(4):487-91. [pmid: 18227916].
512 Yates T, K K, Bull F, Gorely T, Davies MJ. The role of physical activity in the management of impaired glucose tolerance: a systematic review. Diabetologia. Jun. 2007;50(6):1116-26. [pmid: 17415549].
513 Zehetner J, H F, Triaca H, Klaiber Ch. A 6-year experience with the Swedish adjustable gastric band Prospective long-term audit of laparoscopic gastric banding. Surg Endosc. Jan. 2005;19(1):21-8. [pmid: 15549627].
514 Zingmond DS, M ML, Ko CY. Hospitalization before and after gastric bypass surgery. JAMA. Oct. 19. 2005;294(15):1918-24. [pmid: 16234498].
515 Zlabek JA, G MS, Larson CJ, Mathiason MA, Lambert PJ, Kothari SN. The effect of laparoscopic gastric bypass surgery on dyslipidemia in severely obese patients. Surg Obes Relat Dis. Nov-Dec. 2005;1(6):537-42. [pmid: 16925287].
516 Zorrilla PG, S RJ, Salinas-Martinez AM. Vertical banded gastroplasty-gastric bypass with and without the interposition of jejunum: preliminary report. Obes Surg. Feb. 1999;9(1):29-32. [pmid: 10065577].

## Reject Non Systematic Review

1 Anvari M. Use of metabolic surgery for the treatment of type 2 diabetes. Canadian Journal of Diabetes. 2011;35(2):99-108.
2 Jackson L. Translating the Diabetes Prevention Program Into Practice: A Review of Community Interventions. The Diabetes Educator. March. 1. 2009. 2009;35(2):309-20. [pmid: 19321809].
3 Kelley DE, G BH. Effects of physical activity on insulin action and glucose tolerance in obesity. Med Sci Sports Exerc. Nov. 1999;31(11 Suppl):S619-23. [pmid: 10593537].
4 Pappachan JM, Chacko EC, Arunagirinathan G, et al. Management of hypertension and diabetes in obesity: non-pharmacological measures. Int J Hypertens. 2011;2011:398065. [pmid: 21629871].
5 Rubino F, Schauer PR, Kaplan LM, et al. Metabolic surgery to treat type 2 diabetes: clinical outcomes and mechanisms of action. Annu Rev Med. 2010;61:393-411. [pmid: 20059345].
6 Scheen AJ, VG LG, Despres JP, Pi-Sunyer X, Golay A, Hanotin C. Rimonabant improves cardiometabolic risk profile in obese or overweight subjects: overview of RIO studies. Rev Med Suisse. Aug. 23. 2006;2(76):1916-23. [pmid: 16972542].
7 Schernthaner G, Brix JM, Kopp HP, et al. Cure of type 2 diabetes by metabolic surgery? A critical analysis of the evidence in 2010. Diabetes Care. May. Suppl 2. 2011;34:S355-60. [pmid: 21525482].
8 Schulman AP, dG F, Sinha N, Rubino F. “Metabolic” surgery for treatment of type 2 diabetes mellitus. Endocr Pract. Sep-Oct. 2009;15(6):624-31. [pmid: 19625245].
9 Sherwin RS, A RM, Buse JB, Chin MH, Eddy D, Fradkin J, Ganiats TG, Ginsberg HN, Kahn R, Nwankwo R, Rewers M, Schlessinger L, Stern M, Vinicor F, Zinman B. Prevention or delay of type 2 diabetes. Diabetes Care. Jan. Suppl 1. 2004;27:S47-54. [pmid: 14693925].
10 Varela JE. Bariatric surgery: a cure for diabetes?. Curr Opin Clin Nutr Metab Care. Jul. 2011;14(4):396-401. [pmid: 21505331].
11 Villamizar N, Pryor AD. Safety, effectiveness, and cost effectiveness of metabolic surgery in the treatment of type 2 diabetes mellitus. J Obes. 2011;2011:790683. [pmid: 21113308].

## Reject Non-Surgical Treatment with Follow-Up < 1 year

1 Abbott WG, B VL, Grundy SM, Howard BV. Effects of replacing saturated fat with complex carbohydrate in diets of subjects with NIDDM. Diabetes Care. Feb. 1989;12(2):102-7. [pmid: 2702893].
2 Abramson E, A RA. Treatment of the obese diabetic. A comparative study of placebo, sulfonylurea and phenformin. Metabolism. Mar. 1967;16(3):204-12. [pmid: 5336062].
3 Albarracin CA, F BC, Evans JL, Goldfine ID. Chromium picolinate and biotin combination improves glucose metabolism in treated, uncontrolled overweight to obese patients with type 2 diabetes. Diabetes Metab Res Rev. Jan-Feb. 2008;24(1):41-51. [pmid: 17506119].
4 Amano Y, S M, Lee JS, Kawakubo K, Mori K, Tang AC, Akabayashi A. Glycemic index-based nutritional education improves blood glucose control in Japanese adults: a randomized controlled trial. Diabetes Care. Jul. 2007;30(7):1874-6. [pmid: 17440171].
5 Andersen E, H P, Kindstedt K, Hellstrom K. Effects of a high-protein and low-fat diet vs a low-protein and high-fat diet on blood glucose, serum lipoproteins, and cholesterol metabolism in noninsulin-dependent diabetics. Am J Clin Nutr. Feb. 1987;45(2):406-13. [pmid: 3812340].
6 Anderson JW, B-K V, Hamilton CC, Logan JE, Collins RW, Gustafson NJ. Food-containing hypocaloric diets are as effective as liquid-supplement diets for obese individuals with NIDDM. Diabetes Care. Jun. 1994;17(6):602-4. [pmid: 8082533].
7 Aro A, U M, Voutilainen E, Hersio K, Korhonen T, Siitonen O. Improved diabetic control and hypocholesterolaemic effect induced by long-term dietary supplementation with guar gum in type 2 (insulin-independent) diabetes. Diabetologia. Jul. 1981;21(1):29-33. [pmid: 6268475].
8 Baldi JC, S N. Resistance training improves glycaemic control in obese type 2 diabetic men. Int J Sports Med. Aug. 2003;24(6):419-23. [pmid: 12905089].
9 Barnard RJ, L L, Holly RG, Cherny S, Pritikin N. Response of non-insulin-dependent diabetic patients to an intensive program of diet and exercise. Diabetes Care. Jul-Aug. 1982;5(4):370-4. [pmid: 7151652].
10 Barnes AJ, G KJ, Crowley MF, Bloom A. Effect of short and long term chlorpropamide treatment of insulin release and blood-glucose. Lancet. Jul. 13. 1974;2(7872):69-72. [pmid: 4136696].
11 Barratt R, F G, Millward DJ, Truby H. A randomised controlled trial investigating the effect of an intensive lifestyle intervention v. standard care in adults with type 2 diabetes immediately after initiating insulin therapy. Br J Nutr. May. 2008;99(5):1025-31. [pmid: 18197995].
12 Bianchi R, B V, Bravenboer B, Erkelens DW. Effects of benfluorex on insulin resistance and lipid metabolism in obese type II diabetic patients. Diabetes Care. Apr. 1993;16(4):557-9. [pmid: 8462377].
13 Bjorgaas MR, V JT, Stolen T, Lydersen S, Grill V. Regular use of pedometer does not enhance beneficial outcomes in a physical activity intervention study in type 2 diabetes mellitus. Metabolism. May. 2008;57(5):605-11. [pmid: 18442621].
14 Bogardus C, R E, Robbins DC, Wolfe RR, Horton ES, Sims EA. Effects of physical training and diet therapy on carbohydrate metabolism in patients with glucose intolerance and non-insulin-dependent diabetes mellitus. Diabetes. Apr. 1984;33(4):311-8. [pmid: 6368289].
15 Bonanome A, V A, Lusiani L, Beltramello G, Confortin L, Biffanti S, Sorgato F, Costa F, Pagnan A. Carbohydrate and lipid metabolism in patients with non-insulin-dependent diabetes mellitus: effects of a low-fat, high-carbohydrate diet vs a diet high in monounsaturated fatty acids. Am J Clin Nutr. Sep. 1991;54(3):586-90. [pmid: 1877514].
16 Brand JC, C S, Crossman S, Allen A, Roberts DC, Truswell AS. Low-glycemic index foods improve long-term glycemic control in NIDDM. Diabetes Care. Feb. 1991;14(2):95-101. [pmid: 2060429].
17 Bratusch-Marrain P, D R, Waldhausl W. Weight reduction in obese diabetics: a double-blind study of diethylpropionate (author's transl). Wien Klin Wochenschr. Jun. 22. 1979;91(13):455-8. [pmid: 380178].
18 Brunerova L, S V, Potockova J, Andel M. A comparison of the influence of a high-fat diet enriched in monounsaturated fatty acids and conventional diet on weight loss and metabolic parameters in obese non-diabetic and Type 2 diabetic patients. Diabet Med. May. 2007;24(5):533-40. [pmid: 17381504].
19 Brunzell JD, L RL, Porte D Jr., Bierman EL. Effect of a fat free, high carbohydrate diet on diabetic subjects with fasting hyperglycemia. Diabetes. Feb. 1974;23(2):138-42. [pmid: 4811509].
20 Brunzell JD, L RL, Hazzard WR, Porte D Jr., Bierman EL. Improved glucose tolerance with high carbohydrate feeding in mild diabetes. N Engl J Med. Mar. 11. 1971;284(10):521-4. [pmid: 5100724].
21 Brussard HE, GL JA, Frohlich M, Kluft C, Krans HM. Short-term oestrogen replacement improves insulin resistance, lipids and fibrinolysis in postmenopausal women with NIDDM. Diabetologia. 1997;40:843-9. [pmid: 9243107].
22 Buse JB, H RR, Han J, Kim DD, Fineman MS, Baron AD. Effects of exenatide (exendin-4) on glycemic control over 30 weeks in sulfonylurea-treated patients with type 2 diabetes. Diabetes Care. Nov. 2004;27(11):2628-35. [pmid: 15504997].
23 Cabrera-Pivaral CE, G-P G, Vega-Lopez MG, Centeno-Lopez M. Effects of an educational intervention on plasma levels of LDL cholesterol in type 2 diabetics. Salud Publica Mex. Nov-Dec. 2001;43(6):556-62. [pmid: 11816230].
24 Cabrera-Pivaral CE, G-P G, Vega-Lopez MG, Arias-Merino ED. Impact of participatory education on body mass index and blood glucose in obese type-2 diabetics. Cad Saude Publica. Jan-Feb. 2004;20(1):275-81. [pmid: 15029330].
25 Campbell IW, D C, Patton NW, Broadhead T, Tucker GT, Woods HF. The effect of metformin on glycaemic control, intermediary metabolism and blood pressure in non-insulin-dependent diabetes mellitus. Diabet Med. Jul-Aug. 1987;4(4):337-41. [pmid: 2956047].
26 Campbell LV, B R, Gosper JK, Jupp JJ, Simons LA, Chisholm DJ. Impact of intensive educational approach to dietary change in NIDDM. Diabetes Care. Aug. 1990;13(8):841-7. [pmid: 2209318].
27 Castaneda C, L JE, Munoz-Orians L, Gordon PL, Walsmith J, Foldvari M, Roubenoff R, Tucker KL, Nelson ME. A randomized controlled trial of resistance exercise training to improve glycemic control in older adults with type 2 diabetes. Diabetes Care. Dec. 2002;25(12):2335-41. [pmid: 12453982].
28 Cederholm J. Short-term treatment of glucose intolerance in middle-aged subjects by diet, exercise and sulfonylurea. Ups J Med Sci. 1985;90(3):229-42. [pmid: 4095819].
29 Chapman I, P B, Doran S, Feinle-Bisset C, Wishart J, Strobel S, Wang Y, Burns C, Lush C, Weyer C, Horowitz M. Effect of pramlintide on satiety and food intake in obese subjects and subjects with type 2 diabetes. Diabetologia. May. 2005;48(5):838-48. [pmid: 15843914].
30 Chazova I, A VA, Shlyakhto E. Moxonidine improves glycaemic control in mildly hypertensive, overweight patients: a comparison with metformin. Diabetes Obes Metab. Jul. 2006;8(4):456-65. [pmid: 16776753].
31 Chow CC, K GT, Tsang LW, Yeung VT, Chan JC, Cockram CS. Dexfenfluramine in obese Chinese NIDDM patients. A placebo-controlled investigation of the effects on body weight, glycemic control, and cardiovascular risk factors. Diabetes Care. Jul. 1997;20(7):1122-7. [pmid: 9203448].
32 Christiansen E, S S, Palmvig B, Tauber-Lassen E, Pedersen O. Intake of a diet high in trans monounsaturated fatty acids or saturated fatty acids. Effects on postprandial insulinemia and glycemia in obese patients with NIDDM. Diabetes Care. May. 1997;20(5):881-7. [pmid: 9135961].
33 Colman E, K LI, Rogus E, Coon P, Muller D, Goldberg AP. Weight loss reduces abdominal fat and improves insulin action in middle-aged and older men with impaired glucose tolerance. Metabolism. Nov. 1995;44(11):1502-8. [pmid: 7476341].
34 Coniff RF, S JA, Seaton TB. Long-term efficacy and safety of acarbose in the treatment of obese subjects with non-insulin-dependent diabetes mellitus. Arch Intern Med. Nov. 14. 1994;154(21):2442-8. [pmid: 7979840].
35 Connolly VM, G A, Kesson CM. A study of fluoxetine in obese elderly patients with type 2 diabetes. Diabet Med. May. 1995;12(5):416-8. [pmid: 7648804].
36 Coyle D, P AJ, Tam R. Economic evaluation of pioglitazone hydrochloride in the management of type 2 diabetes mellitus in Canada. Pharmacoeconomics. Suppl 1. 2002;20:31-42. [pmid: 12036382].
37 Cuff DJ, M GS, Martin A, Ignaszewski A, Tildesley HD, Frohlich JJ. Effective exercise modality to reduce insulin resistance in women with type 2 diabetes. Diabetes Care. Nov. 2003;26(11):2977-82. [pmid: 14578226].
38 Damsbo P, H LS, Vaag A, Hother-Nielsen O, Beck-Nielsen H. Irreversibility of the defect in glycogen synthase activity in skeletal muscle from obese patients with NIDDM treated with diet and metformin. Diabetes Care. Sep. 1998;21(9):1489-94. [pmid: 9727896].
39 Davey Smith, GB Y, Svendsen KH, Neaton JD, Haffner SM, Kuller LH. Incidence of type 2 diabetes in the randomized multiple risk factor intervention trial. Ann Intern Med. Mar. 1. 2005;142(5):313-22. [pmid: 15738450].
40 Davidson JA, M SO, Waterhouse BR, Cobitz AR. A 24-week, multicenter, randomized, double-blind, placebo-controlled, parallel-group study of the efficacy and tolerability of combination therapy with rosiglitazone and sulfonylurea in African American and Hispanic American patients with type 2 diabetes inadequately controlled with sulfonylurea monotherapy. Clin Ther. Sep. 2007;29(9):1900-14. [pmid: 18035190].
41 De Filippis E, C K, Ocampo G, Berria R, Buck S, Consoli A, Mandarino LJ. Exercise-induced improvement in vasodilatory function accompanies increased insulin sensitivity in obesity and type 2 diabetes mellitus. J Clin Endocrinol Metab. Dec. 2006;91(12):4903-10. [pmid: 17018657].
42 De Jager J, K A, Lehert P, Bets D, Wulffele MG, Teerlink T, Scheffer PG, Schalkwijk CG, Donker AJ, Stehouwer CD. Effects of short-term treatment with metformin on markers of endothelial function and inflammatory activity in type 2 diabetes mellitus: a randomized, placebo-controlled trial. J Intern Med. Jan. 2005;257(1):100-9. [pmid: 15606381].
43 de Luis DA, I O, Aller R, Cuellar L, Terroba MC, Martin T, Cabezas G, Rojo S, Domingo M. A randomized clinical trial with two enteral diabetes-specific supplements in patients with diabetes mellitus type 2: metabolic effects. Eur Rev Med Pharmacol Sci. Jul-Aug. 2008;12(4):261-6. [pmid: 18727459].
44 Dejager S, R S, Foley JE, Schweizer A. Vildagliptin in drug-naive patients with type 2 diabetes: a 24-week, double-blind, randomized, placebo-controlled, multiple-dose study. Horm Metab Res. Mar. 2007;39(3):218-23. [pmid: 17373638].
45 Dekker MJ, L S, Hudson R, Kilpatrick K, Graham TE, Ross R, Robinson LE. An exercise intervention without weight loss decreases circulating interleukin-6 in lean and obese men with and without type 2 diabetes mellitus. Metabolism. Mar. 2007;56(3):332-8. [pmid: 17292721].
46 Derosa GD, A A, Salvadeo SA, Ferrari I, Gravina A, Fogari E, Maffioli P, Cicero AF. Sibutramine effect on metabolic control of obese patients with type 2 diabetes mellitus treated with pioglitazone. Metabolism. Nov. 2008;57(11):1552-7. [pmid: 18940393].
47 Derosa G, F E, Cicero AF, D'Angelo A, Ciccarelli L, Piccinni MN, Pricolo F, Salvadeo SA, Gravina A, Ferrari I, Fogari R. Blood pressure control and inflammatory markers in type 2 diabetic patients treated with pioglitazone or rosiglitazone and metformin. Hypertens Res. May. 2007;30(5):387-94. [pmid: 17587750].
48 Didangelos TP, T AK, Bousboulas SH, Sambanis CL, Athyros VG, Spanou EA, Dimitriou KC, Pappas SI, Karamanos BG, Karamitsos DT. The ORLIstat and CArdiovascular risk profile in patients with metabolic syndrome and type 2 DIAbetes (ORLICARDIA) Study. Curr Med Res Opin. Sep. 2004;20(9):1393-401. [pmid: 15383188].
49 Dornan TL, H SR, Peck GM, Tattersall RB. Double-blind evaluation of efficacy and tolerability of metformin in NIDDM. Diabetes Care. Apr. 1991;14(4):342-4. [pmid: 2060439].
50 Dunstan DW, D RM, Owen N, Jolley D, De Courten M, Shaw J, Zimmet P. High-intensity resistance training improves glycemic control in older patients with type 2 diabetes. Diabetes Care. Oct. 2002;25(10):1729-36. [pmid: 12351469].
51 Dunstan DW, D RM, Owen N, et al. High resistance training improves glycemic control in older patients with type 2 diabetes. Diabetes Care. 2003;25:1729-36. [pmid: 12351469].
52 Einhorn D, R M, Rosenzweig J, Egan JW, Mathisen AL, Schneider RL. Pioglitazone hydrochloride in combination with metformin in the treatment of type 2 diabetes mellitus: a randomized, placebo-controlled study. The Pioglitazone 027 Study Group. Clin Ther. Dec. 2000;22(12):1395-409. [pmid: 11192132].
53 Eliasson B, G S, Cederholm J, Liang Y, Vercruysse F, Smith U. Weight loss and metabolic effects of topiramate in overweight and obese type 2 diabetic patients: randomized double-blind placebo-controlled trial. Int J Obes (Lond). Jul. 2007;31(7):1140-7. [pmid: 17264849].
54 Fanghanel G, S-R L, Trujillo C, Sotres D, Espinosa-Campos J. Metformin's effects on glucose and lipid metabolism in patients with secondary failure to sulfonylureas. Diabetes Care. Nov. 1996;19(11):1185-9. [pmid: 8908377].
55 Fanghanel G, S U, Sanchez-Reyes L, Sisson D, Sotres D, Torres EM. Effects of metformin on fibrinogen levels in obese patients with type 2 diabetes. Rev Invest Clin. Sep-Oct. 1998;50(5):389-94. [pmid: 9949668].
56 Feinbock C, L A, Klingler A, Egger T, Bielesz GK, Winkler F, Siebenhofer A, Grossschadl F, Frank E, Irsigler K. Prospective multicentre trial comparing the efficacy of, and compliance with, glimepiride or acarbose treatment in patients with type 2 diabetes not controlled with diet alone. Diabetes Nutr Metab. Aug. 2003;16(4):214-21. [pmid: 14768770].
57 Filippatos TD, K DN, Liberopoulos EN, Georgoula M, Mikhailidis DP, Elisaf MS. Effect of orlistat, micronised fenofibrate and their combination on metabolic parameters in overweight and obese patients with the metabolic syndrome: the FenOrli study. Curr Med Res Opin. Dec. 2005;21(12):1997-2006. [pmid: 16368051].
58 Fineman MS, S LZ, Taylor K, Kim DD, Baron AD. Effectiveness of progressive dose-escalation of exenatide (exendin-4) in reducing dose-limiting side effects in subjects with type 2 diabetes. Diabetes Metab Res Rev. Sep-Oct. 2004;20(5):411-7. [pmid: 15343588].
59 Finer N, B SR, Frost GS, Banks LM, Griffiths J. Sibutramine is effective for weight loss and diabetic control in obesity with type 2 diabetes: a randomised, double-blind, placebo-controlled study. Diabetes Obes Metab. Apr. 2000;2(2):105-12. [pmid: 11220522].
60 Fritsche A, S MA, Haring HU. Glimepiride combined with morning insulin glargine, bedtime neutral protamine hagedorn insulin, or bedtime insulin glargine in patients with type 2 diabetes. A randomized, controlled trial. Ann Intern Med. Jun. 17. 2003;138(12):952-9. [pmid: 12809451].
61 Fuh MM, L MM, Jeng CY, Ma F, Chen YD, Reaven GM. Effect of low fat-high carbohydrate diets in hypertensive patients with non-insulin-dependent diabetes mellitus. Am J Hypertens. Jul. 1990;3(7):527-32. [pmid: 2194509].
62 Fujii S, O Y, Okada K, Tanaka S, Seki J, Wada M, Iseki T. Effects of physical training on glucose tolerance and insulin response in diabetics. Osaka City Med J. 1982;28(1):1-8. [pmid: 6763179].
63 Fujioka K, S TB, Rowe E, Jelinek CA, Raskin P, Lebovitz HE, Weinstein SP. Weight loss with sibutramine improves glycaemic control and other metabolic parameters in obese patients with type 2 diabetes mellitus. Diabetes Obes Metab. Jun. 2000;2(3):175-87. [pmid: 11220553].
64 Gannon MC, N FQ. Effect of a high-protein, low-carbohydrate diet on blood glucose control in people with type 2 diabetes. Diabetes. Sep. 2004;53(9):2375-82. [pmid: 15331548].
65 Garg A, B A, Grundy SM, Zhang ZJ, Unger RH. Comparison of a high-carbohydrate diet with a high-monounsaturated-fat diet in patients with non-insulin-dependent diabetes mellitus. N Engl J Med. Sep. 29. 1988;319(13):829-34. [pmid: 3045553].
66 Garg A, G SM, Unger RH. Comparison of effects of high and low carbohydrate diets on plasma lipoproteins and insulin sensitivity in patients with mild NIDDM. Diabetes. Oct. 1992;41(10):1278-85. [pmid: 1397701].
67 Glass LC, Q Y, Lenox S, Kim D, Gates JR, Brodows R, Trautmann M, Bergenstal RM. Effects of exenatide versus insulin analogues on weight change in subjects with type 2 diabetes: a pooled post-hoc analysis. Curr Med Res Opin. Mar. 2008;24(3):639-44. [pmid: 18218179].
68 Goldhaber-Fiebert JD, G-F SN, Tristan ML, Nathan DM. Randomized controlled community-based nutrition and exercise intervention improves glycemia and cardiovascular risk factors in type 2 diabetic patients in rural Costa Rica. Diabetes Care. Jan. 2003;26(1):24-9. [pmid: 12502654].
69 Greco AV, M G, Capristo E, De Gaetano A, Ghirlanda G, Castagneto M. Effects of dexfenfluramine on free fatty acid turnover and oxidation in obese patients with type 2 diabetes mellitus. Metabolism. Feb. 1995;44(2 Suppl 2):57-61. [pmid: 7869940].
70 Gregorio F, A F, Angelici F, Cristallini S, Dini FL, Vespasiani G, Santeusanio F, Filipponi P. Body mass index, blood lactate and therapeutic effectiveness of metformin in type II diabetes mellitus. Medicina (Firenze). Apr-Jun. 1989;9(2):200-4. [pmid: 2682123].
71 Gunton JE, C NW, Hitchman R, Hams G, O'Sullivan C, Foster-Powell K, McElduff A. Chromium supplementation does not improve glucose tolerance, insulin sensitivity, or lipid profile: a randomized, placebo-controlled, double-blind trial of supplementation in subjects with impaired glucose tolerance. Diabetes Care. Mar. 2005;28(3):712-3. [pmid: 15735214].
72 Gupta A, G R, Lal B. Effect of Trigonella foenum-graecum (fenugreek) seeds on glycaemic control and insulin resistance in type 2 diabetes mellitus: a double blind placebo controlled study. J Assoc Physicians India. Nov. 2001;49:1057-61. [pmid: 11868855].
73 Guy-Grand B, D P, Eschwege E, Gin H, Joubert JM, Valensi P. Effects of orlistat on obesity-related diseases - a six-month randomized trial. Diabetes Obes Metab. Sep. 2004;6(5):375-83. [pmid: 15287931].
74 Haisch J, R W. Effectiveness and efficiency of ambulatory diabetes education programs. A comparison of specialty practice and general practice. Dtsch Med Wochenschr. Feb. 18. 2000;125(7):171-6. [pmid: 10719390].
75 Halimi SL, B MA, Grange V. Efficacy and safety of acarbose add-on therapy in the treatment of overweight patients with Type 2 diabetes inadequately controlled with metformin: a double-blind, placebo-controlled study. Diabetes Res Clin Pract. Sep. 2000;50(1):49-56. [pmid: 10936668].
76 Halpern A, M MC, Suplicy H, Zanella MT, Repetto G, Gross J, Jadzinsky M, Barranco J, Aschner P, Ramirez L, Matos AG. Latin-American trial of orlistat for weight loss and improvement in glycaemic profile in obese diabetic patients. Diabetes Obes Metab. May. 2003;5(3):180-8. [pmid: 12681025].
77 Han JR, D B, Sun J, Chen CG, Corkey BE, Kirkland JL, Ma J, Guo W. Effects of dietary medium-chain triglyceride on weight loss and insulin sensitivity in a group of moderately overweight free-living type 2 diabetic Chinese subjects. Metabolism. Jul. 2007;56(7):985-91. [pmid: 17570262].
78 Heilbronn LK, N M, Clifton PM. The effect of high- and low-glycemic index energy restricted diets on plasma lipid and glucose profiles in type 2 diabetic subjects with varying glycemic control. J Am Coll Nutr. Apr. 2002;21(2):120-7. [pmid: 11999539].
79 Hermansen K, K M, Luo E, Fanurik D, Khatami H, Stein P. Efficacy and safety of the dipeptidyl peptidase-4 inhibitor, sitagliptin, in patients with type 2 diabetes mellitus inadequately controlled on glimepiride alone or on glimepiride and metformin. Diabetes Obes Metab. Sep. 2007;9(5):733-45. [pmid: 17593236].
80 Hoffmann J, S M. Efficacy of 24-week monotherapy with acarbose, glibenclamide, or placebo in NIDDM patients. The Essen Study Diabetes Care. Jun. 1994;17(6):561-6. [pmid: 8082525].
81 Holman RR, T RC. Basal normoglycemia attained with chlorpropamide in mild diabetes. Metabolism. May. 1978;27(5):539-47. [pmid: 565457].
82 Horton ES, C C, Gatlin M, Foley J, Mallows S, Shen S. Nateglinide alone and in combination with metformin improves glycemic control by reducing mealtime glucose levels in type 2 diabetes. Diabetes Care. Nov. 2000;23(11):1660-5. [pmid: 11092289].
83 Howard BV, A WG, Swinburn BA. Evaluation of metabolic effects of substitution of complex carbohydrates for saturated fat in individuals with obesity and NIDDM. Diabetes Care. Sep. 1991;14(9):786-95. [pmid: 1959472].
84 Hughes VA, F MA, Fielding RA, Ferrara CM, Elahi D, Evans WJ. Long-term effects of a high-carbohydrate diet and exercise on insulin action in older subjects with impaired glucose tolerance. Am J Clin Nutr. Aug. 1995;62(2):426-33. [pmid: 7625352].
85 Hussain SA. Silymarin as an adjunct to glibenclamide therapy improves long-term and postprandial glycemic control and body mass index in type 2 diabetes. J Med Food. Sep. 2007;10(3):543-7. [pmid: 17887949].
86 Jenkins DJ, K CW, McKeown-Eyssen G, Josse RG, Silverberg J, Booth GL, Vidgen E, Josse AR, Nguyen TH, Corrigan S, Banach MS, Ares S, Mitchell S, Emam A, Augustin LS, Parker TL, Leiter LA. Effect of a low-glycemic index or a high-cereal fiber diet on type 2 diabetes: a randomized trial. JAMA. Dec. 17. 2008;300(23):2742-53. [pmid: 19088352].
87 Jimenez-Cruz A, B-G M, Turnbull WH, Rosales-Garay P, Severino-Lugo I. A flexible, low-glycemic index mexican-style diet in overweight and obese subjects with type 2 diabetes improves metabolic parameters during a 6-week treatment period. Diabetes Care. Jul. 2003;26(7):1967-70. [pmid: 12832297].
88 Josephkutty S, P JM. Comparison of tolbutamide and metformin in elderly diabetic patients. Diabet Med. Jul. 1990;7(6):510-4. [pmid: 2142054].
89 Jun JK, G WC, Mathur R. Effects of pioglitazone on diabetes-related outcomes in Hispanic patients. Am J Health Syst Pharm. Mar. 1. 2003;60(5):469-73. [pmid: 12635453].
90 Kadoglou NP, I F, Liapis CD, Perrea D, Angelopoulou N, Alevizos M. Beneficial effects of combined treatment with rosiglitazone and exercise on cardiovascular risk factors in patients with type 2 diabetes. Diabetes Care. Sep. 2007;30(9):2242-4. [pmid: 17586747].
91 Kang J, R RJ, Hagberg JM, Kelley DE, Goss FL, DaSilva SG, Suminski RR, Utter AC. Effect of exercise intensity on glucose and insulin metabolism in obese individuals and obese NIDDM patients. Diabetes Care. Apr. 1996;19(4):341-9. [pmid: 8729157].
92 Karlander S, A I, Efendic S. Metabolic effects and clinical value of beet fiber treatment in NIDDM patients. Diabetes Res Clin Pract. Feb. 1991;11(2):65-71. [pmid: 1850691].
93 Kattelmann KK, C K, Ren C. The medicine wheel nutrition intervention: a diabetes education study with the Cheyenne River Sioux Tribe. J Am Diet Assoc. Sep. 2009;109(9):1532-9. [pmid: 19699832].
94 Keller U, W C, Messer C, Riesen W. Comparison of a calorie-defined diet with the conventional exchange diet in Type 2 diabetes mellitus. Schweiz Med Wochenschr. Jul. 9. 1991;121(27-28):1014-9. [pmid: 1882212].
95 Kelley DE, W R, Buonocore C, Sturis J, Polonsky K, Fitzsimmons M. Relative effects of calorie restriction and weight loss in noninsulin-dependent diabetes mellitus. J Clin Endocrinol Metab. Nov. 1993;77(5):1287-93. [pmid: 8077323].
96 King AB, A DU, Chinnapongse S. Comparison of glycemic and lipid response to pioglitazone treatment in Mexican-Americans and non-Hispanic Caucasians with type 2 diabetes. Diabetes Care. Jan. 2003;26(1):245-6. [pmid: 12502690].
97 Kipnes MS, K A, Rendell MS, Egan JW, Mathisen AL, Schneider RL. Pioglitazone hydrochloride in combination with sulfonylurea therapy improves glycemic control in patients with type 2 diabetes mellitus: a randomized, placebo-controlled study. Am J Med. Jul. 2001;111(1):10-7. [pmid: 11448655].
98 Kuo CS, P D, Yao CY, Hsieh MC, Kuo SW. Effect of orlistat in overweight poorly controlled Chinese female type 2 diabetic patients: a randomised, double-blind, placebo-controlled study. Int J Clin Pract. Aug. 2006;60(8):906-10. [pmid: 16893433].
99 Kutnowski M, D JC, Friedman H, Kolanowski J, Krzentowski G, Scheen A, Van Gaal L. Fluoxetine therapy in obese diabetic and glucose intolerant patients. Int J Obes Relat Metab Disord. Dec. Suppl 4. 1992;16:S63-6. [pmid: 1338388].
100 Lambers SV, L C, Van Acker K, Calders P. Influence of combined exercise training on indices of obesity, diabetes and cardiovascular risk in type 2 diabetes patients. Clin Rehabil. Jun. 2008;22(6):483-92. [pmid: 18511528].
101 Lamotte M, A L, Lefever A, Nechelput M, Masure J. A health economic model to assess the long-term effects and cost-effectiveness of orlistat in obese type 2 diabetic patients. Diabetes Care. Feb. 2002;25(2):303-8. [pmid: 11815500].
102 Lee S, K JL, Davidson LE, Hudson R, Kilpatrick K, Graham TE, Ross R. Exercise without weight loss is an effective strategy for obesity reduction in obese individuals with and without Type 2 diabetes. J Appl Physiol. Sep. 2005;99(3):1220-5. [pmid: 15860689].
103 Lemon CC, L K, Lohse B, Hubacher DO, Klawitter B, Palta M. Outcomes monitoring of health, behavior, and quality of life after nutrition intervention in adults with type 2 diabetes. J Am Diet Assoc. Dec. 2004;104(12):1805-15. [pmid: 15565074].
104 Leutenegger M, B B, Brun JM, Guillon-Metz F, Martin C, Nicolino-Peltier C, Richard JL, Vannereau D. Added benfluorex in obese insulin-requiring type 2 diabetes. Diabetes Metab. Feb. 1998;24(1):55-61. [pmid: 9534010].
105 Liu GC, C AM, Lardinois CK, Hollenbeck CB, Moore JG, Reaven GM. Moderate weight loss and sulfonylurea treatment of non-insulin-dependent diabetes mellitus. Combined effects. Arch Intern Med. Apr. 1985;145(4):665-9. [pmid: 3885889].
106 Lousley SE, J DB, Slaughter P, Carter RD, Jelfs R, Mann JI. High carbohydrate-high fibre diets in poorly controlled diabetes. Diabet Med. May. 1984;1(1):21-5. [pmid: 6100938].
107 Lucas CP, P S, Stepke T, Kinhal V, Darga LL, Carroll-Michals L, Spafford TR, Kasim S. Achieving therapeutic goals in insulin-using diabetic patients with non-insulin-dependent diabetes mellitus. A weight reduction-exercise-oral agent approach. Am J Med. Sep. 18. 1987;83(3A):3-9. [pmid: 3307404].
108 Ludvik BH, M K, Waldhaeusl W, Hofer A, Prager R, Kautzky-Willer A, Pacini G. The effect of Ipomoea batatas (Caiapo) on glucose metabolism and serum cholesterol in patients with type 2 diabetes: a randomized study. Diabetes Care. Jan. 2002;25(1):239-40. [pmid: 11772921].
109 Ludvik B, N B, Pacini G. Efficacy of Ipomoea batatas (Caiapo) on diabetes control in type 2 diabetic subjects treated with diet. Diabetes Care. Feb. 2004;27(2):436-40. [pmid: 14747225].
110 Luis Bautista J, B C, Dirnberger G, Atherton T. Efficacy and safety profile of glimepiride in Mexican American Patients with type 2 diabetes mellitus: a randomized, placebo-controlled study. Clin Ther. Jan. 2003;25(1):194-209. [pmid: 12637120].
111 Maeda H, Y R, Hirao K, Tochikubo O. Effects of agar (kanten) diet on obese patients with impaired glucose tolerance and type 2 diabetes. Diabetes Obes Metab. Jan. 2005;7(1):40-6. [pmid: 15642074].
112 Maheux P, D F, Bourque J, Garon J, Chiasson JL. Fluoxetine improves insulin sensitivity in obese patients with non-insulin-dependent diabetes mellitus independently of weight loss. Int J Obes Relat Metab Disord. Feb. 1997;21(2):97-102. [pmid: 9043962].
113 Markovic TP, C LV, Balasubramanian S, Jenkins AB, Fleury AC, Simons LA, Chisholm DJ. Beneficial effect on average lipid levels from energy restriction and fat loss in obese individuals with or without type 2 diabetes. Diabetes Care. May. 1998;21(5):695-700. [pmid: 9589226].
114 Markovic TP, J AB, Campbell LV, Furler SM, Kraegen EW, Chisholm DJ. The determinants of glycemic responses to diet restriction and weight loss in obesity and NIDDM. Diabetes Care. May. 1998;21(5):687-94. [pmid: 9589225].
115 Mattoo V, E D, Widel M, Duran S, Fajardo C, Strand J, Knight D, Grossman L, Oakley D, Tan M. Metabolic effects of pioglitazone in combination with insulin in patients with type 2 diabetes mellitus whose disease is not adequately controlled with insulin therapy: results of a six-month, randomized, double-blind, prospective, multicenter, parallel-group study. Clin Ther. May. 2005;27(5):554-67. [pmid: 15978304].
116 McAuley KA, W SM, Mann JI, Goulding A, Chisholm A, Wilson N, Story G, McLay RT, Harper MJ, Jones IE. Intensive lifestyle changes are necessary to improve insulin sensitivity: a randomized controlled trial. Diabetes Care. Mar. 2002;25(3):445-52. [pmid: 11874928].
117 McKibbin CL, P TL, Norman G, Patrick K, Jin H, Roesch S, Mudaliar S, Barrio C, O'Hanlon K, Griver K, Sirkin A, Jeste DV. A lifestyle intervention for older schizophrenia patients with diabetes mellitus: a randomized controlled trial. Schizophr Res. Sep. 2006;86(1-3):36-44. [pmid: 16842977].
118 McLaughlin T, C S, Lamendola C, Abbasi F, Schaaf P, Basina M, Reaven G. Clinical efficacy of two hypocaloric diets that vary in overweight patients with type 2 diabetes: comparison of moderate fat versus carbohydrate reductions. Diabetes Care. Jul. 2007;30(7):1877-9. [pmid: 17475941].
119 Meckling KA, OS C, Saari D. Comparison of a low-fat diet to a low-carbohydrate diet on weight loss, body composition, and risk factors for diabetes and cardiovascular disease in free-living, overweight men and women. J Clin Endocrinol Metab. Jun. 2004;89(6):2717-23. [pmid: 15181047].
120 Meneilly GS, G N, Tildesley H, Habener JF, Egan JM, Elahi D. Effects of 3 months of continuous subcutaneous administration of glucagon-like peptide 1 in elderly patients with type 2 diabetes. Diabetes Care. Oct. 2003;26(10):2835-41. [pmid: 14514588].
121 Miller CK, E L, Kissling G, Sanville L. Evaluation of a theory-based nutrition intervention for older adults with diabetes mellitus. J Am Diet Assoc. Aug. 2002;102(8):1069-81. [pmid: 12171451].
122 Miyashita Y, K N, Ohtsuka M, Ozaki H, Itoh Y, Oyama T, Uetake T, Ariga K, Shirai K. Beneficial effect of low carbohydrate in low calorie diets on visceral fat reduction in type 2 diabetic patients with obesity. Diabetes Res Clin Pract. Sep. 2004;65(3):235-41. [pmid: 15331203].
123 Miyazaki Y, M A, Matsuda M, Glass L, Mahankali S, Ferrannini E, Cusi K, Mandarino LJ, DeFronzo RA. Improved glycemic control and enhanced insulin sensitivity in type 2 diabetic subjects treated with pioglitazone. Diabetes Care. Apr. 2001;24(4):710-9. [pmid: 11315836].
124 Muchmore DB, S J, Miller M. Self-monitoring of blood glucose in overweight type 2 diabetic patients. Acta Diabetol. Dec. 1994;31(4):215-9. [pmid: 7888692].
125 Nagulesparan M, S PJ, Bennion LJ, Unger RH, Bennett PH. Diminished effect of caloric restriction on control of hyperglycemia with increasing known duration of type II diabetes mellitus. J Clin Endocrinol Metab. Sep. 1981;53(3):560-8. [pmid: 7021580].
126 Nam SY, K KR, Cha BS, Song YD, Lim SK, Lee HC, Huh KB. Low-dose growth hormone treatment combined with diet restriction decreases insulin resistance by reducing visceral fat and increasing muscle mass in obese type 2 diabetic patients. Int J Obes Relat Metab Disord. Aug. 2001;25(8):1101-7. [pmid: 11477493].
127 Nathan DM, R A, Godine JE. Glyburide or insulin for metabolic control in non-insulin-dependent diabetes mellitus. A randomized, double-blind study. Ann Intern Med. Mar. 1988;108(3):334-40. [pmid: 3124685].
128 Nolan JJ, J NP, Patwardhan R, Deacon LF. Rosiglitazone taken once daily provides effective glycaemic control in patients with Type 2 diabetes mellitus. Diabet Med. Apr. 2000;17(4):287-94. [pmid: 10821295].
129 Noury J, N A. Comparative three-month study of the efficacies of metformin and gliclazide in the treatment of NIDD. Diabete Metab. May. 1991;17(1 Pt 2):209-12. [pmid: 1936478].
130 Nuttall FQ, G MC. The metabolic response to a high-protein, low-carbohydrate diet in men with type 2 diabetes mellitus. Metabolism. Feb. 2006;55(2):243-51. [pmid: 16423633].
131 Osei K, B B. Dietary fructose as a natural sweetener in poorly controlled type 2 diabetes: a 12-month crossover study of effects on glucose, lipoprotein and apolipoprotein metabolism. Diabet Med. Aug. 1989;6(6):506-11. [pmid: 2527132].
132 Osei K, F J, Bossetti BM, Holland GC. Metabolic effects of fructose as a natural sweetener in the physiologic meals of ambulatory obese patients with type II diabetes. Am J Med. Aug. 1987;83(2):249-55. [pmid: 3618627].
133 Paniagua JA, dlS AG, Sanchez E, Romero I, Vidal-Puig A, Berral FJ, Escribano A, Moyano MJ, Perez-Martinez P, Lopez-Miranda JJ, Perez-Jimenez F. A MUFA-rich diet improves posprandial glucose, lipid and GLP-1 responses in insulin-resistant subjects. J Am Coll Nutr. Oct. 2007;26(5):434-44. [pmid: 17914131].
134 Parker B, N M, Luscombe N, Clifton P. Effect of a high-protein, high-monounsaturated fat weight loss diet on glycemic control and lipid levels in type 2 diabetes. Diabetes Care. Mar. 2002;25(3):425-30. [pmid: 11874925].
135 Pathan MF, L ZA, Nazneen NE, Mili SU. Orlistat as an adjunct therapy in type 2 obese diabetic patients treated with sulphonylurea: a Bangladesh experience. Bangladesh Med Res Counc Bull. Apr. 2004;30(1):1-8. [pmid: 15376463].
136 Pereira MA, J DR Jr., Pins JJ, Raatz SK, Gross MD, Slavin JL, Seaquist ER. Effect of whole grains on insulin sensitivity in overweight hyperinsulinemic adults. Am J Clin Nutr. May. 2002;75(5):848-55. [pmid: 11976158].
137 Peters Harmel AL, K DM, Buse JB, Boyle PJ, Marchetti A, Lau H. Impact of adjunctive thiazolidinedione therapy on blood lipid levels and glycemic control in patients with type 2 diabetes. Curr Med Res Opin. 2004;20(2):215-23. [pmid: 15006017].
138 Petersen KF, D S, Befroy D, Lehrke M, Hendler RE, Shulman GI. Reversal of nonalcoholic hepatic steatosis, hepatic insulin resistance, and hyperglycemia by moderate weight reduction in patients with type 2 diabetes. Diabetes. Mar. 2005;54(3):603-8. [pmid: 15734833].
139 Phillips LS, G G, Miller E, Patwardhan R, Rappaport EB, Salzman A. Once- and twice-daily dosing with rosiglitazone improves glycemic control in patients with type 2 diabetes. Diabetes Care. Feb. 2001;24(2):308-15. [pmid: 11213884].
140 Pi-Sunyer FX, S A, Mills D, Dejager S. Efficacy and tolerability of vildagliptin monotherapy in drug-naive patients with type 2 diabetes. Diabetes Res Clin Pract. Apr. 2007;76(1):132-8. [pmid: 17223217].
141 Pijl H, O S, Matsuda M, Miyazaki Y, Mahankali A, Kumar V, Pipek R, Iozzo P, Lancaster JL, Cincotta AH, DeFronzo RA. Bromocriptine: a novel approach to the treatment of type 2 diabetes. Diabetes Care. Aug. 2000;23(8):1154-61. [pmid: 10937514].
142 Pontiroli AE, P M, Piatti PM, Cassisa C, Camisasca R, Pozza G. Benfluorex in obese noninsulin dependent diabetes mellitus patients poorly controlled by insulin: a double blind study versus placebo. J Clin Endocrinol Metab. Oct. 1996;81(10):3727-32. [pmid: 8855830].
143 Poon T, N P, Shen L, Mihm M, Taylor K, Fineman M, Kim D. Exenatide improves glycemic control and reduces body weight in subjects with type 2 diabetes: a dose-ranging study. Diabetes Technol Ther. Jun. 2005;7(3):467-77. [pmid: 15929678].
144 Poppitt SD, K GF, Prentice AM, Williams DE, Sonnemans HM, Valk EE, Robinson E, Wareham NJ. Long-term effects of ad libitum low-fat, high-carbohydrate diets on body weight and serum lipids in overweight subjects with metabolic syndrome. Am J Clin Nutr. Jan. 2002;75(1):11-20. [pmid: 11756055].
145 Pratley RE, R J, Pi-Sunyer FX, Banerji MA, Schweizer A, Couturier A, Dejager S. Management of type 2 diabetes in treatment-naive elderly patients: benefits and risks of vildagliptin monotherapy. Diabetes Care. Dec. 2007;30(12):3017-22. [pmid: 17878242].
146 Rabkin SW, B E, Wilson A, Streja DA. A randomized clinical trial comparing behavior modification and individual counseling in the nutritional therapy of non-insulin-dependent diabetes mellitus: comparison of the effect on blood sugar, body weight, and serum lipids. Diabetes Care. Jan-Feb. 1983;6(1):50-6. [pmid: 6341015].
147 Rains SG, W GA, Richmond W, Elkeles RS. The effect of glibenclamide and metformin on serum lipoproteins in type 2 diabetes. Diabet Med. Oct. 1988;5(7):653-8. [pmid: 2975549].
148 Raskin P, R M, Riddle MC, Dole JF, Freed MI, Rosenstock J. A randomized trial of rosiglitazone therapy in patients with inadequately controlled insulin-treated type 2 diabetes. Diabetes Care. Jul. 2001;24(7):1226-32. [pmid: 11423507].
149 Rasmussen OW, T C, Hansen KW, Vesterlund M, Winther E, Hermansen K. Effects on blood pressure, glucose, and lipid levels of a high-monounsaturated fat diet compared with a high-carbohydrate diet in NIDDM subjects. Diabetes Care. Dec. 1993;16(12):1565-71. [pmid: 8117360].
150 Rave K, R K, Dellweg S, Heise T, tom Dieck H. Improvement of insulin resistance after diet with a whole-grain based dietary product: results of a randomized, controlled cross-over study in obese subjects with elevated fasting blood glucose. Br J Nutr. Nov. 2007;98(5):929-36. [pmid: 17562226].
151 Reaven GM. Beneficial effect of moderate weight loss in older patients with non-insulin-dependent diabetes mellitus poorly controlled with insulin. J Am Geriatr Soc. Feb. 1985;33(2):93-5. [pmid: 3881506].
152 Reboussin DM, G DC Jr., Lipkin EW, Herrington DM, Summerson J, Steffes M, Crouse RJ 3rd, Jovanovic L, Feinglos MN, Probstfield JL, Banerji MA, Pettitt DJ, Williamson J. The combination oral and nutritional treatment of late-onset diabetes mellitus (CONTROL DM) trial results. Diabet Med. Oct. 2004;21(10):1082-9. [pmid: 15384954].
153 Richter H, K K, Kleinwechter H, Demandt N, Meincke G, Dabelstein A, Weisser B. Effects of a telephone intervention in patients with type 2 diabetes. Dtsch Med Wochenschr. Oct. 2008;133(43):2203-8. [pmid: 18924053].
154 Riddle MC, R J, Gerich J. The treat-to-target trial: randomized addition of glargine or human NPH insulin to oral therapy of type 2 diabetic patients. Diabetes Care. Nov. 2003;26(11):3080-6. [pmid: 14578243].
155 Rizkalla SW, T L, Laromiguiere M, Huet D, Boillot J, Rigoir A, Elgrably F, Slama G. Improved plasma glucose control, whole-body glucose utilization, and lipid profile on a low-glycemic index diet in type 2 diabetic men: a randomized controlled trial. Diabetes Care. Aug. 2004;27(8):1866-72. [pmid: 15277409].
156 Rodriguez-Villar C, M JM, Casals E, Perez-Heras A, Zambon D, Gomis R, Ros E. High-monounsaturated fat, olive oil-rich diet has effects similar to a high-carbohydrate diet on fasting and postprandial state and metabolic profiles of patients with type 2 diabetes. Metabolism. Dec. 2000;49(12):1511-7. [pmid: 11145109].
157 Roger P, A J, Drain P. Addition of benfluorex to biguanide improves glycemic control in obese non-insulin-dependent diabetes: a double-blind study versus placebo. J Diabetes Complications. Mar-Apr. 1999;13(2):62-7. [pmid: 10432168].
158 Ronnemaa T, M J, Puukka P, Kuusi T. Effects of long-term physical exercise on serum lipids, lipoproteins and lipid metabolizing enzymes in type 2 (non-insulin-dependent) diabetic patients. Diabetes Res. Feb. 1988;7(2):79-84. [pmid: 3396267].
159 Rosenstock J, E D, Hershon K, Glazer NB, Yu S. Efficacy and safety of pioglitazone in type 2 diabetes: a randomised, placebo-controlled study in patients receiving stable insulin therapy. Int J Clin Pract. May. 2002;56(4):251-7. [pmid: 12074206].
160 Rosenstock J, R J, Bush M, Yang F, Stewart M. Potential of albiglutide, a long-acting GLP-1 receptor agonist, in type 2 diabetes: a randomized controlled trial exploring weekly, biweekly, and monthly dosing. Diabetes Care. Oct. 2009;32(10):1880-6. [pmid: 19592625].
161 Ruderman NB, G OP, Johansen K. The effect of physical training on glucose tolerance and plasma lipids in maturity-onset diabetes. Diabetes. Jan. Suppl 1. 1979;28:89-92. [pmid: 761721].
162 Rudnick PA, T KW. Effect of Prolonged Carbohydrate Restriction on Serum-Insulin Levels in Mild Diabetes. Br Med J. May. 8. 1965;1(5444):1225-8. [pmid: 14275022].
163 Sahin M, T NB, Ertugrul D, Tanaci N, Guvener ND. Effects of metformin or rosiglitazone on serum concentrations of homocysteine, folate, and vitamin B12 in patients with type 2 diabetes mellitus. J Diabetes Complications. Mar-Apr. 2007;21(2):118-23. [pmid: 17331860].
164 Saldalamacchia G, M P, Pacioni D, Giordano C, Tia VN, Pellegrino S, Lilli S, Riccardi G, Rivellese AA. Weight loss in obese type 2 diabetic patients on an intensive therapeutic programme: Importance of an initial short hospitalization period. Nutr Metab Cardiovasc Dis. Feb. 2008;18(2):e1-2. [pmid: 18029160].
165 Salman S, S F, Satman I, Yilmaz Y, Ozer E, Sengul A, Demirel HO, Karsidag K, Dinccag N, Yilmaz MT. Comparison of acarbose and gliclazide as first-line agents in patients with type 2 diabetes. Curr Med Res Opin. 2001;16(4):296-306. [pmid: 11268714].
166 Sanchez-Tainta A, E R, Bullo M, Corella D, Gomez-Gracia E, Fiol M, Algorta J, Covas MI, Lapetra J, Zazpe I, Ruiz-Gutierrez V, Ros E, Martinez-Gonzalez MA. Adherence to a Mediterranean-type diet and reduced prevalence of clustered cardiovascular risk factors in a cohort of 3,204 high-risk patients. Eur J Cardiovasc Prev Rehabil. Oct. 2008;15(5):589-93. [pmid: 18830087].
167 Sargrad KR, H C, Mozzoli M, Boden G. Effect of high protein vs high carbohydrate intake on insulin sensitivity, body weight, hemoglobin A1c, and blood pressure in patients with type 2 diabetes mellitus. J Am Diet Assoc. Apr. 2005;105(4):573-80. [pmid: 15800559].
168 Scarlett JA, G RS, Griffin J, Olefsky JM, Kolterman OG. Insulin treatment reverses the insulin resistance of type II diabetes mellitus. Diabetes Care. Jul-Aug. 1982;5(4):353-63. [pmid: 6759075].
169 Schnack C, R G, Luger A, Schernthaner G. Effects of the alpha-glucosidase inhibitor 1 desoxynojirimycin (Bay m 1099) on postprandial blood glucose, serum insulin and C-peptide levels in type II diabetic patients. Eur J Clin Pharmacol. 1986;30(4):417-9. [pmid: 3527720].
170 Scott R, W M, Sanchez M, Stein P. Efficacy and tolerability of the dipeptidyl peptidase-4 inhibitor sitagliptin as monotherapy over 12 weeks in patients with type 2 diabetes. Int J Clin Pract. Jan. 2007;61(1):171-80. [pmid: 17156104].
171 Segal KR, E A, Abalos A, Albu J, Blando L, Tomas MB, Pi-Sunyer FX. Effect of exercise training on insulin sensitivity and glucose metabolism in lean, obese, and diabetic men. J Appl Physiol. Dec. 1991;71(6):2402-11. [pmid: 1778939].
172 Shahar DR, A R, Elhayany A, Vardi H, Fraser D. Does dairy calcium intake enhance weight loss among overweight diabetic patients?. Diabetes Care. Mar. 2007;30(3):485-9. [pmid: 17327309].
173 Shaw KM, W MS, Campbell DB, Ward JD. Home blood glucose monitoring in non-insulin-dependent diabetics: the effect of gliclazide on blood glucose and weight control, a multicentre trial. Diabet Med. Nov. 1985;2(6):484-90. [pmid: 2951123].
174 Shi YF, P CY, Hill J, Gao Y. Orlistat in the treatment of overweight or obese Chinese patients with newly diagnosed Type 2 diabetes. Diabet Med. Dec. 2005;22(12):1737-43. [pmid: 16401321].
175 Simpson HC, S RW, Lousley S, Carter RD, Geekie M, Hockaday TD, Mann JI. A high carbohydrate leguminous fibre diet improves all aspects of diabetic control. Lancet. Jan. 3. 1981;1(8210):1-5. [pmid: 6109047].
176 Slama G, S A, Hautecouverture M, Tchobroutsky G. Double blind clinical trial of mazindol on weight loss blood glucose, plasma insulin and serum lipids in overweight diabetic patients. Diabete Metab. Sep. 1978;4(3):193-9. [pmid: 361463].
177 Smutok MA, R C, Kokkinos PF, Farmer CM, Dawson PK, DeVane J, Patterson J, Goldberg AP, Hurley BF. Effects of exercise training modality on glucose tolerance in men with abnormal glucose regulation. Int J Sports Med. Aug. 1994;15(6):283-9. [pmid: 7822064].
178 Solomon TP, H JM, Kelly KR, Cook MD, Riccardi M, Rocco M, Kashyap SR, Barkoukis H, Kirwan JP. Randomized trial on the effects of a 7-d low-glycemic diet and exercise intervention on insulin resistance in older obese humans. Am J Clin Nutr. Nov. 2009;90(5):1222-9. [pmid: 19793849].
179 Sun J, W Y, Chen X, Chen Y, Feng Y, Zhang X, Pan Y, Hu T, Xu J, Du L, Zhou W, Zhao H, Riley RE, Mustad VA. An integrated intervention program to control diabetes in overweight Chinese women and men with type 2 diabetes. Asia Pac J Clin Nutr. 2008;17(3):514-24. [pmid: 18818173].
180 Suter SL, N JJ, Wallace P, Gumbiner B, Olefsky JM. Metabolic effects of new oral hypoglycemic agent CS-045 in NIDDM subjects. Diabetes Care. Feb. 1992;15(2):193-203. [pmid: 1547676].
181 Takami K, T N, Nakashima K, Takami R, Hayashi M, Ozeki S, Yamada A, Kokubo Y, Sato M, Kawachi S, Sasaki A, Yasuda K. Effects of dietary treatment alone or diet with voglibose or glyburide on abdominal adipose tissue and metabolic abnormalities in patients with newly diagnosed type 2 diabetes. Diabetes Care. Apr. 2002;25(4):658-62. [pmid: 11919121].
182 Tankova T, D G, Lazarova M, Dakovska L, Kirilov G, Koev D. Sibutramine in the treatment of obesity in type 2 diabetic patients and in nondiabetic subjects. Acta Diabetol. Dec. 2004;41(4):146-53. [pmid: 15660196].
183 Tariq SH, K E, Thomas DR, Thomson K, Philpot C, Chapel DL, Morley JE. The use of a no-concentrated-sweets diet in the management of type 2 diabetes in nursing homes. J Am Diet Assoc. Dec. 2001;101(12):1463-6. [pmid: 11762744].
184 Trovati M, C Q, Cavalot F, Vitali S, Banaudi C, Lucchina PG, Fiocchi F, Emanuelli G, Lenti G. Influence of physical training on blood glucose control, glucose tolerance, insulin secretion, and insulin action in non-insulin-dependent diabetic patients. Diabetes Care. Sep-Oct. 1984;7(5):416-20. [pmid: 6389056].
185 Turner-McGrievy GM, B ND, Cohen J, Jenkins DJ, Gloede L, Green AA. Changes in nutrient intake and dietary quality among participants with type 2 diabetes following a low-fat vegan diet or a conventional diabetes diet for 22 weeks. J Am Diet Assoc. Oct. 2008;108(10):1636-45. [pmid: 18926128].
186 Uusitupa M, L M, Sarlund H, Majander H, Takala J, Penttila I. Long term effects of a very low calorie diet on metabolic control and cardiovascular risk factors in the treatment of obese non-insulin-dependent diabetics. Int J Obes. Suppl 2. 1989;13:163-4. [pmid: 2613415].
187 Valensi P, M I, Le Magoarou M, Paries J, Perret G, Attali JR. Short-term effects of continuous subcutaneous insulin infusion treatment on insulin secretion in non-insulin-dependent overweight patients with poor glycaemic control despite maximal oral anti-diabetic treatment. Diabetes Metab. Feb. 1997;23(1):51-7. [pmid: 9059766].
188 Van Duyn MA, L TA, McIvor ME, Behall KM, Michnowski JE, Mendeloff AI. Nutritional risk of high-carbohydrate, guar gum dietary supplementation in non-insulin-dependent diabetes mellitus. Diabetes Care. Sep-Oct. 1986;9(5):497-503. [pmid: 3021407].
189 Vancea DM, MV José Nelson, Pires Maria Izabel, Fernandes, Reis Marco Antonio, Moura Rafael Brandão, Dib Sergio Atala. Effect of frequency of physical exercise on glycemic control and body composition in type 2 diabetic patients. Arquivos Brasileiros de Cardiologia. 2009;92:23-30. [pmid: 19219261].
190 Verdy M, C L, Verdy I, Belanger R, Bolte E, Chiasson JL. Fenfluramine in the treatment of non-insulin-dependent diabetics: hypoglycemic versus anorectic effect. Int J Obes. 1983;7(4):289-97. [pmid: 6629637].
191 Vernon MC, M J, Transue M, Yancy WS, Westman EC. Clinical experience of a carbohydrate-restricted diet: effect on diabetes mellitus. Metab Syndr Relat Disord. Sep. 2003;1(3):233-7. [pmid: 18370667].
192 Vukovic M, L M, Kalezic N, Gvozdenovic BS. The effect of metformin on fasting and postprandial insulin secretion in obese patients with diabetes mellitus type 2. Srp Arh Celok Lek. Jul-Aug. 2007;135(7-8):447-52. [pmid: 17929538].
193 Vuksan V, J DJ, Spadafora P, Sievenpiper JL, Owen R, Vidgen E, Brighenti F, Josse R, Leiter LA, Bruce-Thompson C. Konjac-mannan (glucomannan) improves glycemia and other associated risk factors for coronary heart disease in type 2 diabetes. A randomized controlled metabolic trial. Diabetes Care. Jun. 1999;22(6):913-9. [pmid: 10372241].
194 Wales JK. The effect of fenfluramine on obese, maturity-onset diabetic patients. Acta Endocrinol (Copenh). Apr. 1979;90(4):616-23. [pmid: 373358].
195 Wall JR, P DA, Oakley WG. Effect of carbohydrate restriction in obese diabetics: relationship of control to weight loss. Br Med J. Mar. 10. 1973;1(5853):577-8. [pmid: 4694404].
196 Wang TF, P D, Li JC, Tsai WC, Tsai CC, Yao CY, Chang ET, Hsieh MC, Su KY, Kuo SW. Effects of sibutramine in overweight, poorly controlled Chinese female type 2 diabetic patients: a randomised, double-blind, placebo-controlled study. Int J Clin Pract. Jul. 2005;59(7):746-50. [pmid: 15963197].
197 Watanabe M, O A, Shimamoto K, Ueshima H. Short-term effectiveness of an individual counseling program for impaired fasting glucose and mild type 2 diabetes in Japan: a multi-center randomized control trial. Asia Pac J Clin Nutr. 2007;16(3):489-97. [pmid: 17704031].
198 Weinsier RL, S A, Herrera MG, Assal JP, Soeldner JS, Gleason RE. High- and low-carbohydrate diets in diabetes mellitus. Study of effects on diabetic control, insulin secretion, and blood lipids. Ann Intern Med. Mar. 1974;80(3):332-41. [pmid: 4816173].
199 Willey KA, M LM, Overland JE, Yue DK. The effects of dexfenfluramine on blood glucose control in patients with type 2 diabetes. Diabet Med. May. 1992;9(4):341-3. [pmid: 1600704].
200 Willms B, R D. Comparison of acarbose and metformin in patients with Type 2 diabetes mellitus insufficiently controlled with diet and sulphonylureas: a randomized, placebo-controlled study. Diabet Med. Sep. 1999;16(9):755-61. [pmid: 10510952].
201 Wing RR, N MP, Epstein LH, Koeske R. Calorie-counting compared to exchange system diets in the treatment of overweight patients with type II diabetes. Addict Behav. 1986;11(2):163-8. [pmid: 3739801].
202 Winnick JJ, G T, Schuster DP. Resistance training differentially affects weight loss and glucose metabolism of White and African American patients with type 2 diabetes mellitus. Ethn Dis. Spring. 2008;18(2):152-6. [pmid: 18507266].
203 Winnick JJ, S WM, Habash DL, Stout MB, Failla ML, Belury MA, Schuster DP. Short-term aerobic exercise training in obese humans with type 2 diabetes mellitus improves whole-body insulin sensitivity through gains in peripheral, not hepatic insulin sensitivity. J Clin Endocrinol Metab. Mar. 2008;93(3):771-8. [pmid: 18073312].
204 Wolffenbuttel BH, W RF, Van Koetsveld PM, Verschoor L. Limitations of diet therapy in patients with non-insulin-dependent diabetes mellitus. Int J Obes. 1989;13(2):173-82. [pmid: 2744929].
205 Woo J, S MM, Tong P, Ko GT, Lee Z, Chan J, Chow FC. Effectiveness of a lifestyle modification programme in weight maintenance in obese subjects after cessation of treatment with Orlistat. J Eval Clin Pract. Dec. 2007;13(6):853-9. [pmid: 18070255].
206 Wycherley TP, B GD, Noakes M, Buckley JD, Clifton PM. Effect of caloric restriction with and without exercise training on oxidative stress and endothelial function in obese subjects with type 2 diabetes. Diabetes Obes Metab. Nov. 2008;10(11):1062-73. [pmid: 18435772].
207 Yamanouchi K, S T, Chikada K, Nishikawa T, Ito K, Shimizu S, Ozawa N, Suzuki Y, Maeno H, Kato K, et al. Daily walking combined with diet therapy is a useful means for obese NIDDM patients not only to reduce body weight but also to improve insulin sensitivity. Diabetes Care. Jun. 1995;18(6):775-8. [pmid: 7555502].
208 Yancy WS Jr., Olsen MK, Guyton JR, Bakst RP, Westman EC. A low-carbohydrate, ketogenic diet versus a low-fat diet to treat obesity and hyperlipidemia: a randomized, controlled trial. Ann Intern Med. May. 18. 2004;140(10):769-77. [pmid: 15148063].
209 Yip I, G VL, DeShields S, Saltsman P, Bellman M, Thames G, Murray S, Wang HJ, Elashoff R, Heber D. Liquid meal replacements and glycemic control in obese type 2 diabetes patients. Obes Res. Nov. Suppl 4. 2001;9:341S-7S. [pmid: 11707563].
210 Ziemer DC, B KJ, Panayioto RM, El-Kebbi IM, Musey VC, Anderson LA, Wanko NS, Fowke ML, Brazier CW, Dunbar VG, Slocum W, Bacha GM, Gallina DL, Cook CB, Phillips LS. A simple meal plan emphasizing healthy food choices is as effective as an exchange-based meal plan for urban African Americans with type 2 diabetes. Diabetes Care. Jun. 2003;26(6):1719-24. [pmid: 12766100].

## Reject Published Before 1990

1 Ackerman NB. Observations on the improvements in carbohydrate metabolism in diabetic and other morbidly obese patients after jejunoileal bypass. Surg Gynecol Obstet. May. 1981;152(5):581-6. [pmid: 7013122].
2 Bendezu R, W RG, Green SG, Hallberg MC, Marsters RW. Certain metabolic consequences of jejunoileal bypass. Am J Clin Nutr. Apr. 1976;29(4):366-70. [pmid: 1266786].
3 Buchwald H. Ileal bypass in the treatment of the hyperlipidemias. J Atheroscler Res. Jul-Aug. 1969;10(1):1-4. [pmid: 5380901].
4 Buchwald H. Lowering of Cholesterol Absorption and Blood Levels by Ileal Exclusion. Experimental Basis and Preliminary Clinical Report. Circulation. May. 1964;29:713-20. [pmid: 14156865].
5 Buchwald H, M RB, Frantz ID Jr., Varco RL. Cholesterol reduction by partial ileal bypass in a pediatric population. Surgery. Dec. 1970;68(6):1101-11. [pmid: 5483243].
6 Buchwald H, V RL. Partial ileal bypass for hypercholesterolemia and atherosclerosis. Surg Gynecol Obstet. Jun. 1967;124(6):1231-8. [pmid: 6024201].
7 Dobrea GM, W RG, Johnson MW. The effect of rapid weight loss due to jejunoileal bypass on total cholesterol and high-density lipoprotein. Am J Clin Nutr. Oct. 1981;34(10):1994-6. [pmid: 7293931].
8 Flickinger EG, P WJ, Meelheim HD, Sinar DR, Blose IL, Thomas FT. The Greenville gastric bypass Progress report at 3 years. Ann Surg. May. 1984;199(5):555-62. [pmid: 6721605].
9 Gleysteen JJ, B JJ. Improvement in heart disease risk factors after gastric bypass. Arch Surg. Jun. 1983;118(6):681-4. [pmid: 6847361].
10 Goldberg RB, W RB, Landau RL. Changes in plasma apolipoproteins A-I, A-II, and B, and lipoprotein cholesterol after jejunoileal bypass. Gastroenterology. Apr. 1983;84(4):732-6. [pmid: 6402411].
11 Gomez CA. Gastroplasty in the surgical treatment of morbid obesity. Am J Clin Nutr. Feb. 1980;33(2 Suppl):406-15. [pmid: 7355812].
12 Gonen B, H JD, Schonfeld G. Lipoprotein levels in morbidly obese patients with massive, surgically-induced weight loss. Metabolism. May. 1983;32(5):492-6. [pmid: 6843360].
13 Halverson JD, K J, Cave A, Permutt A, Santiago J. Altered glucose tolerance, insulin response, and insulin sensitivity after massive weight reduction subsequent to gastric bypass. Surgery. Aug. 1982;92(2):235-40. [pmid: 7048596].
14 Hardie GH, S G, CoBabe T. Gastric bypass: a safe, effective procedure?. Wis Med J. Nov. 1979;78(11):34-8. [pmid: 516786].
15 Herbst CA, H TA, Gwynne JT, Buckwalter JA. Gastric bariatric operation in insulin-treated adults. Surgery. Feb. 1984;95(2):209-14. [pmid: 6364435].
16 Hocking MP, D MC, O'Leary JP, Woodward ER. Jejunoileal bypass for morbid obesity. Late follow-up in 100 cases. N Engl J Med. Apr. 28. 1983;308(17):995-9. [pmid: 6835318].
17 Holt JB, C CL, Trowbridge PE. Immediate and long-term results of vertical banded gastroplasty for morbid obesity. Conn Med. Oct. 1987;51(10):638-42. [pmid: 3677666].
18 Hughes TA, G JT, Switzer BR, Herbst C, White G. Effects of caloric restriction and weight loss on glycemic control, insulin release and resistance, and atherosclerotic risk in obese patients with type II diabetes mellitus. Am J Med. Jul. 1984;77(1):7-17. [pmid: 6377892].
19 Lewis LA, T RB Jr., Page IH. Effects of jejunocolic shunt on obesity, serum lipoproteins, lipids, and electrolytes. Arch Intern Med. Jan. 1966;117(1):4-16. [pmid: 5900488].
20 Mason EE, I C. Gastric bypass in obesity. Surg Clin North Am. Dec. 1967;47(6):1345-51. [pmid: 6073761].
21 Moore RB, B H, Varco RL. The effect of partial ileal bypass on plasma lipoproteins. Circulation. Sep. 1980;62(3):469-76. [pmid: 7398005].
22 Naslund I. Gastric bypass versus gastroplasty. A prospective study of differences in two surgical procedures for morbid obesity. Acta Chir Scand Suppl. 1987;536:1-60. [pmid: 3475886].
23 Naslund I, W G, Christoffersson E, Agren G. A prospective randomized comparison of gastric bypass and gastroplasty. Complications and early results. Acta Chir Scand. Nov. 1986;152:681-9. [pmid: 3551425].
24 Olsson SA, P BG, Sorbris R, Nilsson-Ehle P. Effects of weight reduction after gastroplasty on glucose and lipid metabolism. Am J Clin Nutr. Dec. 1984;40(6):1273-80. [pmid: 6391138].
25 Payne JH, D LT. Surgical treatment of obesity. Am J Surg. Aug. 1969;118(2):141-7. [pmid: 5798387].
26 Pories WJ, C JF, Flickinger EG, Meelheim HD, Swanson MS. The control of diabetes mellitus (NIDDM) in the morbidly obese with the Greenville Gastric Bypass. Ann Surg. Sep. 1987;206(3):316-23. [pmid: 3632094].
27 Pories WJ, F EG, Meelheim D, Van Rij AM, Thomas FT. The effectiveness of gastric bypass over gastric partition in morbid obesity: consequence of distal gastric and duodenal exclusion. Ann Surg. Oct. 1982;196(4):389-99. [pmid: 7125726].
28 Quaade F, B O, Stokholm KH, Andersen T. The Copenhagen PLAFA project: a randomized trial of gastroplasty versus very-low-calorie diet in the treatment of severe obesity (preliminary results). Int J Obes. 1981;5(3):257-61. [pmid: 7024154].
29 Ranlov PJ. Serum lipid changes after gastroplasty for morbid obesity. Acta Med Scand. 1984;216(5):503-8. [pmid: 6524454].
30 Rossner S, H D. Serum lipoproteins in massive obesity. A study and after jejunoileal shunt operation. Acta Med Scand. 1978;204(1-2):103-10. [pmid: 210633].
31 Rucker RD Jr., Goldenberg F, Varco RL, Buchwald H. Lipid effects of obesity operations. J Surg Res. Mar. 1981;30(3):229-35. [pmid: 7230770].
32 Sanderson I, D M, Bojm MA. The handling of glucose and insulin response before and after weight loss with jejuno-ileal bypass: a preliminary report. JPEN J Parenter Enteral Nutr. May-Jun. 1983;7(3):274-6. [pmid: 6345839].
33 Schrumpf E, B A, Djoseland O, Fausa O, Flaten O, Skagen DW, Tronier B. The effect of gastric bypass operation on glucose tolerance in obesity. Scand J Gastroenterol Suppl. 1985;107:24-31. [pmid: 3885381].
34 Schwartz RW, S WE, Simpson WS, Griffen WO Jr. Gastric bypass revision: lessons learned from 920 cases. Surgery. Oct. 1988;104(4):806-12. [pmid: 3051478].
35 Scott HW Jr., Dean RH, Younger RK, Butts WH. Changes in hyperlipidemia and hyperlipoproteinemia in morbidly obese patients treated by jejunoileal bypass. Surg Gynecol Obstet. Mar. 1974;138(3):353-8. [pmid: 4811320].
36 Scott HW Jr., Dean RH, Shull HJ, Gluck F. Results of jejunoileal bypass in two hundred patients with morbid obesity. Surg Gynecol Obstet. Nov. 1977;145(5):661-73. [pmid: 910208].
37 Sherman CD Jr., May AG, Nye W, Waterhouse C. Clinical and metabolic studies following bowel by-passing for obesity. Ann N Y Acad Sci. Oct. 8. 1965;131(1):614-22. [pmid: 5216995].
38 Shibata HR, M JR, Long RC. Metabolic effects of controlled jejunocolic bypass. Arch Surg. Sep. 1967;95(3):413-28. [pmid: 6035465].
39 Solhaug JH, G I. Metabolic changes after jejuno-ileal bypass for obesity. Scand J Gastroenterol. 1978;13(2):169-75. [pmid: 635457].
40 Sugerman HJ, S JV, Birkenhauer R. A randomized prospective trial of gastric bypass versus vertical banded gastroplasty for morbid obesity and their effects on sweets versus non-sweets eaters. Ann Surg. Jun. 1987;205(6):613-24. [pmid: 3296971].
41 Vessby B, B M, Lindahl B, Lithell H, Thoren L, Werner I. Serum lipoprotein lipid and apolipoprotein concentrations in grossly obese patients before and after jejuno-ileal shunt operation. Eur J Clin Invest. Feb. 1981;11(1):49-54. [pmid: 6783429].
42 Yale CE. Gastric surgery for morbid obesity. Complications and long-term weight control. Arch Surg. Aug. 1989;124(8):941-6. [pmid: 2757508].

## Reject Treatment Not of Interest

1 Ahn SM, Pomp A, Rubino F. Metabolic surgery for type 2 diabetes. Ann N Y Acad Sci. Nov. 2010;1212(1):E37-45. [pmid: 21732953].
2 Babio N, B M, Basora J, Martinez-Gonzalez MA, Fernandez-Ballart J, Marquez-Sandoval F, Molina C, Salas-Salvado J. Adherence to the Mediterranean diet and risk of metabolic syndrome and its components. Nutr Metab Cardiovasc Dis. Oct. 2009;19(8):563-70. [pmid: 19176282].
3 Belcher G, L C, Goh KL, Edwards G, Valbuena M. Cardiovascular effects of treatment of type 2 diabetes with pioglitazone, metformin and gliclazide. Int J Clin Pract. Sep. 2004;58(9):833-7. [pmid: 15529516].
4 Berne C. A randomized study of orlistat in combination with a weight management programme in obese patients with Type 2 diabetes treated with metformin. Diabet Med. May. 2005;22(5):612-8. [pmid: 15842517].
5 Berry M. Metabolic surgery in non obese type 2 diabetic patients. Obesity Surgery. 2010;20(8):981.
6 Birkeland KI, R U, Hanssen KF, Vaaler S. NIDDM: a rapid progressive disease. Results from a long-term, randomised, comparative study of insulin or sulphonylurea treatment. Diabetologia. Dec. 1996;39(12):1629-33. [pmid: 8960854].
7 Bravard A, Lefai E, Meugnier E, et al. FTO is increased in muscle during type 2 diabetes, and its overexpression in myotubes alters insulin signaling, enhances lipogenesis and ROS production, and induces mitochondrial dysfunction. Diabetes. Jan. 2011;60(1):258-68. [pmid: 20943749].
8 Buse JB, K DC, Nielsen LL, Guan X, Bowlus CL, Holcombe JH, Maggs DG, Wintle ME. Metabolic effects of two years of exenatide treatment on diabetes, obesity, and hepatic biomarkers in patients with type 2 diabetes: an interim analysis of data from the open-label, uncontrolled extension of three double-blind, placebo-controlled trials. Clin Ther. Jan. 2007;29(1):139-53. [pmid: 17379054].
9 Campbell IW, M DG, Chalmers J, McBain AM, Brown IR. One year comparative trial of metformin and glipizide in type 2 diabetes mellitus. Diabete Metab. Jul-Aug. 1994;20(4):394-400. [pmid: 7843470].
10 Castagneto MD, G A, Mingrone G, Tacchino R, Nanni G, Capristo E, Benedetti G, Tataranni PA, Greco AV. Normalization of Insulin Sensitivity in the Obese Patient after Stable Weight Reduction with Biliopancreatic Diversion. Obes Surg. May. 1994;4(2):161-8. [pmid: 10742775].
11 Chiasson JL, J RG, Hunt JA, Palmason C, Rodger NW, Ross SA, Ryan EA, Tan MH, Wolever TM. The efficacy of acarbose in the treatment of patients with non-insulin-dependent diabetes mellitus. A multicenter controlled clinical trial. Ann Intern Med. Dec. 15. 1994;121(12):928-35. [pmid: 7734015].
12 Clark M, H SE. Implementing a psychological intervention to improve lifestyle self-management in patients with type 2 diabetes. Patient Educ Couns. Mar. 2001;42(3):247-56. [pmid: 11164324].
13 Clarke BF, D LJ. Comparison of chlorpropamide and metformin treatment on weight and blood-glucose response of uncontrolled obese diabetics. Lancet. Jan. 20. 1968;1(7534):123-6. [pmid: 4169605].
14 Dansinger ML, G JA, Griffith JL, Selker HP, Schaefer EJ. Comparison of the Atkins, Ornish, Weight Watchers, and Zone diets for weight loss and heart disease risk reduction: a randomized trial. JAMA. Jan. 5. 2005;293(1):43-53. [pmid: 15632335].
15 de Fine Olivarius N, A AH, Siersma V, Richelsen B, Beck-Nielsen H. Changes in patient weight and the impact of antidiabetic therapy during the first 5 years after diagnosis of diabetes mellitus. Diabetologia. Sep. 2006;49(9):2058-67. [pmid: 16841232].
16 De Paula AL, S AR, Macedo A, Ribamar J, Mancini M, Halpern A, Vencio S. Prospective randomized controlled trial comparing 2 versions of laparoscopic ileal interposition associated with sleeve gastrectomy for patients with type 2 diabetes with BMI 21-34 kg/m(2). Surg Obes Relat Dis. May-Jun. 2010;6(3):296-304. [pmid: 20096647].
17 DePaula AL, M AL, Schraibman V, Mota BR, Vencio S. Hormonal evaluation following laparoscopic treatment of type 2 diabetes mellitus patients with BMI 20-34. Surg Endosc. Aug. 2009;23(8):1724-32. [pmid: 18830747].
18 DePaula AL, M AL, Mota BR, Schraibman V. Laparoscopic ileal interposition associated to a diverted sleeve gastrectomy is an effective operation for the treatment of type 2 diabetes mellitus patients with BMI 21-29. Surg Endosc. Jun. 2009;23(6):1313-20. [pmid: 18830750].
19 DePaula AL, M AL, Rassi N, Vencio S, Machado CA, Mota BR, Silva LQ, Halpern A, Schraibman V. Laparoscopic treatment of metabolic syndrome in patients with type 2 diabetes mellitus. Surg Endosc. Dec. 2008;22(12):2670-8. [pmid: 18347866].
20 DePaula AL, M AL, Rassi N, Machado CA, Schraibman V, Silva LQ, Halpern A. Laparoscopic treatment of type 2 diabetes mellitus for patients with a body mass index less than 35. Surg Endosc. Mar. 2008;22(3):706-16. [pmid: 17704886].
21 DePaula AL, S AR, DePaula CC, Halpern A, Vencio S. Impact on dyslipidemia of the laparoscopic ileal interposition associated to sleeve gastrectomy in type 2 diabetic patients. J Gastrointest Surg. Aug. 2010;14(8):1319-25. [pmid: 20556664].
22 Depaula AL, S A, Halpern A, Vencio S. Thirty-Day Morbidity and Mortality of the Laparoscopic Ileal Interposition Associated with Sleeve Gastrectomy for the Treatment of Type 2 Diabetic Patients with BMI <35: An Analysis of 454 Consecutive Patients. World J Surg. 2010. Nov. 3. [pmid: 21052999].
23 Derosa G, C AF, Murdolo G, Ciccarelli L, Fogari R. Comparison of metabolic effects of orlistat and sibutramine treatment in Type 2 diabetic obese patients. Diabetes Nutr Metab. Aug. 2004;17(4):222-9. [pmid: 15575343].
24 Derosa G, C AF, Gaddi A, Ragonesi PD, Fogari E, Bertone G, Ciccarelli L, Piccinni MN. Metabolic effects of pioglitazone and rosiglitazone in patients with diabetes and metabolic syndrome treated with glimepiride: a twelve-month, multicenter, double-blind, randomized, controlled, parallel-group trial. Clin Ther. May. 2004;26(5):744-54. [pmid: 15220018].
25 Derosa GD, A A, Ragonesi PD, Ciccarelli L, Piccinni MN, Pricolo F, Salvadeo SA, Montagna L, Gravina A, Ferrari I, Paniga S, Cicero AF. Metabolic effects of pioglitazone and rosiglitazone in patients with diabetes and metabolic syndrome treated with metformin. Intern Med J. Feb. 2007;37(2):79-86. [pmid: 17229249].
26 Ferzli GS, D E, Ciaglia M, Bluth MH, Gonzalez A, Fingerhut A. Clinical improvement after duodenojejunal bypass for nonobese type 2 diabetes despite minimal improvement in glycemic homeostasis. World J Surg. May. 2009;33(5):972-9. [pmid: 19288284].
27 Draeger KE, W-P F, Lomp HJ, Schuler E, Rosskamp R. Long-term treatment of type 2 diabetic patients with the new oral antidiabetic agent glimepiride (Amaryl): a double-blind comparison with glibenclamide. Horm Metab Res. Sep. 1996;28(9):419-25. [pmid: 8911976].
28 Gerstein HC, M ME, Byington RP, Goff DC Jr., Bigger JT, Buse JB, Cushman WC, Genuth S, Ismail-Beigi F, Grimm RH Jr., Probstfield JL, Simons-Morton DG, Friedewald WT. Effects of intensive glucose lowering in type 2 diabetes. N Engl J Med. Jun. 12. 2008;358(24):2545-59. [pmid: 18539917].
29 Goel R, Amin P, Goel M, et al. Early resolution of type 2 diabetes mellitus by laparoscopic ileal transposition with sleeve gastrectomy surgery in 23 - 35 BMI patients. Obesity Reviews. 2010;11:254.
30 Goke B, H K, Kerr D, Calle Pascual A, Schweizer A, Foley J, Shao Q, Dejager S. Efficacy and safety of vildagliptin monotherapy during 2-year treatment of drug-naive patients with type 2 diabetes: comparison with metformin. Horm Metab Res. Dec. 2008;40(12):892-5. [pmid: 18726829].
31 Harrower AD. Comparison of diabetic control in type 2 (non-insulin dependent) diabetic patients treated with different sulphonylureas. Curr Med Res Opin. 1985;9(10):676-80. [pmid: 3935376].
32 Hollander PA, L P, Fineman MS, Maggs DG, Shen LZ, Strobel SA, Weyer C, Kolterman OG. Pramlintide as an adjunct to insulin therapy improves long-term glycemic and weight control in patients with type 2 diabetes: a 1-year randomized controlled trial. Diabetes Care. Mar. 2003;26(3):784-90. [pmid: 12610038].
33 Holman RR, T KI, Farmer AJ, Davies MJ, Keenan JF, Paul S, Levy JC. Addition of biphasic, prandial, or basal insulin to oral therapy in type 2 diabetes. N Engl J Med. Oct. 25. 2007;357(17):1716-30. [pmid: 17890232].
34 Horton ES, W F, Ghazzi MN, Venable TC, Whitcomb RW. Troglitazone in combination with sulfonylurea restores glycemic control in patients with type 2 diabetes. The Troglitazone Study Group. Diabetes Care. Sep. 1998;21(9):1462-9. [pmid: 9727892].
35 James S, AJ L, Raghunathan TE, Strogatz DS, Furth ED, Khazanie PG. Physical activity and NIDDM in African-Americans. The Pitt County Study. Diabetes Care. Apr. 1998;21(4):555-62. [pmid: 9571342].
36 Josse RG. Acarbose for the treatment of type II diabetes: the results of a Canadian multi-centre trial. Diabetes Res Clin Pract. Aug. 1995;28(Suppl):S167-72. [pmid: 8529510].
37 Kahn SE, H SM, Heise MA, Herman WH, Holman RR, Jones NP, Kravitz BG, Lachin JM, O'Neill MC, Zinman B, Viberti G. Glycemic durability of rosiglitazone, metformin, or glyburide monotherapy. N Engl J Med. Dec. 7. 2006;355(23):2427-43. [pmid: 17145742].
38 Keyserling TC, A AS, Samuel-Hodge CD, Ingram AF, Skelly AH, Elasy TA, Johnston LF, Cole AS, Henriquez-Roldan CF. A diabetes management program for African American women with type 2 diabetes. Diabetes Educ. Sep-Oct. 2000;26(5):796-805. [pmid: 11140007].
39 Knowler WC, H RF, Edelstein SL, Barrett-Connor E, Ehrmann DA, Walker EA, Fowler SE, Nathan DM, Kahn SE. Prevention of type 2 diabetes with troglitazone in the Diabetes Prevention Program. Diabetes. Apr. 2005;54(4):1150-6. [pmid: 15793255].
40 Kumar KV, U S, Gupta N, Naik V, Kumar P, Bhaskar P, Modi KD. Ileal interposition with sleeve gastrectomy for control of type 2 diabetes. Diabetes Technol Ther. Dec. 2009;11(12):785-9. [pmid: 20001679].
41 Laaksonen M, K Paul, Rissanen Harri, Härkänen Tommi, Virtala Esa, Marniemi Jukka, Aromaa Arpo, Heliövaara Markku, Reunanen Antti. The relative importance of modifiable potential risk factors of type 2 diabetes: a meta-analysis of two cohorts. European Journal of Epidemiology. 2010;25(2):115-24. [pmid: 20012885].
42 Manson JE, N DM, Krolewski AS, Stampfer MJ, Willett WC, Hennekens CH. A prospective study of exercise and incidence of diabetes among US male physicians. JAMA. Jul. 1. 1992;268(1):63-7. [pmid: 1608115].
43 Merriam PA, T TL, Rosal MC, Olendzki BC, Ma Y, Pagoto SL, Ockene IS. Methodology of a diabetes prevention translational research project utilizing a community-academic partnership for implementation in an underserved Latino community. BMC Med Res Methodol. 2009;9:20. [pmid: 19284663].
44 Mertes G. Safety and efficacy of acarbose in the treatment of Type 2 diabetes: data from a 5-year surveillance study. Diabetes Res Clin Pract. Jun. 2001;52(3):193-204. [pmid: 11323089].
45 Ong CR, M LM, Constantino MI, Twigg SM, Yue DK. Long-term efficacy of metformin therapy in nonobese individuals with type 2 diabetes. Diabetes Care. Nov. 2006;29(11):2361-4. [pmid: 17065668].
46 Paajanen H, Suuronen S, Nordstrom P, et al. Laparoscopic versus open cholecystectomy in diabetic patients and postoperative outcome. Surg Endosc. Mar. 2011;25(3):764-70. [pmid: 20661751].
47 Paisey R, E RS, Hambley J, Magill P. The effects of chlorpropamide and insulin on serum lipids, lipoproteins and fractional triglyceride removal. Diabetologia. Aug. 1978;15(2):81-5. [pmid: 700275].
48 Ramos AC, GN MP, de Souza YM, Galvao M, Murakami AH, Silva AC, Canseco EG, Santamaria R, Zambrano TA. Laparoscopic duodenal-jejunal exclusion in the treatment of type 2 diabetes mellitus in patients with BMI<30 kg/m2 (LBMI). Obes Surg. Mar. 2009;19(3):307-12. [pmid: 18987919].
49 Ratner RE, M D, Nielsen LL, Stonehouse AH, Poon T, Zhang B, Bicsak TA, Brodows RG, Kim DD. Long-term effects of exenatide therapy over 82 weeks on glycaemic control and weight in over-weight metformin-treated patients with type 2 diabetes mellitus. Diabetes Obes Metab. Jul. 2006;8(4):419-28. [pmid: 16776749].
50 Raz I, S V, Stein P. Influence of small-group education sessions on glucose homeostasis in NIDDM. Diabetes Care. Jan. 1988;11(1):67-71. [pmid: 3338379].
51 Ribisl PM, L W, Jaramillo SA, Jakicic JM, Stewart KJ, Bahnson J, Bright R, Curtis JF, Crow RS, Soberman JE. Exercise capacity and cardiovascular/metabolic characteristics of overweight and obese individuals with type 2 diabetes: the Look AHEAD clinical trial. Diabetes Care. Oct. 2007;30(10):2679-84. [pmid: 17644623].
52 Riddle MC, H RR, Poon TH, Zhang B, Mac SM, Holcombe JH, Kim DD, Maggs DG. Exenatide elicits sustained glycaemic control and progressive reduction of body weight in patients with type 2 diabetes inadequately controlled by sulphonylureas with or without metformin. Diabetes Metab Res Rev. Nov-Dec. 2006;22(6):483-91. [pmid: 16634116].
53 Schernthaner G, M DR, Charbonnel B, Hanefeld M, Brunetti P. Efficacy and safety of pioglitazone versus metformin in patients with type 2 diabetes mellitus: a double-blind, randomized trial. J Clin Endocrinol Metab. Dec. 2004;89(12):6068-76. [pmid: 15579760].
54 Schouten R, vD FM, van Gemert WG, Greve JW. Conversion of vertical banded gastroplasty to Roux-en-Y gastric bypass results in restoration of the positive effect on weight loss and co-morbidities: evaluation of 101 patients. Obes Surg. May. 2007;17(5):622-30. [pmid: 17658021].
55 Schrier RW, E RO, Mehler PS, Hiatt WR. Appropriate blood pressure control in hypertensive and normotensive type 2 diabetes mellitus: a summary of the ABCD trial. Nat Clin Pract Nephrol. Aug. 2007;3(8):428-38. [pmid: 17653121].
56 Suter M, G V, Heraief E, Zysset F, Calmes JM. Laparoscopic gastric banding. Surg Endosc. Sep. 2003;17(9):1418-25. [pmid: 12802666].
57 Tan M, J D, Gonzalez Galvez G, Antunez O, Fabian G, Flores-Lozano F, Zuniga Guajardo S, Garza E, Morales H, Konkoy C, Herz M. Effects of pioglitazone and glimepiride on glycemic control and insulin sensitivity in Mexican patients with type 2 diabetes mellitus: A multicenter, randomized, double-blind, parallel-group trial. Clin Ther. May. 2004;26(5):680-93. [pmid: 15220012].
58 Taylor KG, J WG, Matthews KA, Wright AD. A prospective study of the effect of 12 months treatment on serum lipids and apolipoproteins A-I and B in Type 2 (non-insulin-dependent) diabetes. Diabetologia. Dec. 1982;23(6):507-10. [pmid: 6818080].
59 Tinoco A, El-Kadre L, Aquiar L, et al. Short-Term and Mid-Term Control of Type 2 Diabetes Mellitus by Laparoscopic Sleeve Gastrectomy with Ileal Interposition. World J Surg. 2011. Jul. 9. [pmid: 21744166].
60 UK Prospective Diabetes Study (UKPDS) Group. Effect of intensive blood-glucose control with metformin on complications in overweight patients with type 2 diabetes (UKPDS 34). The Lancet. 1998;352(9131):854-65.
61 Vencio SAC, Stival AR, De Paula AL. Assessment of insulin secretion and insulin sensitivity with the hyperglycaemic clamp in type 2 diabetic patients with BMI below 35 Kg/m2 submitted to ileal interposition associated to sleeve gastrectomy. Diabetologia. 2010;53:S43.
62 Wake N, H A, Katayama T, Kishikawa H, Ohkubo Y, Sakai M, Araki E, Shichiri M. Cost-effectiveness of intensive insulin therapy for type 2 diabetes: a 10-year follow-up of the Kumamoto study. Diabetes Res Clin Pract. Jun. 2000;48(3):201-10. [pmid: 10802159].
63 Yates T, D M, Gorely T, Bull F, Khunti K. Rationale, design and baseline data from the Pre-diabetes Risk Education and Physical Activity Recommendation and Encouragement (PREPARE) programme study: a randomized controlled trial. Patient Educ Couns. Nov. 2008;73(2):264-71. [pmid: 18653305].
64 Zinman B, H SB, Neuman J, Gerstein HC, Retnakaran RR, Raboud J, Qi Y, Hanley AJ. Low-dose combination therapy with rosiglitazone and metformin to prevent type 2 diabetes mellitus (CANOE trial): a double-blind randomised controlled study. Lancet. Jul. 10. 2010;376(9735):103-11. [pmid: 20605202].

## Reject Non-Surgical Already Included in Systematic Reviews

1 Absetz P, V R, Oldenburg B, Heinonen H, Nissinen A, Fogelholm M, Ilvesmaki V, Talja M, Uutela A. Type 2 diabetes prevention in the “real world”: one-year results of the GOAL Implementation Trial. Diabetes Care. Oct. 2007;30(10):2465-70. [pmid: 17586741].
2 Ackermann RT, F EA, Brizendine E, Zhou H, Marrero DG. Translating the Diabetes Prevention Program into the community. The DEPLOY Pilot Study. Am J Prev Med. Oct. 2008;35(4):357-63. [pmid: 18779029].
3 Aldana SG, B M, Smith R, Yanowitz FG, Adams T, Loveday L, Arbuckle J, LaMonte MJ. The diabetes prevention program: a worksite experience. AAOHN J. Nov. 2005;53(11):499-505. quiz 6-7. [pmid: 16309012].
4 Anderson JW, W K. Long-term effects of high-carbohydrate, high-fiber diets on glucose and lipid metabolism: a preliminary report on patients with diabetes. Diabetes Care. Mar-Apr. 1978;1(2):77-82. [pmid: 729433].
5 Anderssen SA, H I, Urdal P, Torjesen PA, Holme I. Improved carbohydrate metabolism after physical training and dietary intervention in individuals with the “atherothrombogenic syndrome'Oslo Diet and Exercise Study (ODES). A randomized trial. J Intern Med. Oct. 1996;240(4):203-9. [pmid: 8918511].
6 Ash S, R MM, Yeo S, Morrison G, Carey D, Capra S. Effect of intensive dietetic interventions on weight and glycaemic control in overweight men with Type II diabetes: a randomised trial. Int J Obes Relat Metab Disord. Jul. 2003;27(7):797-802. [pmid: 12821964].
7 Balducci S, L F, Di Mario U, Fallucca F. Is a long-term aerobic plus resistance training program feasible for and effective on metabolic profiles in type 2 diabetic patients?. Diabetes Care. Mar. 2004;27(3):841-2. [pmid: 14988317].
8 Banerji MA, C RL, Lebovitz HE. Prolongation of near-normoglycemic remission in black NIDDM subjects with chronic low-dose sulfonylurea treatment. Diabetes. Apr. 1995;44(4):466-70. [pmid: 7698517].
9 Barnard ND, C Joshua, Jenkins David JA, Turner-McGrievy Gabrielle, Gloede Lise, Green Amber, Ferdowsian Hope. A low-fat vegan diet and a conventional diabetes diet in the treatment of type 2 diabetes: a randomized, controlled, 74-wk clinical trial. Am J Clin Nutr. May. 1. 2009. 2009;89(5):1588S-96. [pmid: 19339401].
10 Ben-Avraham S, H-B Ilana, Schwarzfuchs Dan, Shai Iris. Dietary strategies for patients with type 2 diabetes in the era of multi-approaches; review and results from the Dietary Intervention Randomized Controlled Trial (DIRECT). Diabetes Research and Clinical Practice. 2009;86(Supplement 1):S41-S8. [pmid: 20115931].
11 Blonde L, K EJ, Han J, Zhang B, Mac SM, Poon TH, Taylor KL, Trautmann ME, Kim DD, Kendall DM. Interim analysis of the effects of exenatide treatment on A1C, weight and cardiovascular risk factors over 82 weeks in 314 overweight patients with type 2 diabetes. Diabetes Obes Metab. Jul. 2006;8(4):436-47. [pmid: 16776751].
12 Blonk MC, J MA, Biesheuvel EH, Weeda-Mannak WL, Heine RJ. Influences on weight loss in type 2 diabetic patients: little long-term benefit from group behaviour therapy and exercise training. Diabet Med. Jun. 1994;11(5):449-57. [pmid: 8088122].
13 Bloomgarden ZT, K W, Metzger MJ, Brothers M, Nechemias C, Bookman J, Faierman D, Ginsberg-Fellner F, Rayfield E, Brown WV. Randomized, controlled trial of diabetic patient education: improved knowledge without improved metabolic status. Diabetes Care. May-Jun. 1987;10(3):263-72. [pmid: 3297575].
14 Bo S, C G, Baldi C, Benini L, Dusio F, Forastiere G, Lucia C, Nuti C, Durazzo M, Cassader M, Gentile L, Pagano G. Effectiveness of a lifestyle intervention on metabolic syndrome. A randomized controlled trial. J Gen Intern Med. Dec. 2007;22(12):1695-703. [pmid: 17922167].
15 Boltri JM, D-S YM, Seale JP, Shellenberger S, Okosun IS, Cornelius ME. Diabetes prevention in a faith-based setting: results of translational research. J Public Health Manag Pract. Jan-Feb. 2008;14(1):29-32. [pmid: 18091037].
16 Bosch J, L E, Pogue J, Arnold JM, Dagenais GR, Yusuf S. Long-term effects of ramipril on cardiovascular events and on diabetes: results of the HOPE study extension. Circulation. Aug. 30. 2005;112(9):1339-46. [pmid: 16129815].
17 Bourn DM, M JI, McSkimming BJ, Waldron MA, Wishart JD. Impaired glucose tolerance and NIDDM: does a lifestyle intervention program have an effect?. Diabetes Care. Nov. 1994;17(11):1311-9. [pmid: 7821173].
18 Brinkworth GD, N M, Keogh JB, Luscombe ND, Wittert GA, Clifton PM. Long-term effects of a high-protein, low-carbohydrate diet on weight control and cardiovascular risk markers in obese hyperinsulinemic subjects. Int J Obes Relat Metab Disord. May. 2004;28(5):661-70. [pmid: 15007396].
19 Brinkworth GD, N M, Buckley JD, Keogh JB, Clifton PM. Long-term effects of a very-low-carbohydrate weight loss diet compared with an isocaloric low-fat diet after 12 mo. Am J Clin Nutr. Jul. 2009;90(1):23-32. [pmid: 19439458].
20 Brinkworth GD, N M, Parker B, Foster P, Clifton PM. Long-term effects of advice to consume a high-protein, low-fat diet, rather than a conventional weight-loss diet, in obese adults with type 2 diabetes: one-year follow-up of a randomised trial. Diabetologia. Oct. 2004;47(10):1677-86. [pmid: 15480538].
21 Brown SA, B SA, Kouzekanani K, Garcia AA, Winchell M, Hanis CL. Dosage effects of diabetes self-management education for Mexican Americans: the Starr County Border Health Initiative. Diabetes Care. Mar. 2005;28(3):527-32. [pmid: 15735182].
22 Bruce DG, C EM, Campbell LV, Chisholm DJ. Insulin therapy in patients with poorly controlled non-insulin dependent diabetes mellitus. Med J Aust. Mar. 2. 1987;146(5):240-2. [pmid: 3547052].
23 Brun JF, B S, Mercier J, Jaussent A, Picot MC, Prefaut C. Cost-sparing effect of twice-weekly targeted endurance training in type 2 diabetics: a one-year controlled randomized trial. Diabetes Metab. Jun. 2008;34(3):258-65. [pmid: 18468933].
24 Buchanan TA, X AH, Peters RK, Kjos SL, Marroquin A, Goico J, Ochoa C, Tan S, Berkowitz K, Hodis HN, Azen SP. Preservation of pancreatic beta-cell function and prevention of type 2 diabetes by pharmacological treatment of insulin resistance in high-risk hispanic women. Diabetes. Sep. 2002;51(9):2796-803. [pmid: 12196473].
25 Buse JB, G B, Mathias NP, Nelson DM, Faja BW, Whitcomb RW. Troglitazone use in insulin-treated type 2 diabetic patients. The Troglitazone Insulin Study Group. Diabetes Care. Sep. 1998;21(9):1455-61. [pmid: 9727891].
26 Calle-Pascual AL, R C, Camacho F, Sanchez R, Martin-Alvarez PJ, Yuste E, Hidalgo I, Diaz RJ, Calle JR, Charro AL. Behaviour modification in obese subjects with type 2 diabetes mellitus. Diabetes Res Clin Pract. Feb. 1992;15(2):157-62. [pmid: 1563332].
27 Campbell EM, R S, Moffitt PS, Sanson-Fisher RW. The relative effectiveness of educational and behavioral instruction programs for patients with NIDDM: a randomized trial. Diabetes Educ. Jul-Aug. 1996;22(4):379-86. [pmid: 8846745].
28 Carr DB, U KM, Boyko EJ, Asberry PJ, Hull RL, Kodama K, Callahan HS, Matthys CC, Leonetti DL, Schwartz RS, Kahn SE, Fujimoto WY. A reduced-fat diet and aerobic exercise in Japanese Americans with impaired glucose tolerance decreases intra-abdominal fat and improves insulin sensitivity but not beta-cell function. Diabetes. Feb. 2005;54(2):340-7. [pmid: 15677490].
29 Chiasson JL, J Robert G, Gomis Ramon, Hanefeld Markolf, Karasik Avraham, Laakso Markku. Acarbose for prevention of type 2 diabetes mellitus: the STOP-NIDDM randomised trial. The Lancet. 2002;359(9323):2072-7.
30 Chiasson JL, J RG, Gomis R, Hanefeld M, Karasik A, Laakso M. Acarbose for the prevention of Type 2 diabetes, hypertension and cardiovascular disease in subjects with impaired glucose tolerance: facts and interpretations concerning the critical analysis of the STOP-NIDDM Trial data. Diabetologia. Jun. 2004;47(6):969-75. discussion 76-7. [pmid: 15164169].
31 Chiasson JL, J RG, Gomis R, Hanefeld M, Karasik A, Laakso M. Acarbose treatment and the risk of cardiovascular disease and hypertension in patients with impaired glucose tolerance: the STOP-NIDDM trial. JAMA. Jul. 23. 2003;290(4):486-94. [pmid: 12876091].
32 Christian JG, B DH, Byers TE, Christian KK, Goldstein MG, Bock BC. Clinic-based support to help overweight patients with type 2 diabetes increase physical activity and lose weight. Arch Intern Med. Jan. 28. 2008;168(2):141-6. [pmid: 18227359].
33 Clark M, H SE, Avery L, Simpson R. Effects of a tailored lifestyle self-management intervention in patients with type 2 diabetes. Br J Health Psychol. Sep. 2004;9(Pt 3):365-79. [pmid: 15296683].
34 Clarke P, G A, Adler A, Stevens R, Raikou M, Cull C, Stratton I, Holman R. Cost-effectiveness analysis of intensive blood-glucose control with metformin in overweight patients with type II diabetes (UKPDS No. 51). Diabetologia. Mar. 2001;44(3):298-304. [pmid: 11317659].
35 Collins R, A J, Parish S, Sleigh P, Peto R. MRC/BHF Heart Protection Study of cholesterol-lowering with simvastatin in 5963 people with diabetes: a randomised placebo-controlled trial. Lancet. Jun. 14. 2003;361(9374):2005-16. [pmid: 12814710].
36 Corpeleijn E, F EJ, Jansen EH, Mensink M, Saris WH, de Bruin TW, Blaak EE. Improvements in glucose tolerance and insulin sensitivity after lifestyle intervention are related to changes in serum fatty acid profile and desaturase activities: the SLIM study. Diabetologia. Oct. 2006;49(10):2392-401. [pmid: 16896932].
37 Crandall J, S D, Ma Y, Fujimoto WY, Barrett-Connor E, Fowler S, Dagogo-Jack S, Andres R. The influence of age on the effects of lifestyle modification and metformin in prevention of diabetes. J Gerontol A Biol Sci Med Sci. Oct. 2006;61(10):1075-81. [pmid: 17077202].
38 Daly RM, D DW, Owen N, Jolley D, Shaw JE, Zimmet PZ. Does high-intensity resistance training maintain bone mass during moderate weight loss in older overweight adults with type 2 diabetes?. Osteoporos Int. Dec. 2005;16(12):1703-12. [pmid: 15937634].
39 Davis TM, C CA, Holman RR. Relationship between ethnicity and glycemic control, lipid profiles, and blood pressure during the first 9 years of type 2 diabetes: U.K. Prospective Diabetes Study (UKPDS 55). Diabetes Care. Jul. 2001;24(7):1167-74. [pmid: 11423497].
40 Deakin TA, C JE, Williams R, Greenwood DC. Structured patient education: the diabetes X-PERT Programme makes a difference. Diabet Med. Sep. 2006;23(9):944-54. [pmid: 16922700].
41 Despres JP, G A, Sjostrom L. Effects of rimonabant on metabolic risk factors in overweight patients with dyslipidemia. N Engl J Med. Nov. 17. 2005;353(20):2121-34. [pmid: 16291982].
42 Di Loreto C, F C, Lucidi P, Murdolo G, De Cicco A, Parlanti N, Ranchelli A, Fatone C, Taglioni C, Santeusanio F, De Feo P. Make your diabetic patients walk: long-term impact of different amounts of physical activity on type 2 diabetes. Diabetes Care. Jun. 2005;28(6):1295-302. [pmid: 15920042].
43 Diabetes Prevention Program Research Group. Effects of Withdrawal From Metformin on the Development of Diabetes in the Diabetes Prevention Program. Diabetes Care. April. 2003. 2003;26(4):977-80. [pmid: 12663559].
44 Diabetes Prevention Program Research Group. Reduction in the Incidence of Type 2 Diabetes with Lifestyle Intervention or Metformin. N Engl J Med. February. 7. 2002. 2002;346(6):393-403. [pmid: 11832527].
45 Dixon AN, V G, Hanif MW, Field A, Boutsiadis A, Harte A, McTernan PG, Barnett AH, Kumar S. Effect of the orlistat on serum endotoxin lipopolysaccharide and adipocytokines in South Asian individuals with impaired glucose tolerance. Int J Clin Pract. Jul. 2008;62(7):1124-9. [pmid: 18564278].
46 DREAM. Effect of ramipril on the incidence of diabetes. N Engl J Med. 2006;355:1608-10. [pmid: 16980381].
47 Dunstan DW, D RM, Owen N, Jolley D, Vulikh E, Shaw J, Zimmet P. Home-based resistance training is not sufficient to maintain improved glycemic control following supervised training in older individuals with type 2 diabetes. Diabetes Care. Jan. 2005;28(1):3-9. [pmid: 15616225].
48 Ebbeling CB, L MM, Sinclair KB, Seger-Shippee LG, Feldman HA, Ludwig DS. Effects of an ad libitum low-glycemic load diet on cardiovascular disease risk factors in obese young adults. Am J Clin Nutr. May. 2005;81(5):976-82. [pmid: 15883418].
49 Eeley EA, S IM, Hadden DR, Turner RC, Holman RR. UKPDS 18: estimated dietary intake in type 2 diabetic patients randomly allocated to diet, sulphonylurea or insulin therapy. UK Prospective Diabetes Study Group. Diabet Med. Jul. 1996;13(7):656-62. [pmid: 8840101].
50 Eriksson J, L J, Valle T, Aunola S, Hamalainen H, Ilanne-Parikka P, Keinanen-Kiukaanniemi S, Laakso M, Lauhkonen M, Lehto P, Lehtonen A, Louheranta A, Mannelin M, Martikkala V, Rastas M, Sundvall J, Turpeinen A, Viljanen T, Uusitupa M, Tuomilehto J. Prevention of Type II diabetes in subjects with impaired glucose tolerance: the Diabetes Prevention Study (DPS) in Finland. Study design and 1-year interim report on the feasibility of the lifestyle intervention programme. Diabetologia. Jul. 1999;42(7):793-801. [pmid: 10440120].
51 Eriksson KF, L F. No excess 12-year mortality in men with impaired glucose tolerance who participated in the Malmo Preventive Trial with diet and exercise. Diabetologia. Sep. 1998;41(9):1010-6. [pmid: 9754818].
52 Eriksson KF, L F. Prevention of type 2 (non-insulin-dependent) diabetes mellitus by diet and physical exercise. The 6-year Malmo feasibility study. Diabetologia. Dec. 1991;34(12):891-8. [pmid: 1778354].
53 Esposito K, M MI, Ciotola M, Di Palo C, Scognamiglio P, Gicchino M, Petrizzo M, Saccomanno F, Beneduce F, Ceriello A, Giugliano D. Effects of a Mediterranean-style diet on the need for antihyperglycemic drug therapy in patients with newly diagnosed type 2 diabetes: a randomized trial. Ann Intern Med. Sep. 1. 2009;151(5):306-14. [pmid: 19721018].
54 Fitz JD, S EM, Fein HG. A hypocaloric high-protein diet as primary therapy for adults with obesity-related diabetes: effective long-term use in a community hospital. Diabetes Care. Jul-Aug. 1983;6(4):328-33. [pmid: 6617408].
55 Fontbonne A, D I, Baccara-Dinet M, Eschwege E, Charles MA. Effects of 1-year treatment with metformin on metabolic and cardiovascular risk factors in non-diabetic upper-body obese subjects with mild glucose anomalies: a post-hoc analysis of the BIGPRO1 trial. Diabetes Metab. Nov. 2009;35(5):385-91. [pmid: 19665415].
56 Forlani G, L C, Moscatiello S, Ridolfi V, Melchionda N, Di Domizio S, Marchesini G. Are behavioural approaches feasible and effective in the treatment of type 2 diabetes? A propensity score analysis vs. prescriptive diet. Nutrition, Metabolism and Cardiovascular Diseases. 2009;19(5):313-20.
57 Fraser A, A R, Lawlor DA, Fraser D, Elhayany A. A modified Mediterranean diet is associated with the greatest reduction in alanine aminotransferase levels in obese type 2 diabetes patients: results of a quasi-randomised controlled trial. Diabetologia. Sep. 2008;51(9):1616-22. [pmid: 18597068].
58 Freeman DJ, N J, Sattar N, Neely RD, Cobbe SM, Ford I, Isles C, Lorimer AR, Macfarlane PW, McKillop JH, Packard CJ, Shepherd J, Gaw A. Pravastatin and the development of diabetes mellitus: evidence for a protective treatment effect in the West of Scotland Coronary Prevention Study. Circulation. Jan. 23. 2001;103(3):357-62. [pmid: 11157685].
59 Fujimoto WY, J KA, Bray GA, Kriska A, Barrett-Connor E, Haffner S, Hanson R, Hill JO, Hubbard V, Stamm E, Pi-Sunyer FX. Body size and shape changes and the risk of diabetes in the diabetes prevention program. Diabetes. Jun. 2007;56(6):1680-5. [pmid: 17363740].
60 Gaede P, L-A H, Parving HH, Pedersen O. Effect of a multifactorial intervention on mortality in type 2 diabetes. N Engl J Med. Feb. 7. 2008;358(6):580-91. [pmid: 18256393].
61 Gallagher A, H W, Abraira C. Dietary patterns and metabolic control in diabetic diets: a prospective study of 51 outpatient men on unmeasured and exchange diets. J Am Coll Nutr. Dec. 1987;6(6):525-32. [pmid: 3693756].
62 Gerstein HC, Y S, Bosch J, Pogue J, Sheridan P, Dinccag N, Hanefeld M, Hoogwerf B, Laakso M, Mohan V, Shaw J, Zinman B, Holman RR. Effect of rosiglitazone on the frequency of diabetes in patients with impaired glucose tolerance or impaired fasting glucose: a randomised controlled trial. Lancet. Sep. 23. 2006;368(9541):1096-105. [pmid: 16997664].
63 Gilliland SS, A SP, Perez GE, Carter JS. Strong in body and spirit: lifestyle intervention for Native American adults with diabetes in New Mexico. Diabetes Care. Jan. 2002;25(1):78-83. [pmid: 11772905].
64 Group TDPPR. Effect of weight loss with lifestyle intervention on risk of diabetes. Diabetes Care. 2006;29:2192-07.
65 Gruesser M, B U, Ellermann P, Kronsbein P, Joergens V. Evaluation of a structured treatment and teaching program for non-insulin-treated type II diabetic outpatients in Germany after the nationwide introduction of reimbursement policy for physicians. Diabetes Care. Sep. 1993;16(9):1268-75. [pmid: 8404431].
66 Guare JC, W RR, Grant A. Comparison of obese NIDDM and nondiabetic women: short- and long-term weight loss. Obes Res. Jul. 1995;3(4):329-35. [pmid: 8521149].
67 Gurka MJ, W AM, Conaway MR, Crowther JQ, Nadler JL, Bovbjerg VE. Lifestyle intervention in obese patients with type 2 diabetes: impact of the patient's educational background. Obesity (Silver Spring). Jun. 2006;14(6):1085-92. [pmid: 16861614].
68 Gurlek A, E T, Gedik O. Frequency of severe hypoglycaemia in type 1 and type 2 diabetes during conventional insulin therapy. Exp Clin Endocrinol Diabetes. 1999;107(3):220-4. [pmid: 10376450].
69 Haffner S, T M, Crandall J, Fowler S, Goldberg R, Horton E, Marcovina S, Mather K, Orchard T, Ratner R, Barrett-Connor E. Intensive lifestyle intervention or metformin on inflammation and coagulation in participants with impaired glucose tolerance. Diabetes. May. 2005;54(5):1566-72. [pmid: 15855347].
70 Haimoto H, I M, Wakai K, Umegaki H. Long-term effects of a diet loosely restricting carbohydrates on HbA1c levels, BMI and tapering of sulfonylureas in type 2 diabetes: a 2-year follow-up study. Res Clin Pract. 2008;79:350-6.
71 Hamalainen H, R T, Virtanen A, Lindstrom J, Eriksson JG, Valle TT, Ilanne-Parikka P, Keinanen-Kiukaanniemi S, Rastas M, Aunola S, Uusitupa M, Tuomilehto J. Improved fibrinolysis by an intensive lifestyle intervention in subjects with impaired glucose tolerance. The Finnish Diabetes Prevention Study. Diabetologia. Nov. 2005;48(11):2248-53. [pmid: 16205886].
72 Hamman RF, W RR, Edelstein SL, Lachin JM, Bray GA, Delahanty L, Hoskin M, Kriska AM, Mayer-Davis EJ, Pi-Sunyer X, Regensteiner J, Venditti B, Wylie-Rosett J. Effect of weight loss with lifestyle intervention on risk of diabetes. Diabetes Care. Sep. 2006;29(9):2102-7. [pmid: 16936160].
73 Hanefeld M, F S, Schmechel H, Rothe G, Schulze J, Dude H, Schwanebeck U, Julius U. Diabetes Intervention Study. Multi-intervention trial in newly diagnosed NIDDM. Diabetes Care. Apr. 1991;14(4):308-17. [pmid: 2060433].
74 Hanefeld M, S G. The effects of orlistat on body weight and glycaemic control in overweight patients with type 2 diabetes: a randomized, placebo-controlled trial. Diabetes Obes Metab. Nov. 2002;4(6):415-23. [pmid: 12406041].
75 Heart Outcomes Prevention Evaluation Study Investigators. Effects of ramipril on cardiovascular and microvascular outcomes in people with diabetes mellitus: results of the HOPE study and MICRO-HOPE substudy. Lancet. Jan. 22. 2000;355(9200):253-9. [pmid: 10675071].
76 Heath GW, W RH, Smith J, Leonard BE. Community-based exercise and weight control: diabetes risk reduction and glycemic control in Zuni Indians. Am J Clin Nutr. Jun. 1991;53(6 Suppl):1642S-6S. [pmid: 2031500].
77 Heitzmann CA, K RM, Wilson DK, Sandler J. Sex differences in weight loss among adults with type II diabetes mellitus. J Behav Med. Apr. 1987;10(2):197-211. [pmid: 3612778].
78 Heller SR, C P, Daly H, Davis I, McCulloch DK, Allison SP, Tattersall RB. Group education for obese patients with type 2 diabetes: greater success at less cost. Diabet Med. Sep. 1988;5(6):552-6. [pmid: 2974778].
79 Herder C, P M, Koenig W, Kraft I, Muller-Scholze S, Martin S, Lakka T, Ilanne-Parikka P, Eriksson JG, Hamalainen H, Keinanen-Kiukaanniemi S, Valle TT, Uusitupa M, Lindstrom J, Kolb H, Tuomilehto J. Systemic immune mediators and lifestyle changes in the prevention of type 2 diabetes: results from the Finnish Diabetes Prevention Study. Diabetes. Aug. 2006;55(8):2340-6. [pmid: 16873699].
80 Hockaday TD, H JM, Mann JI, Turner RC. Prospective comparison of modified fat-high-carbohydrate with standard low-carbohydrate dietary advice in the treatment of diabetes: one year follow-up study. Br J Nutr. Mar. 1978;39(2):357-62. [pmid: 629924].
81 Hollander P. Endocannabinoid blockade for improving glycemic control and lipids in patients with type 2 diabetes mellitus. Am J Med. Feb. 2007;120(2 Suppl 1):S18-28. discussion S9-32. [pmid: 17296341].
82 Hollander PA, E SC, Hirsch IB, Kelley D, McGill J, Taylor T, Weiss SR, Crockett SE, Kaplan RA, Comstock J, Lucas CP, Lodewick PA, Canovatchel W, Chung J, Hauptman J. Role of orlistat in the treatment of obese patients with type 2 diabetes. A 1-year randomized double-blind study. Diabetes Care. Aug. 1998;21(8):1288-94. [pmid: 9702435].
83 Holloszy JO, S J, Kusnierkiewicz J, Hagberg JM, Ehsani AA. Effects of exercise on glucose tolerance and insulin resistance. Brief review and some preliminary results. Acta Med Scand Suppl. 1986;711:55-65. [pmid: 3535414].
84 Holman RR, C CA, Turner RC. A randomized double-blind trial of acarbose in type 2 diabetes shows improved glycemic control over 3 years (U.K. Prospective Diabetes Study 44). Diabetes Care. Jun. 1999;22(6):960-4. [pmid: 10372249].
85 Horrocks PM, B R, Wright AD. A long-term follow-up of dietary advice in maturity onset diabetes: the experience of one centre in the UK prospective study. Diabet Med. May-Jun. 1987;4(3):241-4. [pmid: 2956027].
86 Hughes TA, K JO, Segrest JP. Effects of glyburide therapy on lipoproteins in non-insulin-dependent diabetes mellitus. Am J Med. Sep. 20. 1985;79(3B):86-91. [pmid: 3931466].
87 Hypertension in Diabetes Study III. Prospective study of therapy of hypertension in type 2 diabetic patients: efficacy of ACE inhibition and beta-blockade. Diabet Med. Oct. 1994;11(8):773-82. [pmid: 7851072].
88 Jarrett RJ, K H, Fuller JH, McCartney M. Worsening to diabetes in men with impaired glucose tolerance (“borderline diabetes”). Diabetologia. Jan. 1979;16(1):25-30. [pmid: 761734].
89 Johnston PS, L HE, Coniff RF, Simonson DC, Raskin P, Munera CL. Advantages of alpha-glucosidase inhibition as monotherapy in elderly type 2 diabetic patients. J Clin Endocrinol Metab. May. 1998;83(5):1515-22. [pmid: 9589648].
90 Jonsson B, C JR, Pedersen TR. The cost-effectiveness of lipid lowering in patients with diabetes: results from the 4S trial. Diabetologia. Nov. 1999;42(11):1293-301. [pmid: 10550412].
91 Kaplan RM, H SL, Wilson DK, Wallace JP. Effects of diet and exercise interventions on control and quality of life in non-insulin-dependent diabetes mellitus. J Gen Intern Med. Jul-Aug. 1987;2(4):220-8. [pmid: 3302144].
92 Karlstrom B, N M, Vessby B. Dietary habits and effects of dietary advice in patients with type 2 diabetes. Results from a one-year intervention study. Eur J Clin Nutr. Jan. 1989;43(1):59-68. [pmid: 2543554].
93 Kawamori R, T N, Iwamoto Y, Kashiwagi A, Shimamoto K, Kaku K. Alpha-glucosidase inhibitor for the prevention of type 2 diabetes mellitus: a randomised, double-blind trial in Japanese subjects with impaired glucose tolerance. Nippon Rinsho. Sep. 2009;67(9):1821-5. [pmid: 19768922].
94 Kawamori R, T N, Iwamoto Y, Kashiwagi A, Shimamoto K, Kaku K. Voglibose for prevention of type 2 diabetes mellitus: a randomised, double-blind trial in Japanese individuals with impaired glucose tolerance. Lancet. May. 9. 2009;373(9675):1607-14. [pmid: 19395079].
95 Keech A, S RJ, Barter P, Best J, Scott R, Taskinen MR, Forder P, Pillai A, Davis T, Glasziou P, Drury P, Kesaniemi YA, Sullivan D, Hunt D, Colman P, d'Emden M, Whiting M, Ehnholm C, Laakso M. Effects of long-term fenofibrate therapy on cardiovascular events in 9795 people with type 2 diabetes mellitus (the FIELD study): randomised controlled trial. Lancet. Nov. 26. 2005;366(9500):1849-61. [pmid: 16310551].
96 Keen H, J RJ, Ward JD, Fuller JH. Borderline diabetics and their response to tolbutamide. Adv Metab Disord. Suppl 2. 1973;2:521-31. [pmid: 4720382].
97 Keen H, J RJ, McCartney P. The ten-year follow-up of the Bedford survey (1962-1972): glucose tolerance and diabetes. Diabetologia. Feb. 1982;22(2):73-8. [pmid: 7060852].
98 Kilo C, D J, Kalb E. Evaluation of saftey and efficacy of gliclazide in non-insulin-dependent diabetic patients. Diabetes Res Clin Pract. 1991;(14):79S-82S.
99 Kirk A, M N, MacIntyre P, Fisher M. Effects of a 12-month physical activity counselling intervention on glycaemic control and on the status of cardiovascular risk factors in people with Type 2 diabetes. Diabetologia. May. 2004;47(5):821-32. [pmid: 15138687].
100 Kirkman MS, W M, Landsman PB, Samsa GP, Shortliffe EA, Simel DL, Feussner JR. A telephone-delivered intervention for patients with NIDDM. Effect on coronary risk factors. Diabetes Care. Aug. 1994;17(8):840-6. [pmid: 7956628].
101 Kitabchi AE, T M, Knowler WC, Kahn SE, Fowler SE, Haffner SM, Andres R, Saudek C, Edelstein SL, Arakaki R, Murphy MB, Shamoon H. Role of insulin secretion and sensitivity in the evolution of type 2 diabetes in the diabetes prevention program: effects of lifestyle intervention and metformin. Diabetes. Aug. 2005;54(8):2404-14. [pmid: 16046308].
102 Klonoff DC, B JB, Nielsen LL, Guan X, Bowlus CL, Holcombe JH, Wintle ME, Maggs DG. Exenatide effects on diabetes, obesity, cardiovascular risk factors and hepatic biomarkers in patients with type 2 diabetes treated for at least 3 years. Curr Med Res Opin. Jan. 2008;24(1):275-86. [pmid: 18053320].
103 Knowler WC, B-C E, Fowler SE, Hamman RF, Lachin JM, Walker EA, Nathan DM. Reduction in the incidence of type 2 diabetes with lifestyle intervention or metformin. N Engl J Med. Feb. 7. 2002;346(6):393-403. [pmid: 11832527].
104 Korhonen T, U M, Aro A, Kumpulainen T, Siitonen O, Voutilainen E, Pyorala K. Efficacy of dietary instructions in newly diagnosed non-insulin-dependent diabetic patients. Comparison of two different patient education regimens. Acta Med Scand. 1987;222(4):323-31. [pmid: 3425385].
105 Kosaka K, N M, Kuzuya T. Prevention of type 2 diabetes by lifestyle intervention: a Japanese trial in IGT males. Diabetes Res Clin Pract. Feb. 2005;67(2):152-62. [pmid: 15649575].
106 Kramer MK, K AM, Venditti EM, Miller RG, Brooks MM, Burke LE, Siminerio LM, Solano FX, Orchard TJ. Translating the Diabetes Prevention Program: a comprehensive model for prevention training and program delivery. Am J Prev Med. Dec. 2009;37(6):505-11. [pmid: 19944916].
107 Kudlacek S, S G. The effect of insulin treatment on HbA1c, body weight and lipids in type 2 diabetic patients with secondary-failure to sulfonylureas. A five year follow-up study. Horm Metab Res. Oct. 1992;24(10):478-83. [pmid: 1464414].
108 Kulzer B, H Norbert, Gorges Daniela, Schwarz Peter, Haak Thomas. Prevention of Diabetes Self-Management Program (PREDIAS): Effects on Weight, Metabolic Risk Factors, and Behavioral Outcomes. Diabetes Care. July. 2009. 2009;32(7):1143-6. [pmid: 19509014].
109 Laaksonen DE, L J, Lakka TA, Eriksson JG, Niskanen L, Wikstrom K, Aunola S, Keinanen-Kiukaanniemi S, Laakso M, Valle TT, Ilanne-Parikka P, Louheranta A, Hamalainen H, Rastas M, Salminen V, Cepaitis Z, Hakumaki M, Kaikkonen H, Harkonen P, Sundvall J, Tuomilehto J, Uusitupa M. Physical activity in the prevention of type 2 diabetes: the Finnish diabetes prevention study. Diabetes. Jan. 2005;54(1):158-65. [pmid: 15616024].
110 Lachin JM, C CA, Edelstein SL, Ehrmann DA, Hamman RF, Kahn SE, Knowler WC, Nathan DM. Factors associated with diabetes onset during metformin versus placebo therapy in the diabetes prevention program. Diabetes. Apr. 2007;56(4):1153-9. [pmid: 17395752].
111 Laitinen JH, A IE, Sarkkinen ES, Winberg RL, Harmaakorpi-Iivonen PA, Uusitupa MI. Impact of intensified dietary therapy on energy and nutrient intakes and fatty acid composition of serum lipids in patients with recently diagnosed non-insulin-dependent diabetes mellitus. J Am Diet Assoc. Mar. 1993;93(3):276-83. [pmid: 8382712].
112 Lehtovirta M, F B, Gullstrom M, Haggblom M, Eriksson JG, Taskinen MR, Groop L. Metabolic effects of metformin in patients with impaired glucose tolerance. Diabet Med. Jul. 2001;18(7):578-83. [pmid: 11553189].
113 Lewis EJ, H LG, Clarke WR, Berl T, Pohl MA, Lewis JB, Ritz E, Atkins RC, Rohde R, Raz I. Renoprotective effect of the angiotensin-receptor antagonist irbesartan in patients with nephropathy due to type 2 diabetes. N Engl J Med. Sep. 20. 2001;345(12):851-60. [pmid: 11565517].
114 Ley SJ, M PA, Scragg RK, Swinburn BA. Long-term effects of a reduced fat diet intervention on cardiovascular disease risk factors in individuals with glucose intolerance. Diabetes Res Clin Pract. Feb. 2004;63(2):103-12. [pmid: 14739050].
115 Li CL, P CY, Lu JM, Zhu Y, Wang JH, Deng XX, Xia FC, Wang HZ, Wang HY. Effect of metformin on patients with impaired glucose tolerance. Diabet Med. Jun. 1999;16(6):477-81. [pmid: 10391395].
116 Li Z, H K, Saltsman P, DeShields S, Bellman M, Thames G, Liu Y, Wang HJ, Elashoff R, Heber D. Long-term efficacy of soy-based meal replacements vs an individualized diet plan in obese type II DM patients: relative effects on weight loss, metabolic parameters, and C-reactive protein. Eur J Clin Nutr. Mar. 2005;59(3):411-8. [pmid: 15674301].
117 Liao D, A PJ, Shofer JB, Callahan H, Matthys C, Boyko EJ, Leonetti D, Kahn SE, Austin M, Newell L, Schwartz RS, Fujimoto WY. Improvement of BMI, body composition, and body fat distribution with lifestyle modification in Japanese Americans with impaired glucose tolerance. Diabetes Care. Sep. 2002;25(9):1504-10. [pmid: 12196418].
118 Lindahl B, N TK, Jansson JH, Asplund K, Hallmans G. Improved fibrinolysis by intense lifestyle intervention. A randomized trial in subjects with impaired glucose tolerance. J Intern Med. Jul. 1999;246(1):105-12. [pmid: 10447232].
119 Lindgarde F. The effect of orlistat on body weight and coronary heart disease risk profile in obese patients: the Swedish Multimorbidity Study. J Intern Med. Sep. 2000;248(3):245-54. [pmid: 10971792].
120 Lindstrom J, E JG, Valle TT, Aunola S, Cepaitis Z, Hakumaki M, Hamalainen H, Ilanne-Parikka P, Keinanen-Kiukaanniemi S, Laakso M, Louheranta A, Mannelin M, Martikkala V, Moltchanov V, Rastas M, Salminen V, Sundvall J, Uusitupa M, Tuomilehto J. Prevention of diabetes mellitus in subjects with impaired glucose tolerance in the Finnish Diabetes Prevention Study: results from a randomized clinical trial. J Am Soc Nephrol. Jul. 2003;14(7 Suppl 2):S108-13. [pmid: 12819313].
121 Lindstrom J, I-P P, Peltonen M, Aunola S, Eriksson JG, Hemio K, Hamalainen H, Harkonen P, Keinanen-Kiukaanniemi S, Laakso M, Louheranta A, Mannelin M, Paturi M, Sundvall J, Valle TT, Uusitupa M, Tuomilehto J. Sustained reduction in the incidence of type 2 diabetes by lifestyle intervention: follow-up of the Finnish Diabetes Prevention Study. Lancet. Nov. 11. 2006;368(9548):1673-9. [pmid: 17098085].
122 Lindstrom J, L A, Mannelin M, Rastas M, Salminen V, Eriksson J, Uusitupa M, Tuomilehto J. The Finnish Diabetes Prevention Study (DPS): Lifestyle intervention and 3-year results on diet and physical activity. Diabetes Care. Dec. 2003;26(12):3230-6. [pmid: 14633807].
123 Lindstrom J, P M, Eriksson JG, Aunola S, Hamalainen H, Ilanne-Parikka P, Keinanen-Kiukaanniemi S, Uusitupa M, Tuomilehto J. Determinants for the effectiveness of lifestyle intervention in the Finnish Diabetes Prevention Study. Diabetes Care. May. 2008;31(5):857-62. [pmid: 18252900].
124 Lindstrom J, P M, Eriksson JG, Louheranta A, Fogelholm M, Uusitupa M, Tuomilehto J. High-fibre, low-fat diet predicts long-term weight loss and decreased type 2 diabetes risk: the Finnish Diabetes Prevention Study. Diabetologia. May. 2006;49(5):912-20. [pmid: 16541277].
125 Lindstrom J, P M, Tuomilehto J. Lifestyle strategies for weight control: experience from the Finnish Diabetes Prevention Study. Proc Nutr Soc. Feb. 2005;64(1):81-8. [pmid: 15877926].
126 Manning RM, J RT, Leese GP, Newton RW. The comparison of four weight reduction strategies aimed at overweight diabetic patients. Diabet Med. May. 1995;12(5):409-15. [pmid: 7648803].
127 Manning RM, J RT, Leese GP, Newton RW. The comparison of four weight reduction strategies aimed at overweight patients with diabetes mellitus: four-year follow-up. Diabet Med. Jun. 1998;15(6):497-502. [pmid: 9632125].
128 Mazzuca SA, M NH, Wheeler ML, Norton JA, Fineberg NS, Vinicor F, Cohen SJ, Clark CM Jr. The diabetes education study: a controlled trial of the effects of diabetes patient education. Diabetes Care. Jan-Feb. 1986;9(1):1-10. [pmid: 3948638].
129 McAuley KA, S KJ, Taylor RW, McLay RT, Williams SM, Mann JI. Long-term effects of popular dietary approaches on weight loss and features of insulin resistance. Int J Obes (Lond). Feb. 2006;30(2):342-9. [pmid: 16158081].
130 McBride PE, E JA, Grant H, Sargent C, Underbakke G, Vitcenda M, Zeller L, Stein JH. Putting the Diabetes Prevention Program into practice: a program for weight loss and cardiovascular risk reduction for patients with metabolic syndrome or type 2 diabetes mellitus. J Nutr Health Aging. Dec. 2008;12(10):745S-9S. [pmid: 19043651].
131 McCarron DA, R ME. Reducing cardiovascular disease risk with diet. Obes Res. Nov. Suppl 4. 2001;9:335S-40S. [pmid: 11707562].
132 Mensink M, B EE, Corpeleijn E, Saris WH, de Bruin TW, Feskens EJ. Lifestyle intervention according to general recommendations improves glucose tolerance. Obes Res. Dec. 2003;11(12):1588-96. [pmid: 14694225].
133 Mensink M, B EE, Wagenmakers AJ, Saris WH. Lifestyle intervention and fatty acid metabolism in glucose-intolerant subjects. Obes Res. Aug. 2005;13(8):1354-62. [pmid: 16129717].
134 Mensink M, F EJ, Saris WH, De Bruin TW, Blaak EE. Study on Lifestyle Intervention and Impaired Glucose Tolerance Maastricht (SLIM): preliminary results after one year. Int J Obes Relat Metab Disord. Mar. 2003;27(3):377-84. [pmid: 12629566].
135 Mertes G. Efficacy and safety of acarbose in the treatment of type 2 diabetes: data from a 2-year surveillance study. Diabetes Res Clin Pract. Apr. 1998;40(1):63-70. [pmid: 9699092].
136 Metz JA, S JS, Kris-Etherton P, Reusser ME, Morris CD, Hatton DC, Oparil S, Haynes RB, Resnick LM, Pi-Sunyer FX, Clark S, Chester L, McMahon M, Snyder GW, McCarron DA. A randomized trial of improved weight loss with a prepared meal plan in overweight and obese patients: impact on cardiovascular risk reduction. Arch Intern Med. Jul. 24. 2000;160(14):2150-8. [pmid: 10904458].
137 Molitch ME, F W, Hamman RF, Knowler WC. The diabetes prevention program and its global implications. J Am Soc Nephrol. Jul. 2003;14(7 Suppl 2):S103-7. [pmid: 12819312].
138 New JP, M JM, Freemantle N, Teasdale S, Wong LM, Bruce NJ, Burns JA, Gibson JM. Specialist nurse-led intervention to treat and control hypertension and hyperlipidemia in diabetes (SPLINT): a randomized controlled trial. Diabetes Care. Aug. 2003;26(8):2250-5. [pmid: 12882844].
139 Nielsen JV, J E, Nilsson AK. Lasting improvement of hyperglycaemia and bodyweight: low-carbohydrate diet in type 2 diabetes. A brief report. Ups J Med Sci. 2005;110(2):179-83. [pmid: 16075898].
140 Nijpels G, B W, Dekker JM, Kostense PJ, Bouter LM, Heine RJ. A study of the effects of acarbose on glucose metabolism in patients predisposed to developing diabetes: the Dutch acarbose intervention study in persons with impaired glucose tolerance (DAISI). Diabetes Metab Res Rev. Nov-Dec. 2008;24(8):611-6. [pmid: 18756586].
141 Nissen SE, W K, Topol EJ. Effect of muraglitazar on death and major adverse cardiovascular events in patients with type 2 diabetes mellitus. JAMA. Nov. 23. 2005;294(20):2581-6. [pmid: 16239637].
142 Oldroyd JC, U NC, White M, Mathers JC, Alberti KG. Randomised controlled trial evaluating lifestyle interventions in people with impaired glucose tolerance. Diabetes Res Clin Pract. May. 2006;72(2):117-27. [pmid: 16297488].
143 Orchard M, Goldberg R, Haffner S, Ratner R, Marcovina S, Fowler S. The effect of metformin and intensive lifestyle intervention on the metabolic syndrome: the Diabetes Prevention Program randomized trial. Ann Intern Med. Apr. 19. 2005;142(8):611-9. [pmid: 15838067].
144 Page RC, H KE, Cook JT, Turner RC. Can life-styles of subjects with impaired glucose tolerance be changed? A feasibility study. Diabet Med. Jul. 1992;9(6):562-6. [pmid: 1643806].
145 Pan X, L G, Hu Y. Effect of dietary and/or exercise intervention on incidence of diabetes in 530 subjects with impaired glucose tolerance from 1986-1992. Zhonghua Nei Ke Za Zhi. Feb. 1995;34(2):108-12. [pmid: 7796655].
146 Pan XR, L GW, Hu YH, Wang JX, Yang WY, An ZX, Hu ZX, Lin J, Xiao JZ, Cao HB, Liu PA, Jiang XG, Jiang YY, Wang JP, Zheng H, Zhang H, Bennett PH, Howard BV. Effects of diet and exercise in preventing NIDDM in people with impaired glucose tolerance. The Da Qing IGT and Diabetes Study. Diabetes Care. Apr. 1997;20(4):537-44. [pmid: 9096977].
147 Perreault L, K Steven E, Christophi Costas A, Knowler William C, Hamman Richard F. Regression From Pre-Diabetes to Normal Glucose Regulation in the Diabetes Prevention Program. Diabetes Care. September. 2009. 2009;32(9):1583-8. [pmid: 19587364].
148 Pritchard DA, H J, Taba F. Nutritional counselling in general practice: a cost effective analysis. J Epidemiol Community Health. May. 1999;53(5):311-6. [pmid: 10396539].
149 Ratner R, G R, Haffner S, Marcovina S, Orchard T, Fowler S, Temprosa M. Impact of intensive lifestyle and metformin therapy on cardiovascular disease risk factors in the diabetes prevention program. Diabetes Care. Apr. 2005;28(4):888-94. [pmid: 15793191].
150 Ratzmann KP, W S, Schulz B. The effect of long-term glibenclamide treatment on glucose tolerance, insulin secretion and serum lipids in subjects with impaired glucose tolerance. Diabete Metab. May-Jun. 1983;9(2):87-93. [pmid: 6413265].
151 Ratzmann KP, Z E, Witt S, Schulz B. Effect of a combined diet-training program on the insulin sensitivity of obese persons with normal or disordered glucose tolerance. Z Gesamte Inn Med. May. 15. 1982;37(10):304-8. [pmid: 7048770].
152 Ridgeway NA, H DR, Harvill LM, Falin TM, Forester GM, Gose OD. Improved control of type 2 diabetes mellitus: a practical education/behavior modification program in a primary care clinic. South Med J. Jul. 1999;92(7):667-72. [pmid: 10414474].
153 Rossner S, S L, Noack R, Meinders AE, Noseda G. Weight loss, weight maintenance, and improved cardiovascular risk factors after 2 years treatment with orlistat for obesity. European Orlistat Obesity Study Group. Obes Res. Jan. 2000;8(1):49-61. [pmid: 10678259].
154 Roumen C, C E, Feskens EJ, Mensink M, Saris WH, Blaak EE. Impact of 3-year lifestyle intervention on postprandial glucose metabolism: the SLIM study. Diabet Med. May. 2008;25(5):597-605. [pmid: 18445174].
155 Rowley KG, D M, Skinner K, Skinner M, White GA, O'Dea K. Effectiveness of a community-directed 'healthy lifestyle' program in a remote Australian aboriginal community. Aust N Z J Public Health. Apr. 2000;24(2):136-44. [pmid: 10790932].
156 Samaras K, H CS, Sullivan D, Kelly RP, Campbell LV. Effects of postmenopausal hormone replacement therapy on central abdominal fat, glycemic control, lipid metabolism, and vascular factors in type 2 diabetes: a prospective study. Diabetes Care. Sep. 1999;22(9):1401-7. [pmid: 10480500].
157 Sanchez-Reyes L, F G, Yamamoto J, Martinez-Rivas L, Campos-Franco E, Berber A. Use of sibutramine in overweight adult hispanic patients with type 2 diabetes mellitus: a 12-month, randomized, double-blind, placebo-controlled clinical trial. Clin Ther. Sep. 2004;26(9):1427-35. [pmid: 15531005].
158 Sarkadi A, R U. Field test of a group education program for type 2 diabetes: measures and predictors of success on individual and group levels. Patient Educ Couns. Aug. 2001;44(2):129-39. [pmid: 11479053].
159 Sartor G, S B, Carlstrom S, Melander A, Norden A, Persson G. Ten-year follow-up of subjects with impaired glucose tolerance: prevention of diabetes by tolbutamide and diet regulation. Diabetes. Jan. 1980;29(1):41-9. [pmid: 7380107].
160 Scheen AJ, F N, Hollander P, Jensen MD, Van Gaal LF. Efficacy and tolerability of rimonabant in overweight or obese patients with type 2 diabetes: a randomised controlled study. Lancet. Nov. 11. 2006;368(9548):1660-72. [pmid: 17098084].
161 Scheen AJ, P N, Lefebvre PJ. United Kingdom Prospective Diabetes Study (UKPDS): 10 years later. Rev Med Liege. Oct. 2008;63(10):624-9. [pmid: 19009971].
162 Scherbaum WA, S A, Mari A, Nilsson PM, Lalanne G, Jauffret S, Foley JE. Efficacy and tolerability of vildagliptin in drug-naive patients with type 2 diabetes and mild hyperglycaemia*. Diabetes Obes Metab. Aug. 2008;10(8):675-82. [pmid: 18248490].
163 Sever PS, D B, Poulter NR, Wedel H, Beevers G, Caulfield M, Collins R, Kjeldsen SE, Kristinsson A, McInnes GT, Mehlsen J, Nieminen M, O'Brien E, Ostergren J. Prevention of coronary and stroke events with atorvastatin in hypertensive patients who have average or lower-than-average cholesterol concentrations, in the Anglo-Scandinavian Cardiac Outcomes Trial--Lipid Lowering Arm (ASCOT-LLA): a multicentre randomised controlled trial. Drugs. Suppl 2. 2004;64:43-60. [pmid: 15765890].
164 Sever PS, P NR, Dahlof B, Wedel H, Collins R, Beevers G, Caulfield M, Kjeldsen SE, Kristinsson A, McInnes GT, Mehlsen J, Nieminen M, O'Brien E, Ostergren J. Reduction in cardiovascular events with atorvastatin in 2,532 patients with type 2 diabetes: Anglo-Scandinavian Cardiac Outcomes Trial--lipid-lowering arm (ASCOT-LLA). Diabetes Care. May. 2005;28(5):1151-7. [pmid: 15855581].
165 Simmons D, F C, Voyle J, Fou F, Feo S, Gatland B. A pilot urban church-based programme to reduce risk factors for diabetes among Western Samoans in New Zealand. Diabet Med. Feb. 1998;15(2):136-42. [pmid: 9507914].
166 Simmons D, V JA, Fou F, Feo S, Leakehe L. Tale of two churches: differential impact of a church-based diabetes control programme among Pacific Islands people in New Zealand. Diabet Med. Feb. 2004;21(2):122-8. [pmid: 14984446].
167 Sirtori CR, C G, Manzato E, Mancini M, Rivellese A, Paoletti R, Pazzucconi F, Pamparana F, Stragliotto E. One-year treatment with ethyl esters of n-3 fatty acids in patients with hypertriglyceridemia and glucose intolerance: reduced triglyceridemia, total cholesterol and increased HDL-C without glycemic alterations. Atherosclerosis. Apr. 1998;137(2):419-27. [pmid: 9622285].
168 Skarfors ET, W TA, Lithell H, Selinus I. Physical training as treatment for type 2 (non-insulin-dependent) diabetes in elderly men. A feasibility study over 2 years. Diabetologia. Dec. 1987;30(12):930-3. [pmid: 3436489].
169 Sol BG, vdG Y, van der Bijl JJ, Goessens BM, Visseren FL. The role of self-efficacy in vascular risk factor management: a randomized controlled trial. Patient Educ Couns. May. 2008;71(2):191-7. [pmid: 18242934].
170 Sone H, K A, Ishibashi S, Abe R, Saito Y, Murase T, Yamashita H, Yajima Y, Ito H, Ohashi Y, Akanuma Y, Yamada N. Effects of lifestyle modifications on patients with type 2 diabetes: the Japan Diabetes Complications Study (JDCS) study design, baseline analysis and three year-interim report. Horm Metab Res. Sep. 2002;34(9):509-15. [pmid: 12384828].
171 Stone DB, C WE. The prolonged effects of a low cholesterol, high carbohydrate diet upon the serum lipids in diabetic patients. Diabetes. Mar-Apr. 1963;12:127-32. [pmid: 13984377].
172 Swinburn BA, M PA, Ley SJ. Long-term (5-year) effects of a reduced-fat diet intervention in individuals with glucose intolerance. Diabetes Care. Apr. 2001;24(4):619-24. [pmid: 11315819].
173 Takekoshi H, M K, Suzuki Y, Atsumi Y, Kubo A, Hayashi K, Horiuchi A. A ten year follow up study in NIDDM with or without exercise. J Med Assoc Thai. Mar. Suppl 2. 1987;70:149-52. [pmid: 3598424].
174 Tapsell LC, B MJ, Teuss G, Tan SY, Dalton S, Quick CJ, Gillen LJ, Charlton KE. Long-term effects of increased dietary polyunsaturated fat from walnuts on metabolic parameters in type II diabetes. Eur J Clin Nutr. Aug. 2009;63(8):1008-15. [pmid: 19352378].
175 Tate DF, J EH, Wing RR. Effects of Internet behavioral counseling on weight loss in adults at risk for type 2 diabetes: a randomized trial. JAMA. Apr. 9. 2003;289(14):1833-6. [pmid: 12684363].
176 Taylor CB, M NH, Reilly KR, Greenwald G, Cunning D, Deeter A, Abascal L. Evaluation of a nurse-care management system to improve outcomes in patients with complicated diabetes. Diabetes Care. Apr. 2003;26(4):1058-63. [pmid: 12663573].
177 Tenkanen L, M M, Manninen V. Some coronary risk factors related to the insulin resistance syndrome and treatment with gemfibrozil.Experience from the Helsinki Heart Study. Circulation. Oct. 1. 1995;92(7):1779-85. [pmid: 7671361].
178 Torgerson JS, H J, Boldrin MN, Sjostrom L. XENical in the prevention of diabetes in obese subjects (XENDOS) study: a randomized study of orlistat as an adjunct to lifestyle changes for the prevention of type 2 diabetes in obese patients. Diabetes Care. Jan. 2004;27(1):155-61. [pmid: 14693982].
179 Torjesen PA, B KI, Anderssen SA, Hjermann I, Holme I, Urdal P. Lifestyle changes may reverse development of the insulin resistance syndrome. The Oslo Diet and Exercise Study: a randomized trial. Diabetes Care. Jan. 1997;20(1):26-31. [pmid: 9028689].
180 Trento M, P P, Borgo E, Tomalino M, Bajardi M, Cavallo F, Porta M. A 5-year randomized controlled study of learning, problem solving ability, and quality of life modifications in people with type 2 diabetes managed by group care. Diabetes Care. Mar. 2004;27(3):670-5. [pmid: 14988283].
181 Trento M, P P, Tomalino M, Bajardi M, Pomero F, Allione A, Vaccari P, Molinatti GM, Porta M. Group visits improve metabolic control in type 2 diabetes: a 2-year follow-up. Diabetes Care. Jun. 2001;24(6):995-1000. [pmid: 11375359].
182 Trento M, P P, Bajardi M, Tomalino M, Grassi G, Borgo E, Donnola C, Cavallo F, Bondonio P, Porta M. Lifestyle intervention by group care prevents deterioration of Type II diabetes: a 4-year randomized controlled clinical trial. Diabetologia. Sep. 2002;45(9):1231-9. [pmid: 12242455].
183 Tuomilehto J, L J, Eriksson JG, Valle TT, Hamalainen H, Ilanne-Parikka P, Keinanen-Kiukaanniemi S, Laakso M, Louheranta A, Rastas M, Salminen V, Uusitupa M. Prevention of type 2 diabetes mellitus by changes in lifestyle among subjects with impaired glucose tolerance. N Engl J Med. May. 3. 2001;344(18):1343-50. [pmid: 11333990].
184 Turner R, C C, Holman R. United Kingdom Prospective Diabetes Study 17: a 9-year update of a randomized, controlled trial on the effect of improved metabolic control on complications in non-insulin-dependent diabetes mellitus. Ann Intern Med. Jan. 1. 1996;124(1 Pt 2):136-45. [pmid: 8554206].
185 Turner RC, C CA, Frighi V, Holman RR. Glycemic control with diet, sulfonylurea, metformin, or insulin in patients with type 2 diabetes mellitus: progressive requirement for multiple therapies (UKPDS 49). UK Prospective Diabetes Study (UKPDS) Group. JAMA. Jun. 2. 1999;281(21):2005-12. [pmid: 10359389].
186 U.K. Prospective Diabetes Study Group. Quality of life in type 2 diabetic patients is affected by complications but not by intensive policies to improve blood glucose or blood pressure control (UKPDS 37). Diabetes Care. Jul. 1999;22(7):1125-36. [pmid: 10388978].
187 UK Prospective Diabetes Study (UKPDS) Group. Intensive blood-glucose control with sulphonylureas or insulin compared with conventional treatment and risk of complications in patients with type 2 diabetes (UKPDS 33). Lancet. Sep. 12. 1998;352(9131):837-53. [pmid: 9742976].
188 UK prospective study of therapies of maturity-onset diabetes I. Effect of diet, sulphonylurea, insulin or biguanide therapy on fasting plasma glucose and body weight over one year. Diabetologia. Jun. 1983;24(6):404-11. [pmid: 6350078].
189 U.K. prospective diabetes study II. Reduction in HbA1c with basal insulin supplement, sulfonylurea, or biguanide therapy in maturity-onset diabetes. A multicenter study. Diabetes. Aug. 1985;34(8):793-8. [pmid: 2862087].
190 UKPDS Group. UK Prospective Diabetes Study 7: response of fasting plasma glucose to diet therapy in newly presenting type II diabetic patients. Metabolism. Sep. 1990;39(9):905-12. [pmid: 2392060].
191 United Kingdom Prospective Diabetes Study 24. a 6-year, randomized, controlled trial comparing sulfonylurea, insulin, and metformin therapy in patients with newly diagnosed type 2 diabetes that could not be controlled with diet therapy. United Kingdom Prospective Diabetes Study Group. Ann Intern Med. Feb. 1. 1998;128(3):165-75. [pmid: 9454524].
192 United Kingdom Prospective Diabetes Study (UKPDS) 13: Relative efficacy of randomly allocated diet, sulphonylurea, insulin, or metformin in patients with newly diagnosed non-insulin dependent diabetes followed for three years. BMJ. Jan. 14. 1995;310(6972):83-8. [pmid: 7833731].
193 Uusitupa M, L V, Louheranta A, Salopuro T, Lindstrom J, Tuomilehto J. Long-term improvement in insulin sensitivity by changing lifestyles of people with impaired glucose tolerance: 4-year results from the Finnish Diabetes Prevention Study. Diabetes. Oct. 2003;52(10):2532-8. [pmid: 14514637].
194 Uusitupa M, P Markku, Lindström Jaana, Aunola Sirkka, Ilanne-Parikka Pirjo, Keinänen-Kiukaanniemi Sirkka, Valle Timo T, Eriksson Johan G, Tuomilehto Jaakko, The Finnish Diabetes Prevention Study Group. Ten-Year Mortality and Cardiovascular Morbidity in the Finnish Diabetes Prevention Study—Secondary Analysis of the Randomized Trial. PLoS ONE. 2009;4(5):e5656. [pmid: 19479072].
195 van Sluijs EM, vP MN, Twisk JW, Chin A, Paw MJ, Calfas KJ, van Mechelen W. Effect of a tailored physical activity intervention delivered in general practice settings: results of a randomized controlled trial. Am J Public Health. Oct. 2005;95(10):1825-31. [pmid: 16186461].
196 Vanninen E, U M, Lansimies E, Siitonen O, Laitinen J. Effect of metabolic control on autonomic function in obese patients with newly diagnosed type 2 diabetes. Diabet Med. Jan-Feb. 1993;10(1):66-73. [pmid: 8435991].
197 Vanninen E, U M, Siitonen O, Laitinen J, Lansimies E. Habitual physical activity, aerobic capacity and metabolic control in patients with newly-diagnosed type 2 (non-insulin-dependent) diabetes mellitus: effect of 1-year diet and exercise intervention. Diabetologia. Apr. 1992;35(4):340-6. [pmid: 1516762].
198 Venojarvi M, P R, Hamalainen H, Marniemi J, Rastas M, Rusko H, Nuutila P, Hanninen O, Aunola S. Role of skeletal muscle-fibre type in regulation of glucose metabolism in middle-aged subjects with impaired glucose tolerance during a long-term exercise and dietary intervention. Diabetes Obes Metab. Nov. 2005;7(6):745-54. [pmid: 16219019].
199 Wadden TA, W DS, Neiberg RH, Wing RR, Ryan DH, Johnson KC, Foreyt JP, Hill JO, Trence DL, Vitolins MZ. One-year weight losses in the Look AHEAD study: factors associated with success. Obesity (Silver Spring). Apr. 2009;17(4):713-22. [pmid: 19180071].
200 Watanabe M, Y K, Yokotsuka M, Tango T. Randomized controlled trial of a new dietary education program to prevent type 2 diabetes in a high-risk group of Japanese male workers. Diabetes Care. Dec. 2003;26(12):3209-14. [pmid: 14633803].
201 Wein P, B N, Harris C, Permezel M. A trial of simple versus intensified dietary modification for prevention of progression to diabetes mellitus in women with impaired glucose tolerance. Aust N Z J Obstet Gynaecol. May. 1999;39(2):162-6. [pmid: 10755770].
202 Weitgasser R, L M, Luger A, Klingler A. Effects of glimepiride on HbA(1c) and body weight in Type 2 diabetes: results of a 1.5-year follow-up study. Diabetes Res Clin Pract. Jul. 2003;61(1):13-9. [pmid: 12849919].
203 Wing RR, K R, Epstein LH, Nowalk MP, Gooding W, Becker D. Long-term effects of modest weight loss in type II diabetic patients. Arch Intern Med. Oct. 1987;147(10):1749-53. [pmid: 3310940].
204 Wolever TM, G AL, Mehling C, Chiasson JL, Connelly PW, Josse RG, Leiter LA, Maheux P, Rabasa-Lhoret R, Rodger NW, Ryan EA. The Canadian Trial of Carbohydrates in Diabetes (CCD), a 1-y controlled trial of low-glycemic-index dietary carbohydrate in type 2 diabetes: no effect on glycated hemoglobin but reduction in C-reactive protein. Am J Clin Nutr. Jan. 2008;87(1):114-25. [pmid: 18175744].
205 Woollard J, B V, Beilin LJ, Verheijden M, Bulsara MK. Effects of a general practice-based intervention on diet, body mass index and blood lipids in patients at cardiovascular risk. J Cardiovasc Risk. Feb. 2003;10(1):31-40. [pmid: 12569235].
206 Wright AD, C CA, Macleod KM, Holman RR. Hypoglycemia in Type 2 diabetic patients randomized to and maintained on monotherapy with diet, sulfonylurea, metformin, or insulin for 6 years from diagnosis: UKPDS73. J Diabetes Complications. Nov-Dec. 2006;20(6):395-401. [pmid: 17070446].
207 Yamanouchi T, S T, Igarashi K, Ichiyanagi K, Watanabe H, Kawasaki T. Comparison of metabolic effects of pioglitazone, metformin, and glimepiride over 1 year in Japanese patients with newly diagnosed Type 2 diabetes. Diabet Med. Aug. 2005;22(8):980-5. [pmid: 16026361].
208 Yancy WS Jr., Westman Eric C, McDuffie Jennifer R, Grambow Steven C, Jeffreys Amy S, Bolton Jamiyla, Chalecki Allison, Oddone Eugene Z. A Randomized Trial of a Low-Carbohydrate Diet vs Orlistat Plus a Low-Fat Diet for Weight Loss. Arch Intern Med. January. 25. 2010. 2010;170(2):136-45. [pmid: 20101008].
209 Yates T, D Melanie, Gorely Trish, Bull Fiona, Khunti Kamlesh. Effectiveness of a Pragmatic Education Program Designed to Promote Walking Activity in Individuals With Impaired Glucose Tolerance. Diabetes Care. August. 2009. 2009;32(8):1404-10. [pmid: 19602539].
210 Yusuf S, G H, Hoogwerf B, Pogue J, Bosch J, Wolffenbuttel BH, Zinman B. Ramipril and the development of diabetes. JAMA. Oct. 17. 2001;286(15):1882-5. [pmid: 11597291].

## Reject Wrong Population –Cancer Patients

1 Lanzarini E, Csendes A, Lembach H, et al. Evolution of type 2 diabetes mellitus in non morbid obese gastrectomized patients with Roux en-Y reconstruction: retrospective study. World J Surg. Sep. 2010;34(9):2098-102. [pmid: 20532768].

## Reject N < 10, case reports / case series

1 Cohen RV, S CA, Pinheiro JS, Correa JL, Rubino F. Duodenal-jejunal bypass for the treatment of type 2 diabetes in patients with body mass index of 22-34 kg/m2: a report of 2 cases. Surg Obes Relat Dis. Mar-Apr. 2007;3(2):195-7. [pmid: 17386401].
2 Ikramuddin S, Leslie D, Swan T, et al. Outcomes of Roux-en Y gastric bypass for patients with BMI <35 Kg/M2. Obesity Surgery. 2010;20(8):998-9.
3 Lee HC, Kim MK, Kwon HS, et al. Early changes in incretin secretion after laparoscopic duodenal-jejunal bypass surgery in type 2 diabetic patients. Obes Surg. Nov. 2010;20(11):1530-5. [pmid: 20803098].
4 Yang JG, Wang CC, Huang J, et al. Laparoscopic Roux-en-Y gastric bypass surgery for treatment of type 2 diabetes mellitus. Nan Fang Yi Ke Da Xue Xue Bao. Jun. 2010;30(6):1373-5. [pmid: 20584680].

## Reject Other

1 Moore H, S C, Hooper L, Cruickshank K, Vyas A, Johnstone P, Ashton V, Kopelman P. Dietary advice for treatment of type 2 diabetes mellitus in adults. Cochrane Database Syst Rev. 2004;(3):CD004097. [pmid: 15266517].
2 Qin L, K Mirjam, Corpeleijn Eva, Stolk Ronald. Does physical activity modify the risk of obesity for type 2 diabetes: a review of epidemiological data. European Journal of Epidemiology. 2010;25(1):5-12. [pmid: 19847656].
3 Van de Laar FA, L PL, Akkermans RP, Van de Lisdonk EH, De Grauw WJ. Alpha-glucosidase inhibitors for people with impaired glucose tolerance or impaired fasting blood glucose. Cochrane Database Syst Rev. 2006;(4):CD005061. [pmid: 17054235].