# Evidence Tables

Appendix C Evidence Tables For Surgical Treatment v. Non-Surgical Treatment Trials

Appendix C Evidence Tables For Surgical Treatment v. Surgical Treatment Trials

Appendix C Evidence Tables For Observational Studies and Controlled Trials with 1 surgical arm