# Data Collection Forms

Short Form Screener

The Short Form Screener asks 10 questions about each article: Does the article report on cases with BMI between 30 and 35; does the article include cases with type II diabetes or other metabolic conditions; does the article report on these treatments, nonsurgical treatments of metabolic conditions, surgical treatments including lap-adjustable banding, roux-en-y gastric bypass, sleeve gastrectomy, other bariatric surgeries, biliopancreatic diversion, or none of the above; type of study design; does the study focus on 11 listed outcomes; sample size entering study; duration of followup; language of article; does the article duplicate another study; and is there a reference that needs to be checked.

Detailed Abstraction Form

The Detailed Abstraction Form asks questions about participants, study characteristics, and outcomes.

AMSTAR Quality Assessment Form

The Detailed Abstraction Form asks questions about participants, study characteristics, and outcomes. The AMSTAR quality assessment form asks 11 questions: was an a priori design provided, was there duplicate study selection and data abstraction, was a comprehensive literature search performed, was the status of publication used as an inclusion criterion, was a list of included studies provided, were the characteristics of the included studies provided, was the scientific quality of the included studies assessed and documented, was the scientific quality of the included studies used appropriately in formulating conclusions, were the methods used to combine the findings of the studies appropriate, was the likelihood of publication bias assessed, and was the conflict of interest stated.