# Search Methodology

Search performed 3/5/2010:

DATABASE SEARCHED & TIME PERIOD COVERED:

PubMed - All years

SEARCH STRATEGY:

diabetes OR diabetic* OR diabetes mellitus

AND

lifestyle* OR life style* OR life style OR exercis*[tiab] OR exercise therapy OR physical activity OR diet, reducing OR diet OR diets OR dieting OR nutrition

AND

obese OR obesity OR (weight AND reduce) OR (weight AND reducing) OR (weight AND reduction) OR weight-reducing OR (decreas* AND weight) OR “weight loss” OR (weight AND lost) OR overweight

AND

intervention OR patient education as topic OR “look ahead” OR prevent*[tiab] OR prevention[sh] OR psychology[sh]

AND

follow-up studies OR follow-up[tiab] OR followup[tiab] OR longitudinal studies OR longitudinal[tiab] OR outcome assessment (health care) OR treatment outcome OR randomi* OR randomized controlled trial[pt] OR double-blind OR double blind OR prospective studies

NUMBER OF RESULTS: 1413

______________________________________________________________________________

Search performed 3/10/2010:

DATABASE SEARCHED & TIME PERIOD COVERED:

PubMed - All years

SEARCH STRATEGY:

[diabetes[tiab] OR diabetic* OR diabetes mellitus

AND

patient utilities OR “quality of life” OR “standard gamble” OR “time tradeoff” OR “time trade-off” OR cost-utilit* OR patient utilit* OR utility OR utilities]

AND

bariatric OR obesity/su OR (obesity AND (surgery OR surgical)]

NUMBER OF RESULTS: 161

______________________________________________________________________________

Search performed 3/11/2010:

DATABASE SEARCHED & TIME PERIOD COVERED:

PubMed - All years

SEARCH STRATEGY:

diabetes[tiab] OR diabetic* OR diabetes mellitus

AND

cost-utilit* OR patient utilit* OR “standard gamble” OR “time tradeoff” OR “time trade-off” OR bariatric OR obesity/su OR (obesity AND (surgery OR surgical))

NUMBER OF RESULTS: 108

______________________________________________________________________________

Search performed 3/25/2010:

DATABASE SEARCHED & TIME PERIOD COVERED:

PubMed - All years

SEARCH STRATEGY:

diabetes[tiab] OR diabetic* OR diabetes mellitus

AND

obese OR obesity OR (weight AND reduce) OR (weight AND reducing) OR (weight AND reduction) OR weight-reducing OR (decreas* AND weight) OR “weight loss” OR (weight AND lost) OR overweight

AND

lifestyle* OR life style* OR life style OR exercis*[tiab] OR exercise therapy OR physical activity OR diet, reducing OR diet OR diets OR dieting OR nutrition

AND

systematic[sb] OR systematic review* OR meta-analy* OR meta analy* OR metaanaly* OR meta-analysis[pt] OR randomized controlled trial* OR rct* OR randomized controlled trial[pt] OR controlled clinical trial* OR cct* OR controlled clinical trial[pt]

NUMBER OF RESULTS: 1766