# Abbreviations/Acronyms

AHRQ: Agency for Healthcare Research and Quality
AMSTAR: Measurement tool created to assess the methodological quality of systematic reviews
BL: Baseline
BMI: Body Mass Index
BPD: Biliopancreatic Diversion
cc: Cubic Centimeters
CCTs: Controlled Clinical Trials
CDQDPS: China Da Qing Diabetes Prevention Study
CENTRAL: Cochrane Central Register of Controlled Trials
CER: Comparative Effectiveness Review
CHIP: Children's Health Insurance Program
CINAHL: Cumulative Index to Nursing and Allied Health Literature
CMS: Center for Medicare & Medicaid Services
CPAP: Continuous Positive Airway Pressure
CV: Cardiovascular
CVD: Cardiovascular Disease
DARE: Cochrane Database of Abstracts of Reviews of Effects
DM: Diabetes Mellitus
DPP: Diabetes Prevention Program
EPC: Evidence-based Practice Center
EWL: Excess Weight Loss
FDA: Food and Drug Administration
GERD: Gastroesophageal Reflux Disease
GHb: Glycated Hemoglobin
GI: Gastrointestinal
HbA1c: Glycosylated Hemoglobin
HDL: High-Density Lipoprotein
HFLC: High-Fat Low-Carbohydrate Diet
IDPP: Indian Diabetes Prevention Programme
IGT: Impaired Glucose Tolerance
LAGB: Laparoscopic Adjustable Gastric Banding
LDL: Low-Density Lipoprotein
LFHC: Low-Fat High-Carbohydrate Diet
N: Sample Size
OSA: Obstructive Sleep Apnea
QOL: Quality of Life
RCTs: Randomized Controlled Trials
RYGB: Roux-en-Y Gastric Bypass
SE: Standard Error
SG: Sleeve Gastrectomy
TEP: Technical Expert Panel
UKPDS: United Kingdom Prospective Diabetes Study
VBG: Vertical Banded Gastroplasty
VLCDs: Very-Low-Calorie Diets
WMD: Weighted Mean Difference