# Results

## Introduction

Our findings are organized by Key Question (KQ), following an overview of the literature search results and a description of the included studies. The section includes tables with characteristics and outcomes for each KQ. Articles that used the same population sample are grouped together within these tables.

Due to heterogeneity in study populations, settings, and measurement of outcomes, we could not synthesize results quantitatively. Therefore, we based all conclusions on qualitative analysis. We used cross-sectional studies only to examine case mix addressed in KQ 1a. We assessed risk of bias only for the longitudinal peer-reviewed studies from the United States for KQs 1b, 1c, and 2. The risk of bias assessments and overall strength of evidence ratings appear in Appendix E and Appendix F. Only outcomes that were assessed for strength of evidence are reported in the strength of evidence table in Appendix F. We excluded no studies from analysis based on risk of bias.

## Results of Literature Searches

Our search yielded 2,043 unique references. Figure 2 describes the results of the literature search and screening process. A total of 73 full-text articles were screened for final inclusion. Of the 37 articles excluded at the full-text screening stage, 3 were nonapplicable countries, 10 had no relevant comparison, 8 had no relevant settings or sample, 15 had no relevant characteristics or outcomes, and 1 was a review. Excluded references and reasons for exclusion are listed in Appendix C. This step in database searching produced a total of 36 articles for final inclusion. Hand searching produced an additional 6 articles, 5 of which were grey literature reports, for a total of 42 articles that addressed 32 unique studies.

Figure 2 Literature flow diagram for review of long-term care for older adults

Figure 2 is the literature flow diagram. It describes the results of the literature search and the screening process to identify eligible articles. These results are also described in the text of the report.

## Description of Included Studies

No randomized controlled trials (RCTs) were identified. Of the 42 observational studies included in the review, 37 were peer-reviewed journal articles,32-68 and five were grey literature reports.69-73 The peer-reviewed journal articles included 22 cross-sectional studies33-38,40,41,43,45-47,49,53,55,57,59,61,63,65-67 and 15 longitudinal studies.32,39,42,44,48,50-52,54,56,58,60,62,64,68 Of the15 peer-reviewed longitudinal studies, 14 were used as the analytic set for outcomes for KQs 1b, 1c, and 2.^32,39,42,44,48,50,52,54,56,58,60,62,64,68^ Three grey literature reports that provided longitudinal data are also included as part of the analytic set for outcomes for KQs 1b, 1c, and 2, but we did not assess risk of bias for these reports. Eight studies included in the review are international.32,35,37,38,49,57,58,66 Twelve studies focused on populations with dementia.34,35,40,45,47,49,52,53,62,65,68 One study64 focused on PACE (Program for All-Inclusive Care for the Elderly) enrollees. Although there have been numerous studies on PACE, no others met the inclusion criteria for this review by explicitly comparing Home and Community-Based Services (HCBS) recipients and nursing home (NH) residents. Most PACE studies compared PACE enrollees to non-PACE enrollees but did not specify the residence of the individuals (i.e., in home and community settings or in NHs). Thus these studies were not eligible for inclusion in this review.

### KQ 1 Benefits and Harms of HCBS Compared With NHs for Older Adults Using LTC

#### KQ 1a Similarity of Populations Served by HCBS and NHs

##### Key Points

- NH samples were consistently more impaired than HCBS (including assisted living [AL] samples in terms of both physical function and cognition.
- The picture with mental health and clinical status was mixed.

##### Detailed Synthesis

Tables 4–15 present cross-sectional data that compare samples of individuals receiving care in NHs, through HCBS, and/or in AL settings at baseline. Tables 4 and 5 contrast the physical function (measured in various ways) in peer-reviewed studies for those receiving HCBS and/or in AL settings with those in NHs. In all cases, NH residents were more disabled than their counterparts.

Table 4 Description of participant physical function: U.S. cross-sectional and longitudinal peer-reviewed studies

Study | Measure of Physical Function | HCBS/AL | NH | Significance | Summary
Ohio HCBS Waiver Applebaum et al., 2004^33^ | Mean number of ADL impairments; range 0-6 | HCBS: 3.0 | 3.9 | NR | On average, HCBS recipients had fewer ADL impairments
Borrayo et al., 2002^36^ | Mean number of ADL impairments; range 0-5 | HCBS: 2.24 (SD 1.81) AL: 2.21 (SD 1.82) | 3.98 (SD 1.32) | NR | On average, HCBS recipients and AL residents had fewer ADL impairments
aDementia Care Project Port et al., 2005^53^ | Mean number of ADLs in which resident was independent; range 0-7 | AL: 3.4 (SD 2.4) | 2.4 (SD 1.8) | p=0.001 | On average, AL residents were more independent in ADLs
aEdelman et al., 2005^40^ | Mean number of ADL dependencies; range 0-6 | AL: 2.5 (SD 2.0) | 3.8 (SD 2.2) | p<0.01 | On average, AL residents had fewer ADL dependencies
Gaugler, 2006^43^ | Mean number of ADL dependencies; range not specified | HCBS: 2.04 (SD 3.01) AL: 1.75 (SD 1.86) | 5.59 (SD 3.57) | p<0.05 for NH vs. HCBS and for NH vs. AL | On average, HCBS recipients and AL residents had fewer ADL dependencies
Lee et al., 2001^46^ | Mean number of ADL dependencies; range 0-14, with higher scores indicating more dependency | HCBS: 5.07 (SD 2.13) | 7.67 (SD 3.72) | p<0.001 | On average, HCBS recipients had fewer ADL dependencies
Mehdizadeh, 2002^51^ | Mean number of ADL impairments; range 0-6 | HCBS: 2.6 | 3.2 | p≤0.05 | On average, HCBS recipients had fewer ADL impairments
Oregon Assisted Living Frytak et al., 2001^42^ | Mean ADL score; range 0-100, with higher scores indicating more dependence | AL: 16.88 | 57.09 | NR | On average, AL residents had fewer ADL dependencies
Collaborative Studies of Long-Term Care subsample Sloane et al., 2005^62^ | Mean ADL impairment score from MDS ADL; range 0-28, with higher scores indicating more impairment | AL: 7.6 (SD 7.9) | 11.9 (SD 8.2) | p=0.001 | On average, AL residents had fewer ADL impairments
Wieland et al., 2010^64^ | Mean number of ADL dependencies; range 0-6 | HCBS: 0.45 PACE: 1.05 | 2.25 | NR | On average, HCBS and PACE recipients had fewer ADL dependencies
Shugarman, et al., 1999^61^ | Mean ADL Index score; range 4–18, with higher scores indicating more dependence | HCBS: 6.99 | 9.74 | p<0.001 | On average, HCBS recipients had fewer ADL dependencies
ASPE private LTC insurance cohort Doty et al., 2010^39^ | ADL impairments (percentage) | HCBS: 18% with <2, 52% with 2-4, 30% with 5+ AL: 36% with <2, 44% with 2-4, 20% with 5+ | 12% with <2, 31% with 2-4, 57% with 5+ | NR | HCBS and AL groups had fewer individuals with higher numbers of ADL impairments
aMitchell et al., 2004^52^ | MDS ADL score, with higher scores indicating more dependence (percentage) | HCBS: 70.2% score 0-20, 23.1% score 21-27, 6.7% score 28 | 24.3% score 0-20, 36.2% score 21-27, 39.3% score 28 | p<0.001, p<0.001, p<0.001 | HCBS group had fewer individuals with higher ADL dependency
Reinardy and Kane, 1999^55^ | Number of ADLs requiring some help (percentage) | HCBS: 85% with 0-1, 9% with 2-3, 6% with 4+ | 54% with 0-1, 14% with 2-3, 32% with 4+ | NR | HCBS group had fewer individuals that required some help with several ADLs
Collaborative Studies of Long-Term Care subsample Zimmerman et al., 2003^67^ | Impairment in at least one of six ADLs (percentage) | AL(a): 37% AL(b): 25% AL(c): 15% | 83% | NR | AL groups had fewer individuals requiring help in an ADL
aBeattie et al., 2005^34^ | Mean motor ability item average; range 0-4 for six items, with higher scores indicating poorer motor ability | AL: 0.35 (SD 0.48) | 0.76 (SD 0.71) | p<0.01 | On average, AL residents had better motor ability
Franks, 2004^41^ | Mean SIP-NH score; higher scores indicate more disability | AL: 22.8 | 41.7 | NR | On average, AL residents had less disability
aLeon and Moyer, 1999^47^ | Mean SF-36 Physical Functioning Subscale score; range 0-100, with higher values indicating higher functioning | AL: 46.7 (SD 32.04) | 20.15 (SD 23.30) | p<0.001 | On average, AL residents had higher functioning
Pruchno and Rose, 2000^54^ | Mean MAI functional ability; range 15-45, with higher scores indicating better function | AL: 40.03 | 34.89 | p<0.001 | On average, AL group had better functioning
Schroeder et al., 1998^59^ | Mean Physical Activity Questionnaire for the Elderly score; higher score indicates greater physical activity levels | AL: 6.8 (SD 1.4) | 1.2 (SD 0.3) | p≤0.05 | On average, AL residents had greater physical activity levels
Collaborative Studies of Long-Term Care subsample Sloane et al., 2003^63^ | Required partial or complete assistance with locomotion at study enrollment (percentage) | AL: 20.0% | 38.1% | p=0.021 | AL group had fewer individuals requiring partial or complete assistance with locomotion at enrollment

ADL = Activities of Daily Living; AL = Assisted Living; ASPE = Assistant Secretary for Planning and Evaluation; HCBS = Home and Community-Based Services; LTC = Long term care; MAI = Multilevel Assessment Instrument; NH = Nursing Home; NR = Not reported; PACE = Program of All-Inclusive Care; SD = Standard Deviation; SF-36 = Short-Form Health Survey; SIP-NH = Sickness Impact Profile for Nursing Homes

Note: Table rows ordered by similar measures of physical function.

a Study focused on samples with dementia.

Table 5 Description of participant physical function: international cross-sectional and longitudinal peer-reviewed studies

Study | Measure of Physical Function | HCBS/AL | NH | Significance | Summary
aBoersma et al., 1997^35^ The Netherlands | Mean ADL score; range 0-10, with higher scores indicating more ADL dependency | HCBS(a): 4.2 HCBS(b): 4.9 | 8.4 | NR | On average, HCBS recipients had fewer ADL dependencies
Challis et al., 2000^37^ England | Median Barthel score; range 0-20, with lower scores indicating more dependency | HCBS: 14.3 | 8.7 | p<0.001 | On average, HCBS recipients had less dependency
aMargallo-Lana et al., 2001^49^ United Kingdom | Mean Barthel score; range 0-20, with lower scores indicating more dependency | HCBS: 14.8 | 11.0 | NR | On average, HCBS recipients had less dependency
Nottingham Studies Rothera et al., 2003^57^ United Kingdom | Median Barthel score; range 0-20, with lower scores indicating more dependency | HCBS: 13 | 7 | p<0.001 | On average, HCBS recipients had less dependency
Chappell et al., 2004^38^ Canada | Functional Autonomy Measurement System score | Scores were not specified | Scores were not specified | Scores were not significantly different for HCBS and NH participants | HCBS and NH recipients had similar functional scores
Wodchis et al., 2003^66^ Canada | Total dependence in mobility (percentage) | HCBS(a): 2% HCBS(b): 0% | 28% | NR | HCBS groups had fewer individuals totally dependent in mobility

ADL = Activities of Daily Living; HCBS = Home and Community-Based Services; NH = Nursing Home; NR = Not Reported

Note: Table rows ordered by similar measures of physical function.

a Study focused on samples with dementia.

Table 6 Description of participant cognitive function: U.S. cross-sectional and longitudinal peer-reviewed studies

Study | Measure of Cognitive Function | HCBS/AL | NH | Significance | Summary
aBeattie et al., 2005^34^ | Mean MMSE score; range 0–24, with lower scores indicating more impairment | AL: 8.40 (SD 7.06) | 7.56 (SD 7.10) | Not significant | On average, AL residents did not differ significantly from NH residents in cognitive function scores (study focused on samples with dementia)
aEdelman et al., 2005^40^ | (All participants had MMSE score of 10 or higher) Mean MMSE score; range 0–30, with lower scores indicating more impairment | AL: 11.1 (SD 6.8) | 7.9 (SD 6.8) | p<0.01 | On average, AL residents had higher cognitive function (study focused on samples with dementia)
Pruchno and Rose, 2000^54^ | Mean MMSE score; range 0–30, with lower score indicating more impairment | AL: 23.57 (SD 4.25) | 23.09 (SD 4.06) | Not significant | On average, AL residents did not differ significantly from NH residents in cognitive function
Lee et al., 2001^46^ | MDS-COGS; range 0–9, with higher scores indicating more impairment | Scores were not specified | Scores were not specified | Mean score of HCBS participants was significantly lower than NH participants (p<0.05) | On average, HCBS recipients had higher cognitive function
Collaborative Studies of Long-Term Care subsample aSloane et al., 2005^62^ | (All participants had diagnosis of dementia) Mean MDS-COGS score; range 0–10, with higher scores indicating more impairment | AL: 5.3 (SD 2.4) | 5.7 (SD 2.3) | p=0.005 | On average, AL residents had higher cognitive function (study focused on samples with dementia)
Borrayo et al., 2002^36^ | Mean cognitive impairment; range 0–3, with higher scores indicating more severe impairment Alzheimer's disease or other dementia (percentage) | HCBS: 1.72 (SD 1.23), 18% AL: 1.60 (SD 1.12), 42% | 1.42 (SD 1.05), 56% | NR | On average HCBS recipients and AL residents had more cognitive impairment; HCBS and AL groups had fewer individuals with Alzheimer's disease or other dementia
Gaugler, 2006^43^ | Mean SPMSQ score; range 0–10, with higher scores indicating more impairment | HCBS: 3.02 (SD 2.67) AL: 2.30 (SD 2.20) | 3.20 (SD 2.46) | Not significant | On average, HCBS recipients and AL residents were not significantly different from NH residents in cognitive function
aLeon and Moyer, 1999^47^ | (All participants met criteria for probable Alzheimer's disease) Mean CDRS score; range 0.5–6, with higher scores indicating more severe dementia | AL: 2.16 (SD 0.97) | 2.72 (SD 0.97) | p<0.001 | On average, AL residents had less severe dementia (study focused on samples with dementia)
Oregon Assisted Living Gaugler and Kane, 2005^44^ | Mean MSQ score; range 0–10, with lower scores indicating more impairment | AL: 7.07 (SD 2.30) | 6.46 (SD 2.18) | p<0.001 | On average, AL residents had higher cognitive function
aDementia Care Project Port et al., 2005^53^ | (All participants had diagnosis of dementia) Classified with mild, moderate, severe, or very severe dementia based on MMSE or MDS-COGS (percentage) | AL: 13.3% mild, 28.8% moderate, 23.8% severe, 29.2% very severe | 8.0% mild, 13.3% moderate, 22.1% severe, 56.6% very severe | p=0.003 | AL group had fewer individuals with very severe dementia (study focused on samples with dementia)
Kansas Medicaid Studies Shireman and Rigler, 2004^60^ | Diagnosis of Alzheimer's disease or dementia (percentage) | HCBS: 6.1% | 34.6% | p<0.01 | HCBS group had fewer individuals with a diagnosis of Alzheimer's disease or dementia
Reinardy and Kane, 1999^55^ | Dementia diagnosis (percentage) | HCBS: 15% | 20% | Not significant | HCBS recipients did not differ significantly from NH residents in the number of individuals diagnosed with dementia
Collaborative Studies of Long-Term Care subsample Sloane et al., 2003^63^ | Moderate or advanced dementia at study enrollment (percentage) | AL: 38.6% | 67.2% | p=0.001 | AL group had fewer individuals with moderate or advanced dementia at study enrollment
Wieland et al., 2010^64^ | Diagnosis of dementia (percentage) | HCBS: 18.0% PACE: 80.9% | 50.2% | p<0.001 | HCBS group had fewer individuals than NH group with a diagnosis of dementia; PACE group had more individuals than NH group with a diagnosis of dementia
aMitchell et al., 2004^52^ | (All persons in sample had diagnosis of dementia and CPS of 5 or 6 at admission) CPS 6 versus 5 (percentage), with 6 indicating more cognitive impairment | HCBS: 34.6% | 57.1% | p<0.001 | HCBS group had fewer individuals with the highest cognitive impairment score (study focused on samples with dementia)
ASPE private LTC insurance cohort Doty et al., 2010^39^ | Cognitive impairment (percentage) | HCBS: 28% AL: 63% | 64% | NR | HCBS group had fewer individuals than the NH group with cognitive impairment; AL group had similar number of individuals as NH group with cognitive impairment
Mehdizadeh, 2002^51^ | Cognitively impaired (percentage) | HCBS: 16% | 49% | NR | HCBS group had fewer individuals with cognitive impairment
Collaborative Studies of Long-Term Care subsample Zimmerman et al., 2003^67^ | Cognitive impairment indicated by diagnosis of dementia, MMSE score, or information on MDS (percentage) | AL(a): 42% AL(b): 35% AL(c): 23% | 51% | NR | AL groups had fewer individuals with cognitive impairment

AL = Assisted Living; ASPE = Assistant Secretary for Planning and Evaluation; CDRS = Clinical Dementia Rating Score; CPS = Cognitive Performance Score; HCBS = Home and Community-Based Services; LTC = Long Term Care; MDS-COGS = Minimum Data Set Cognition Scale; MMSE = Mini-mental State Exam; MSQ = Mental Status Questionnaire; NH = Nursing Home; NR = Not Reported PACE = Program of All-Inclusive Care; SD = Standard Deviation; SPMSQ = Short Portable Mental Status Questionnaire

Note: Table rows ordered by similar measures of cognitive function.

a Study focused on samples with dementia.

Table 7 Description of participant cognitive function: international cross-sectional and longitudinal peer-reviewed studies

Study | Measure of Cognitive Function | HCBS/AL | NH | Significance | Summary
aBoersma et al., 1997^35^ The Netherlands | Mean MMSE score; range 0-28, lower scores indicate more impairment | HCBS(a): 14.8 HCBS(b): 13.6 | 5.5 | NR | On average, HCBS recipients had higher cognitive function (study focused on samples with dementia)
aMargallo-Lana et al., 2001^49^ United Kingdom | Mean MMSE score; lower scores indicate more impairment | HCBS: 15.3 | 7.0 | NR | On average, HCBS recipients had higher cognitive function (study focused on samples with dementia)
Challis et al., 2000^37^ England | Median MMSE score; lower scores indicate more impairment | HCBS: 16 | 12 | p<0.001 | On average, HCBS recipients had higher cognitive function
Nottingham Studies Rothera et al., 2003^57^ United Kingdom | Median MMSE score; range 0–30, with lower scores indicating more impairment | HCBS: 17 | 14 | NR | On average, HCBS recipients had higher cognitive function
Resource Implications Study Group, 2000^32^ United Kingdom | Mean AGECAT score; higher scores indicate more impairment | HCBS: 0.9 | 2.2 | NR | On average, HCBS recipients had higher cognitive function
Wodchis et al., 2003^66^ Canada | Severe cognitive impairment (percentage) | HCBS(a): 4% HCBS(b): 0% | 34% | NR | HCBS groups had fewer individuals with severe cognitive impairment

AGECAT = Automated Geriatric Examination Computer Assisted Taxonomy; AL = Assisted Living; HCBS = Home and Community-Based Services; MMSE = Mini-mental State Exam; NH = Nursing Home; NR = Not Reported

Note: Table rows ordered by similar measures of cognitive function.

a Study focused on samples with dementia.

Table 8 Description of participant mental health: U.S. cross-sectional and longitudinal peer-reviewed studies

Study | Measure of Mental Health | HCBS/AL | NH | Significance | Summary
Marek et al., 2005^48^ | Mean score on MDS-based depression rating scale; range 0–21, with lower scores indicating less depressive symptoms | HCBS: 0.7 (SD 1.1) | 1.1 (SD 1.9) | NS | On average, HCBS recipients did not differ significantly from NH residents in depressive symptoms
Pruchno and Rose, 2000^54^ | Mean CES-D score; higher scores indicate more depressive symptoms | AL: 13.92 (SD 10.85) | 17.98 (SD 11.10) | p<0.05 | On average, AL residents had fewer depressive symptoms
Collaborative Studies of Long-Term Care subsample aSloane et al., 2005^62^ | Mean CSDD score; higher scores indicate more depressive symptoms | AL: 4.5 (SD 4.8) | 3.6 (SD 4.6) | p=0.001 | On average, AL residents had more depressive symptoms
aDementia Care Project Gruber-Baldini et al., 2005^45^ | CSDD score of 7 or greater indicating clinically significant depression (percentage) | AL: 23.9% | 26.6% | NS | AL group did not differ significantly in number of individuals with clinically significant depression
aEdelman et al., 2005^40^ | CSDD score of 7 or greater indicating depression (percentage) | AL: 36.4% | 21.4% | NR | AL group had more individuals with a score indicating depression
Kansas Medicaid Studies Shireman and Rigler, 2004^60^ | Diagnosis of depression, any psychosis (percentage) | HCBS: 6.9%, 10.4% | 9.8%, 24.6% | p<0.01, p<0.01 | HCBS group had fewer individuals with a diagnosis of depression or a diagnosis of psychosis
Wieland et al., 2010^64^ | Diagnosis of anxiety/depression (percentage) | HCBS: 26.6% PACE: 26.2% | 22.6% | NR | HCBS and PACE groups had more individuals with a diagnosis of anxiety/depression
Gaugler, 2006^43^ | Mean positive affect subscale score from the Dementia Quality of Life scale; higher scores indicate better psychosocial status | HCBS: 3.65 (SD 0.79) AL: 3.73 (SD 0.71) | 3.83 (SD 0.71) | NS | On average, HCBS recipients and AL residents did not differ significantly from NH residents in psychosocial status
Oregon Assisted Living Frytak et al., 2001^42^ | Mean psychological well-being score from SF-36 mental health subscale; range 0–100, with higher scores indicating better psychological well-being | AL: 76.04 | 71.35 | NR | On average, AL residents had better psychological well-being
Schroeder et al, 1998^59^ | Mean SWLS score; range 0–35, with higher score indicating higher life satisfaction | AL: 28.2 (SD 1.3) | 29.5 (SD 1.0) | NS | On average, AL residents did not differ significantly in life satisfaction

AL = Assisted Living; CES-D = Center for Epidemiological Studies Depression Scale; CSDD = Cornell Scale for Depression in Dementia; HCBS = Home and Community-Based Services; MDS = Minimum Data Set; NH = Nursing Home; NR = Not Reported; NS = Not significant; PACE = Program of All-Inclusive Care; SD = Standard Deviation; SF-36 = Short-Form Health Survey; SWLS = Satisfaction with Life Scale

Note: Table rows order by similar measures of mental health.

a Study focused on samples with dementia.

Table 9 Description of participant mental health: international cross-sectional and longitudinal peer-reviewed studies

Study | Measure of Mental Health | HCBS/AL | NH | Significance | Summary
Nottingham Studies Rothera et al., 2003^57^ United Kingdom | Median Geriatric Depression Scale score; lower scores indicate less depression | HCBS: 5 | 7 | Categorical depression not significantly different between types of care | HCBS group did not differ significantly from NH group in number of individuals with depression
aBoersma et al., 1997^35^ The Netherlands | CAMDEX indicator for depression (percentage) | HCBS(a): 14.3% HCBS(b): 10.5% | 16.2% | NR | HCBS groups had fewer individuals with an indicator for depression
Chappell et al., 2004^38^ Canada | Terrible Delightful Scale and life satisfaction question | Scores were not specified | Scores were not specified | Scores were not significantly different for HCBS and NH participants, indicating they were comparable in terms of life satisfaction | HCBS group did not differ significantly from NH group in life satisfaction scores
Wodchis et al., 2003^66^ Canada | Generally happy/free from worry (percentage) | HCBS(a): 53% HCBS(b): 84% | 29% | NR | HCBS groups had more individuals that were generally happy/free from worry

CAMDEX = Cambridge Examination for Mental Disorders of the Elderly; HCBS = Home and Community-Based Services; MDS = Minimum Data Set; NH = Nursing Home; NR = Not Reported

Note: Table rows order by similar measures of mental health.

a Study focused on samples with dementia.

Table 10 Description of participant clinical status: U.S. cross-sectional and longitudinal peer-reviewed studies

Study | Measure of Clinical Status | HCBS/AL | NH | Significance | Summary
Borrayo et al., 2002^36^ | Mean number of chronic diseases; range 0–16 | HCBS: 3.34 (SD 1.80) AL: 2.01 (SD 1.25) | 2.55 (SD 1.56) | NR | On average, HCBS recipients had more chronic diseases than NH users; On average, AL residents had fewer chronic disease than NH residents
aDementia Care Project Port et al., 2005^53^, Williams et al., 2005^65^ | Mean number of 11 comorbidities Score of 2 or more on PGC-PIS indicating pain (percentage) | AL: 2.0 (SD 1.5, range 0-7), 38.9% with pain | 2.4 (SD 1.6, range 0-7), 25.0% with pain | NS; NS | On average, AL residents did not differ significantly from NH residents in the number of comorbidities; AL group did not differ significantly from NH group in number of individuals with pain
aEdelman et al., 2005^40^ | Mean number of mild to severe comorbid conditions (out of 11 conditions) from the CIRS-g | AL: 3.6 (SD 2.0) | 2.8 (SD 1.5) | p<0.05 | On average, AL residents had more mild to severe comorbid conditions
aLeon and Moyer, 1999^47^ | Mean CIRS-g Severity Index score excluding psychiatric illness; higher scores indicate more severity Has possible terminal conditions (percentage) | AL: 2.06 (SD 0.53), 34% (s.e. 0.04) | 2.11 (SD 0.36), 54% (s.e. 0.04) | p<0.001 for terminal conditions | On average, AL residents had less severe conditions; AL group had fewer individuals with possible terminal conditions
Collaborative Studies of Long-Term Care subsample aSloane et al., 2005^62^ | Mean number of comorbid conditions | AL: 3.6 (SD 2.3) | 4.4 (SD 2.2) | p=0.001 | On average, AL residents had fewer comorbid conditions
Kansas Medicaid Studies Rigler et al., 2004^56^ | CIRS-g summed disease burden score indicating disease categories but not severity (percentage) | HCBS: 27.4% score 0 or 1, 21.0% score 2 or 3, 21.0% score 4 or 5, 30.8% score ≥6 | 19.3% score 0 or 1, 39.7% score 2 or 3, 19.4% score 4 or 5, 21.6% score ≥6 | NR | HCBS group had more individuals with diseases in many disease categories
Shugarman et al., 1999^61^ | Mean Case-Mix Index score; higher scores indicate more resource intensive | HCBS: 0.84 | 1.03 | p<0.001 | On average, HCBS recipients were less resource intensive
Lee et al., 2001^46^ | Top 3 primary diagnoses for residents in each setting (percentage) | HCBS: 47.8% disease of circulatory system, 19.4% endocrine disorder, 10.4% disease of musculoskeletal system | 29.9% disease of circulatory system, 28.4% disease of nervous system, 16.4% fracture | p<0.001 | The most common primary diagnoses differed between HCBS recipients and NH residents
Mehdizadeh, 2002^51^ | Number of diseases diagnosed, including cancer, diabetes, and/or other gland diseases; circulatory diseases; musculoskeletal diseases; and respiratory diseases (percentage) | HCBS: 36% with 0, 34% with 1, 22% with 2, 8% with 3, 0% with 4 | 31% with 0, 36% with 1, 25% with 2, 8% with 3, 0% with 4 | NR | Individuals in HCBS group had similar number of diseases diagnosed as individuals in NH group
aMitchell et al., 2004^52^ | Diagnoses of cancer, congestive heart failure, and chronic obstructive pulmonary disease (percentage) | HCBS: 13.7%, 11.6%, 29.6% | 11.4%, 15.6%, 29.6% | NS, NS, NS | HCBS group had similar number of individuals diagnosed with different diseases as NH group
Reinardy and Kane, 1999^55^ | Diagnoses of heart condition, stroke, skeletal-muscular (percentage) | HCBS: 21%, 19%, 16% | 30%, 19%, 25% | p<0.05 for heart condition and skeletal-muscular | HCBS group had fewer number of individuals diagnosed with heart condition and skeletal-muscular condition
Wieland et al., 2010^64^ | Top 3 diseases/conditions for residents in each setting (percentage) | HCBS: 39.2% with diabetes, 27.1% with congestive heart failure, 26.6% with anxiety/depression PACE: 80.9% with dementia, 40.6% with stroke, 35.7% with diabetes | 50.2% with dementia, 29.5% with diabetes, 23.5% with stroke | NR | The most common diseases/conditions was different for individuals in HCBS and PACE groups than for individuals in NH group
Collaborative Studies of Long-Term Care subsample Zimmerman et al., 2003^67^ | Diagnosis of heart condition (percentage) | AL(a): 38% AL(b): 49% AL(c): 48% | 48% | NR | AL groups had similar number of individuals with a diagnosis of a heart condition as NH group
Oregon Assisted Living Frytak et al., 2001^42^; Gaugler and Kane, 2005^44^ | Mean pain and discomfort score from scale developed at RAND; higher scores indicate more pain and discomfort Mean subjective health impairment; range 0–4 with lower scores indicating better health | AL: 12.62 2.53 (SD 0.87) | 12.97 2.73 (SD 0.92) | p<0.001 for subjective health | On average, AL residents had less pain and discomfort and better subjective health
Pruchno and Rose, 2000^54^ | Mean subjective health from 4-item scale from the MAI; higher scores indicate better health | AL: 8.86 | 8.07 | p<0.05 | On average, AL residents had better subjective health

AL = Assisted Living; CIRS-g = Cumulative Illness Rating Scale-for Geriatrics; HCBS = Home and Community-Based Services; MAI = Multilevel Assessment Instrument; NH = Nursing Home; NR = Not Reported; NS = Not significant; PACE = Program of All-Inclusive Care; PGC-PIS = Philadelphia Geriatric Center-Pain Intensity Scale; SD = Standard Deviation; s.e. = Standard Error

Note: Table rows ordered by similar measures of clinical status.

a Study focused on samples with dementia.

Table 11 Description of participant clinical status: international cross-sectional and longitudinal peer-reviewed studies

Study | Measure of Clinical Status | HCBS/AL | NH | Significance | Summary
McCann et al., 2009^50^ Northern Ireland | Limiting long-term illness (percentage) General health poor (percentage) | HCBS: 89%, 31% | 99%, 64% | NR | HCBS group had fewer individuals with a limiting long-term illness and poor health
Wodchis et al., 2003^66^ Canada | Severe pain (percentage) | HCBS(a): 6% HCBS(b): 4% | 30% | NR | HCBS group had fewer individuals with severe pain

AL = Assisted Living; HCBS = Home and Community-Based Services; NH = Nursing Home; NR = Not Reported

Note: Table rows ordered by similar measures of clinical status.

Table 12 Description of participant physical function: U.S. cross-sectional and longitudinal grey literature studies

Study | Measure of Physical Function | HCBS/AL | NH | Significance | Summary
ASPE private LTC insurance cohort Miller et al., 2008^71^ | Mean number of ADL limitations; range 0–6, with higher scores indicating more dependence | HCBS: 3.4 AL: 2.9 | 4.5 | NR | On average, HCBS recipients and AL residents had fewer ADL limitations
Department of Elder Affairs, State of Florida, 2009-2010^69^ | Mean number of ADLs requiring assistance; range 0–8 | HCBS: 3.54 Managed care HCBS: 5.06 AL: 4.35 | 5.15 | NR | On average, HCBS recipients and AL residents had fewer ADLs requiring assistance
Ohio HCBS Waiver Mehdizadeh, 2007^70^ | Mean number of ADL impairments; range 0–6 | HCBS: 3.0 | 4.4 | NR | On average, HCBS recipients had fewer ADL impairments
Spillman et al., 2002^73^ | ADL or IADL impairments (percentage) | AL: 3.8% with no ADL/IADL, 32.5% with 1-2 ADL, 52.1% with 3 or more ADL, 11.1% with IADL only | 2.2% with no ADL/IADL, 19.9% with 1-2 ADL, 74.4% with 3 or more ADL, 2.9% with IADL only | NR | AL group had fewer individuals with more ADL impairments

ADL = Activities of Daily Living; AL = Assisted Living; ASPE = Assistant Secretary for Planning and Evaluation; HCBS = Home and Community-Based Services; IADL = Instrumental Activities of Daily Living; LTC = Long Term Care; NH = Nursing Home; NR = Not Reported

Note: Table rows ordered by similar measures of physical function.

Table 13 Description of participant cognitive function: U.S. cross-sectional and longitudinal grey literature studies

Study | Measure of Cognitive Function | HCBS/AL | NH | Significance | Summary
Department of Elder Affairs, State of Florida, 2009-2010^69^ | Dementia (percentage) | HCBS: 32% Managed care HCBS: 63% AL: 62% | 60% | NR | HCBS and AL groups had fewer or similar number of individuals with dementia compared with NH group
Ormond et al., 2006^72^ | Diagnosis of dementia (percentage) | HCBS(a): 12.9% HCBS(b): 20.3% | 31.9% | NR | HCBS groups had fewer individuals with a diagnosis of dementia
Spillman et al., 2002^73^ | Alzheimer's disease and other dementia (percentage) | AL: 35.3% | 46.1% | NR | AL group had fewer individuals with Alzheimer's disease and other dementia
Ohio HCBS Waiver Mehdizadeh, 2007^70^ | Cognitively impaired (percentage) | HCBS: 13.5% | 70.7% | NR | HCBS group had fewer individuals with cognitive impairment

AL = Assisted Living; CPS = Cognitive Performance Score; HCBS = Home and Community-Based Services; NH = Nursing Home; NR = Not Reported

Note: Table rows ordered by similar measures of cognitive function.

Table 14 Description of participant mental health: U.S. cross-sectional and longitudinal grey literature studies

Study | Measure of Mental Health | HCBS/AL | NH | Significance | Summary
Ormond et al., 2006^72^ | Diagnosis of depression (percentage) | HCBS(a): 8.9% HCBS(b): 19.2% | 20.4% | NR | HCBS groups had fewer individuals with a diagnosis of depression
Spillman et al., 2002^73^ | Mental disorder (percentage) | AL: 25.2% | 28.9% | NR | AL group had fewer individuals with a mental disorder

AL = Assisted Living; HCBS = Home and Community-Based Services; NH = Nursing Home; NR = Not Reported

Note: Table rows ordered by similar measures of mental health.

Table 15 Description of participant clinical status: U.S. cross-sectional and longitudinal grey literature studies

Study | Measure of Clinical Status | HCBS/AL | NH | Significance | Summary
Ormond et al., 2006^72^ | Diagnosis of stroke; other cardiovascular; endocrine, nutritional and metabolic diseases and immune disorders; diseases of the nervous system and sense organs; respiratory system diseases (percentage) | HCBS(a): 11.3%, 70.7%, 41.0%, 22.4%, 14.3% HCBS(b): 16.6%, 79.1%, 41.1%, 19.8%, 17.3% | 11.7%, 68.2%, 30.8%, 24.2%, 11.6% | NR | HCBS groups had few differences in the number of individuals diagnosed with different diseases
Spillman et al., 2002^73^ | Has diabetes; hip fracture; emphysema/asthma/COPD; stroke (percentage) | AL: 14.9%, 6.8%, 8.5%, 14.9% | 19.7%, 5.4%, 9.6%, 21.5% | NR | AL group had fewer individuals diagnosed with different diseases

AL = Assisted Living; COPD = Chronic obstructive pulmonary disease; HCBS = Home and Community-Based Services; NH = Nursing Home; NR = Not Reported

Note: Table rows ordered by similar measures of clinical status.

Tables 6 and 7 contrast levels of cognitive functioning of study participants from the peer-reviewed studies. Once again, NH samples were consistently more impaired than HCBS and AL samples.

The picture with mental health is more mixed. As shown in Tables 8 and 9, three studies35,48,60 found more depression in NH residents than in those receiving HCBS, while one study found more depression in HCBS recipients64 and another study found no difference between the groups.57 Compared with AL residents, more NH residents were depressed in two studies45,54 and fewer in two.40,62 Comparisons of other measures of mental health are also mixed. Three studies38,43,59 found no difference in psychological well-being or life satisfaction between HCBS or AL recipients and NH residents, while two studies42,66 found HCBS or AL recipients to have better psychological well-being.

Tables 10 and 11 summarize mixed information on clinical status. In one study,36 the number of conditions was lower for NH residents than for HCBS recipients, while another study found that NH residents had higher case-mix scores than HCBS recipients.61 One study52 found that NH residents had more of three specific conditions than did HCBS recipients, but the differences were not significant. The comparison is likewise mixed with AL. The rate of conditions among NH residents was higher in two studies,36,62 but lower in a third.40

Parallel information from the grey literature reflects a similar pattern. As shown in Table 12, physical function was more impaired in NH residents than in HCBS recipients or AL residents. Likewise, cognitive function was more impaired in NH residents than in those receiving HCBS or in AL (Table 13), although one study showed a similar rate of cognitive impairment between residents in AL and NH.69 The prevalence of depression (Table 14) was higher for NH residents than for HCBS recipients.72 Rates of mental disorders were similar for those receiving care in NHs and HCBS settings.73 As shown in Table 15, the rates of comorbidities were similar for HCBS recipients and NH residents.72 NH residents generally had more comorbidities than those in AL.73

#### KQ 1b Outcomes in Populations Served by HCBS Versus NHs

##### Key Points

- Evidence was low strength or insufficient for all of the outcomes examined.
- Low-strength evidence suggested that the rate of change in physical function did not differ between AL and NH residents over time. Evidence was insufficient for the HCBS versus NH comparison.
- Low-strength evidence suggested that the rate of change in cognitive function did not differ between AL and NH residents over time. Evidence was insufficient for the HCBS versus NH comparison.
- Low-strength evidence suggested that the rate of change in mental health did not differ between AL and NH residents over time. Evidence was insufficient for the HCBS versus NH comparison.
- Low-strength evidence suggested that mortality did not differ between AL and NH residents. Evidence insufficient for the HCBS versus NH comparison.
- Evidence was insufficient for acute care utilization for the AL versus NH comparison and for the HCBS versus NH comparison.
- Other outcomes were rarely examined.
- No studies conducted subgroup analysis.

##### Detailed Synthesis

Tables 16–18 describe the analyses performed and list the outcome domains addressed in the modest collection of longitudinal studies. Outcomes were measured in terms of functional change (physical or cognitive), mental health, mortality, and use of acute care services. Evidence was low strength or insufficient for the outcomes examined in detail.

Table 16 Description of analysis and outcome domains: U.S. longitudinal peer-reviewed studies

Study | Sample/Intervention/Comparison | Analysis | Outcome Domains
ASPE private LTC insurance cohort Doty et al., 2010^39^ | Private LTC insurance policyholders including HCBS recipients, AL residents, and NH residents; longitudinal panel starting at initiation of services and followed for 28 months | Descriptive statistics; logistic regression was used to predict transitions | Satisfaction
Oregon Assisted Living Frytak et al., 2001^42^ | AL and NH residents in Oregon followed for 1 year | Hierarchical linear models were used to examine how setting (AL versus NH) affected growth trajectories for each outcome studied (ability to perform activities of daily living, psychological well-being, and pain and discomfort); models adjusted for resident characteristics, including health status variables, demographic variables, and social measures | Physical function, mental health, pain and discomfort
Oregon Assisted Living Gaugler and Kane, 2005^44^ | AL and NH residents in Oregon followed for 1 year | Used the Heckman two-stage approach to model the decision to move into an AL or NH setting and then used the information about the likelihood of choosing an AL or NH (Mills ratio) to correct for selection bias in the subsequent models; ANCOVA models were used, including the Mills ratio, to determine if resident activity varied among AL and NH respondents at baseline, 6 months, 1 year, for the change from baseline to 6 months and baseline to 1 year | Activity
Marek et al., 2005^48^ | Medicaid HCBS Aging in Place program participants and NH residents in Missouri followed for 30 months | Individually matched NH residents were compared with HCBS participants, with matching based on Medicaid eligible, ADLs (within 2 points), cognitive performance (within 1 point), age (within 4 years), and admission date (within 90 days); rank-based nonparametric methods were used for testing differences in outcomes; the baseline value of each outcome was used as the stratifying variable to further adjust for individual differences in initial status | Physical function, cognitive function, mental health
aMitchell et al., 2004^52^ | A retrospective cohort of HCBS recipients and NH residents in Michigan with dementia; all persons in sample died within 1 year of admission to either HCBS program or NH | Bivariate analyses were used to compare end-of-life outcomes; logistic regression for end-of-life outcomes that differed significantly (p<0.05) between settings in the bivariate analyses with age, race, sex, functional status, ethnicity, cognitive status (Cognitive Performance Score of 6 versus 5), and days between admission and death included as covariates in all multivariate models, with other potential confounders included as covariates in individual models depending on the outcome being examined | Utilization, advance care planning, nonpalliative treatments, symptoms, other treatments
Pruchno and Rose, 2000^54^ | All participants lived on a single LTC campus in Cleveland, Ohio; residents lived in AL or NH with followup for 15 months | Logistic regression was used to estimate effects of facility on mortality; repeated ANOVA was used for cognitive status, functional ability, and depression to estimate time, facility, and time by facility interaction effects | Physical function, cognitive function, mental health, mortality
Kansas Medicaid Study Rigler et al., 2004^56^ | Kansas Medicaid ambulatory cohort (community-dwelling older adults not receiving any HCBS or NH care during study year), HCBS cohort, and NH cohorts with follow-up for 1 year | Logistic regression was used to examine associations between level of disease burden and inappropriate medication use for each cohort separately without adjustment and with adjustment for sex, age, race, and mean total number of prescriptions per month | Harms
Kansas Medicaid Study Shireman and Rigler, 2004^60^ | Kansas Medicaid HCBS and NH cohorts with follow-up for 10–12 months | Multiple linear regression was used to test for differences in costs between the settings; all demographic and major chronic condition variables were included in the models | Expenditures
Collaborative Studies of Long-Term Care subsample aSloane et al., 2005^62^ | Residential care/assisted living facility (AL) residents stratified by (a) facilities with <16 beds; (b) facilities with ≥ 16 beds of the “new-model” type that provide nursing care and cater to an impaired population; and (c) “traditional” facilities with ≥ 16 beds not meeting the “new-model” criteria and NH residents with dementia in four states with follow-up for 1 year | Modeled functional change using generalized estimating equations; modeled rates of mortality, hospitalization, and incidence of new or worsening morbidity using generalized estimating equations; adjusted for baseline age, gender, race, education, marital status, length of stay, cognitive status, and number of comorbid conditions; to adjust for differential selection probabilities among the settings, they incorporated sampling weights into all outcome analyses | Physical function, cognitive function, mental health, mortality, utilization, behavior, social function, social withdrawal, morbidity
Wieland et al., 2010^64^ | Entrants into HCBS program, PACE program, and NHs in two counties in South Carolina with followup for 5 years | Kaplan-Meier curves tested with log-rank statistics for cohort survival comparisons (overall and stratified by mortality risk) | Mortality
Dementia Care Project aZimmerman et al., 2005^68^ | Residential care/assisted living facility (AL) residents stratified by (a) facilities with <16 beds; (b) facilities with ≥ 16 beds of the “new-model” type that provide nursing care and cater to an impaired population; and (c) “traditional” facilities with ≥ 16 beds not meeting the “new-model” criteria and NH residents with dementia in four states with follow-up for 6 months | Linear mixed regression models with random effects were used to adjust the standard errors of the quality of life measures for clustering; estimated adjusted change in quality of life outcomes as the residual from regression of raw change on the baseline value | Quality of life

ADL = Activities of Daily Living; AL = Assisted Living; ANCOVA = Analysis of Covariance; ASPE = Assistant Secretary for Planning and Evaluation; HCBS = Home and Community-Based Services; NH = Nursing Home; PACE = Program of All-Inclusive Care

a Study focused on samples with dementia.

Table 17 Description of analysis and outcome domains: international longitudinal peer-reviewed studies

Study | Sample/Intervention/Comparison | Analysis | Outcome Domains
Resource Implications Study Group, 2000^32^ | Care-recipients receiving HCBS or NH care in the United Kingdom, with followup for 2 years | Tested significance of changes over time in General Health Questionnaire (GHQ) score of caregivers using t test for paired samples | Family caregivers' psychological morbidity
McCann et al., 2009^50^ | Residents in residential homes (referred to as HCBS group) and NHs in Northern Ireland, with followup for 5 years | Cox proportional hazards models were used to examine the relationship between resident and setting characteristics and risk of death during the 5-year followup adjusted for age, sex, general health, and marital status | Mortality
Nottingham Studies Rothera et al., 2002^58^ | Residents in residential homes (referred to as HCBS group) and NHs in the United Kingdom, with followup for 20 months | Survival function was calculated for the number of days survived within the 20-month period; univariate and multivariate Cox analyses controlling for age, gender, and prior placement were performed | Mortality

ADL = Activities of Daily Living; HCBS = Home and Community-Based Services; NH = Nursing Home; PACE = Program of All-Inclusive Care

Table 18 Description of analysis and outcome domains: U.S. longitudinal grey literature studies

Study | Sample/Intervention/Comparison | Analysis | Outcome Domains
ASPE private LTC insurance cohort Miller et al., 2008^71^ | Private LTC insurance policyholders, including HCBS recipients, AL residents, and NH residents; longitudinal panel starting at initiation of services and followed for 28 months | Multivariate logistic regression predicting mortality, controlling for disability, medical conditions, and demographic characteristics at baseline; multivariate fixed effects model predicting expenditures on LTC, controlling for disability, demographic characteristics, and utilization | Mortality, expenditures
Department of Elder Affairs, State of Florida, 2009-2010^69^ | Medicaid LTC users in Florida in HCBS waiver, managed care HCBS program, AL program, and NHs for fiscal year 2009–10 | Reports annual cost per client | Expenditures
Ohio HCBS Waiver Mehdizadeh 2007^70^ | Medicaid LTC users in Ohio in HCBS waiver and NHs | Reports annual Medicaid and other public expenditures for both settings | Expenditures

AL = Assisted Living; ASPE = Assistant Secretary for Planning and Evaluation; HCBS = Home and Community-Based Services; LTC = Long Term Care; NH = Nursing Home

Table 19 summarizes the results for physical function over time for HCBS recipients or AL residents with NH residents for peer-reviewed studies from the United States. Frytak et al. 2001^42^ found that although AL residents were more functional at the outset of the study, their rate of decline in physical function was the same as that of NH residents. In the study by Pruchno and Rose 2000,^54^ AL residents maintained better function throughout, but the rate of change in functional ability did not differ between AL and NH residents over time. Sloane et al. 2005^62^ found no significant differences in the mean rate of decline in function between AL and NH residents for the cohort with mild dementia or for the cohort with moderate or severe dementia. These three studies provided low-strength evidence (due to high risk of bias of the studies) that the rate of change in physical function did not differ between AL and NH residents over time. Marek et al. 2005^48^ found that NH residents remained more disabled than HCBS clients over 24 months, but they did not evaluate rate of change in function between NH and HCBS recipients. This study provided insufficient evidence for the HCBS versus NH comparison of change in physical function.

Table 19 Physical function outcomes: U.S. longitudinal peer-reviewed studies

Study | Measure | Result | Risk of Bias Rating
Oregon Assisted Living Frytak et al., 2001^42^ | Functional ability, measured as need for assistance in ADLs, over 1 year | Intercept coefficient: -29.863, p=0.000 Slope coefficient: 0.656, p=0.465 The type of setting (AL vs. NH) was strongly related to functional ability at the start of the study, but it was not significantly related to individual growth rates. Conclusions: AL and NH residents experienced change in physical functioning over the study period, but the change was not related to the type of setting they lived in, so there were no significant differences in the trajectory of physical functioning between AL and NH residents. | High
Pruchno and Rose, 2000^54^ | Mean MAI functional ability over 1 year; higher score indicates better function | There was a significant main effect for facility (AL versus NH) in the repeated ANOVA analysis, indicating that AL residents had higher mean functional scores across time compared with NH residents. The interaction term for time versus facility was not significant, indicating that there were not different trends over time in functional ability for AL versus NH residents. Conclusions: Functional ability for AL and NH residents did not change at different rates. | High
Collaborative Studies of Long-Term Care subsample aSloane et al, 2005^62^ | Mean increase in ADL dependency per 12 months; measure based on MDS ADL items | Residents with mild dementia: AL 4.29, NH 5.80, p=0.059 Residents with moderate or severe dementia: AL 0.87, NH 1.13, p=0.807 Conclusions: Mean rates of decline in ADL dependency did not differ between AL and NH residents for the cohort with mild dementia or for the cohort with moderate or severe dementia. | High
Marek et al., 2005^48^ | Mean impairment in ADLs; measured from MDS ADL items, with a range of 0–20, where higher scores indicate greater impairment | 6 months: HCBS mean 1.3, NH mean 3.2, p=0.02 12 months: HCBS mean 1.7, NH mean 3.5, p=0.04 18 months: HCBS mean 1.4, NH mean 3.8, p=0.08 24 months: HCBS mean 0.8, NH mean 3.2, p=0.00 Conclusions: ADL functioning was significantly better in the HCBS group compared with the NH group at all time periods except the 18-month time period. | High

ADL = Activities of Daily Living; AL = Assisted Living; ANOVA = Analysis of Variance; HCBS = Home and Community-Based Services; MAI = Multilevel Assessment Instrument; MDS = Minimum Data Set; NH = Nursing Home

Note: Table 16 reports analysis performed in each study.

Note: Table rows ordered by analyses of AL versus NH then by analyses of HCBS versus NH.

a Study focused on samples with dementia.

Table 20 summarizes the U.S. longitudinal peer-reviewed studies that examined changes in cognitive function. Two studies54,62 showed no significant differences in trends in cognition between AL and NH residents. Due to high risk of bias, these two studies provided low-strength evidence that the rate of change in cognitive function did not differ between AL and NH residents over time. Marek et al. 2005^48^ showed that NH residents remained more impaired than HCBS recipients at most time points, but they did not evaluate rate of change in cognition between the two groups. This high-risk-of-bias study provided insufficient evidence for the HCBS versus NH comparison of change in cognitive function.

Table 20 Cognitive function outcomes: U.S. longitudinal peer-reviewed studies

Study | Measure | Result | Risk of Bias Rating
Pruchno and Rose, 2000^54^ | Mean MMSE score over 1 year; range 0–30, with lower score indicating more impairment | There were no significant time, time by facility, or facility effects (for AL versus NH) in the repeated ANOVA analysis, indicating that AL and NH residents had similar trends in cognitive ability over time. Conclusions: Trends in cognitive ability for AL and NH residents were similar. | High
Collaborative Studies of Long-Term Care subsample aSloane et al., 2005^62^ | Mean increase in cognitive impairment per 12 months; measure based on MDS-COGS | Residents with mild dementia: AL 0.41, NH 0.71, p=0.181 Residents with moderate or severe dementia: AL -0.13, NH 0.45, p=0.093 Conclusions: Mean rates of decline in cognitive function did not differ between AL and NH residents for the cohort with mild dementia or for the cohort with moderate or severe dementia. | High
Marek et al., 2005^48^ | Mean cognitive impairment; measured from MDS Cognitive Performance Scale, with a range of 0–6, where higher scores indicate greater impairment | 6 months: HCBS mean 0.8, NH mean 1.4, p=0.00 12 months: HCBS mean 0.7, NH mean 1.8, p=0.00 18 months: HCBS mean 0.6, NH mean 1.8, p=0.00 24 months: HCBS mean 0.8, NH mean 2.1, p=0.38 Conclusions: Cognition was significantly better in the HCBS group compared with the NH group at the 6-, 12-, and 18-month time periods, but not at the 24-month time period. | High

AL = Assisted Living; ANOVA = Analysis of Variance; HCBS = Home and Community-Based Services; MDS = Minimum Data Set; MDS-COGS = Minimum Data Set Cognition Scale; MMSE = Mini-Mental State Examination; NH = Nursing Home

Note: Table 16 reports analysis performed in each study.

Note: Table rows ordered by analyses of AL versus NH then by analyses of HCBS versus NH.

a Study focused on samples with dementia.

Table 21 summarizes the results from the U.S. peer-reviewed studies in terms of mental health outcomes. Two studies54,62 found that changes in depression scores did not differ significantly between AL and NH residents. Frytak et al. 2001^42^ found no difference in psychological well-being scores from the SF-36 between AL and NH residents and no change over time for either group. The three studies provided low-strength evidence that the rate of change in mental health did not differ between AL and NH residents over time. Marek et al. 2005^48^ found that depression was higher for NH residents than for HCBS clients at 6 and 12 months, but not at baseline. The difference disappeared for the 18- and 24-month followup times. However, this study did not analyze the rate of change in depression between HCBS recipients and NH residents. This high-risk-of-bias study provided insufficient evidence for the HCBS versus NH comparison for change in mental health.

Table 21 Mental health outcomes: U.S. longitudinal peer-reviewed studies

Study | Measure | Result | Risk of Bias Rating
Oregon Assisted Living Frytak et al., 2001^42^ | Psychological well-being, measured by SF-36 mental health subscale, over 1 year | Intercept coefficient: 2.197, p=0.361 Slope coefficient: 1.575, p=0.235 Average baseline levels of psychological well-being were similar across both settings (AL and NH), and individual growth rates were insignificant. Conclusions: AL and NH residents experienced no change in psychological well-being on average. | High
Pruchno and Rose, 2000^54^ | Mean CES-D score; higher scores indicate more depressive symptoms | There were no significant time, time by facility, or facility effects (for AL versus NH) in the repeated ANOVA analysis, indicating that residents in AL and NH had similar trends for depression over time. Conclusions: Trends in depression for AL and NH residents were similar. | High
Collaborative Studies of Long-Term Care subsample aSloane et al., 2005^62^ | Mean increase in depressive symptoms per 12 months; measure based on CSDD | Residents with mild dementia: AL 1.33, NH 1.53, p=0.753 Residents with moderate or severe dementia: AL 1.52, NH 0.85, p=0.409 Conclusions: Mean rates of change in depressive symptoms did not differ between AL and NH residents for the cohort with mild dementia or for the cohort with moderate or severe dementia. | High
Marek et al., 2005^48^ | Mean score on MDS-based depression rating scale; range 0–21, with lower scores indicating less depressive symptoms | Baseline: HCBS mean 0.7, NH mean 1.1, p=0.76 6 months: HCBS mean 0.5, NH mean 1.4, p=0.00 12 months: HCBS mean 0.3, NH mean 1.5, p=0.00 18 months: HCBS mean 0.5, NH mean 1.4, p=0.14 24 months: HCBS mean 0.4, NH mean 1.3, p=0.39 Conclusions: Depression was significantly better in the HCBS group compared with the NH group at the 6- and 12-month time periods, but not at baseline, 18-, or 24-month time periods. | High

AL = Assisted Living; ANOVA = Analysis of Variance; CES-D = Center for Epidemiological Studies Depression Scale; CSDD = Cornell Scale for Depression in Dementia; HCBS = Home and Community-Based Services; MDS = Minimum Data Set; NH = Nursing Home; SF-36 = Short-Form Health Survey

Note: Table 16 reports analysis performed in each study.

Note: Table rows ordered by analyses of AL versus NH then by analyses of HCBS versus NH.

a Study focused on samples with dementia.

Two U.S. peer-reviewed studies that compared mortality in residents of AL versus NH (Table 22)54,62 found no differences. Another study found that median survival was lowest for NH residents and highest for PACE enrollees, with HCBS recipients falling between the two.64 Two peer-reviewed international studies (Table 23) showed that individuals in nursing homes had a higher risk of mortality.50,58 A study from the grey literature (Table 24) showed the highest odds of mortality for NH residents, followed by those in HCBS and AL, compared with individuals not yet receiving long-term care (LTC).71 The two published studies from the United States provided low-strength evidence (due to high risk of bias of the studies) that mortality did not differ between AL and NH residents; evidence was insufficient for mortality for the HCBS versus NH comparison.

Table 22 Mortality outcomes: U.S. longitudinal peer-reviewed studies

Study | Measure | Result | Risk of Bias Rating
Pruchno and Rose, 2000^54^ | Mortality | Facility coefficient (NH versus AL): -1.50, s.e. 0.88 The type of facility (NH versus AL) had no effect on mortality after controlling for other demographic characteristics. Conclusions: Patterns of mortality were not significantly different for AL and NH residents. | High
Collaborative Studies of Long-Term Care subsample aSloane et al., 2005^62^ | Mortality incidence rate per 100 participants per quarter | Residents with mild dementia: AL 3.2, NH 4.2, p=0.409 Residents with moderate or severe dementia: AL 3.7, NH 4.2, p=0.683 Conclusions: Mortality did not differ significantly between AL and NH residents for the cohort with mild dementia or for the cohort with moderate or severe dementia. | High
Wieland et al., 2010^64^ | Median survival | Median survival (unstratified): HCBS 3.5 years, PACE 4.2 years, NH 2.3 years | High

AL = Assisted Living; HCBS = Home and Community-Based Services; NH = Nursing Home; PACE = Program of All-Inclusive Care for the Elderly; s.e. = Standard Error

Note: Table 16 reports analysis performed in each study.

Note: Table rows ordered by analyses of AL versus NH then by analyses of HCBS versus NH.

a Study focused on samples with dementia.

Table 23 Mortality outcomes: international longitudinal peer-reviewed studies

Study | Measure | Result | Risk of Bias Rating
McCann et al., 2009^50^ Northern Ireland | Median survival; mortality risk | Median survival: HCBS 4.51 years (3.92, 4.92), NH 2.33 years (2.25, 2.59) Mortality risk hazard ratios: Not in care home: reference HCBS: 1.63 (1.44, 1.85) NH: 2.17 (1.96, 2.41) Conclusions: Residents in nursing care homes had the highest mortality risk compared with those not in care homes. | NA
Nottingham Studies Rothera et al., 2002^58^ United Kingdom | Mortality | Mortality over 20-month period: HCBS 23.3%, NH 39.1% Mortality (multivariate Cox): HCBS: reference NH: 1.85 (1.50, 2.23) Conclusions: Residents in nursing homes had higher odds of mortality than HCBS group. | NA

HCBS = Home and Community-Based Services; NH = Nursing Home

Note: Table 17 reports analysis performed in each study.

Table 24 Mortality outcomes: U.S. longitudinal grey literature studies

Study | Measure | Result | Risk of Bias Rating
Miller et al., 2008^71^ (ASPE private LTC insurance cohort) | Mortality over 28-month study period; examined characteristics at baseline (including service setting) that predict mortality | Mortality odds ratio: Not yet receiving LTC: reference HCBS: 1.497, p=0.039 AL: 1.329, p=0.147 NH: 1.822, p=0.013 The odds of mortality are highest for those receiving NH services at baseline (compared with those not yet receiving LTC at baseline). | NA

AL = Assisted Living; ASPE = Assistance Secretary for Planning and Evaluation; HCBS = Home and Community-Based Services; LTC = Long-Term Care; NA = Not Applicable; NH = Nursing Home

Note: Table 18 reports analysis performed in each study.

As shown in Table 25, two peer-reviewed studies from the United States examined the use of acute care services. Mitchell et al. found no significant difference in the odds of hospitalization for HCBS recipients compared with NH residents.52 NH residents, however, had lower odds of using hospice services. Sloane et al. found that among persons with mild dementia, those in AL used hospitals more than those in NHs,62 but they found no difference for those with moderate or severe dementia. Due to the high risk of bias of both studies, evidence was insufficient for the use of acute care services for AL versus NH residents and for HCBS recipients versus NH residents.

Table 25 Utilization outcomes: U.S. longitudinal peer-reviewed studies

Study | Measure | Result | Risk of Bias Rating
Collaborative Studies of Long-Term Care subsample aSloane et al., 2005^62^ | Hospitalization reported as incidence rate per 100 participants per quarter | Residents with mild dementia: AL 14.2, NH 8.4, p=0.009 Residents with moderate or severe dementia: AL 14.2, NH 10.0, p=0.115 Conclusions: Hospitalization rates were significantly higher among AL residents with mild dementia than among NH residents with mild dementia, but hospitalization rates were not significantly different between AL and NH residents with moderate or severe dementia. | High
aMitchell et al., 2004^52^ | Hospitalization in 90 days prior to last MDS assessment | Adjusted odds ratio: hospitalization HCBS: reference NH : 1.30 (0.98, 1.74) Conclusions: The odds of hospitalization did not differ between HCBS recipients and NH residents in the adjusted model. | High
aMitchell et al., 2004^52^ | Hospice referral any time prior to death | Adjusted odds ratio: hospice referral HCBS: reference NH: 0.26 (0.16, 0.43) Conclusions: The odds of hospice referral were significantly lower among NH residents compared with HCBS recipients in the adjusted model. | High

AL = Assisted Living; HCBS = Home and Community-Based Services; MDS = Minimum Data Set; NH = Nursing Home

Note: Table 16 reports analysis performed in each study.

Note: Table rows ordered by analyses of AL versus NH then by analyses of HCBS versus NH.

a Study focused on samples with dementia.

Other outcomes are presented in Appendix G, Tables G1 and G2.

No studies conducted subgroup analysis to determine whether outcomes differed between subgroups of HCBS recipients and NH residents for characteristics such as socioeconomic status.

#### KQ 1c Harms in Populations Served by HCBS Versus NHs

##### Key Points

- The strength of evidence for harms was low for the HCBS versus NH comparison, and it was insufficient for AL versus NH.
- Harms differed between HCBS recipients and NH residents. HCBS recipients experienced higher rates of some harms and NH residents experienced higher rates of other harms. Evidence was insufficient for harms for the AL versus NH comparison.

##### Detailed Synthesis

Three U.S. peer-reviewed studies measured harms (Table 26). The strength of evidence for harms was low for the HCBS versus NH comparison and insufficient for AL versus NH. Rigler et al. examined inappropriate medication use;56 the overall unadjusted rate was higher for HCBS recipients than for NH residents. Mitchell et al. compared end-of-life care for older individuals with advanced dementia.52 Compared with HCBS recipients, NH residents had lower odds of pain, shortness of breath, and use of anti-anxiety medication, but higher odds of having a feeding tube, experiencing pneumonia, having a pressure ulcer, or using oxygen therapy. These two studies provided low-strength evidence that harms differed between HCBS recipients and NH residents, since HCBS recipients experienced higher rates of some harms and NH residents experienced higher rates of other harms. Another study found that neither pain nor discomfort differed at baseline or over time between individuals in AL and NHs.42 This high-risk-of-bias study offered insufficient evidence for the AL versus NH comparison.

Table 26 Harms: U.S. longitudinal peer-reviewed studies

Study | Measure | Result | Risk of Bias Rating
Oregon Assisted Living Frytak et al. 2001^42^ | Pain and discomfort from scale developed at RAND; higher scores indicate more pain and discomfort | Intercept coefficient: -0.500, p=0.373 Slope coefficient: 0.615, p=0.419 Slope^2^ coefficient: -0.378, p=0.293 Type of setting (AL versus NH) did not predict one's pain and discomfort score at baseline, individual variation in the growth rates for pain and discomfort, or the acceleration rate for pain and discomfort. | High
Kansas Medicaid Rigler et al., 2004^56^ | Inappropriate medication use defined as any paid claim for an unconditionally inappropriate medication during the study year based on Beers criteria | Overall rates of any inappropriate medication use: HCBS 48%, NH 38% Conclusions: The rate of any inappropriate medication use (unadjusted) was higher in the HCBS cohort compared with the NH cohort. | High
aMitchell et al., 2004^52^ | Whether or not subjects had feeding tube; pneumonia; daily or almost daily pain; shortness of breath; pressure ulcers; oxygen therapy in the 14 days prior to last assessment; in-dwelling bladder catheters; anti-anxiety agents in the 7 days prior to last assessment | Adjusted odds ratio feeding tube: HCBS reference, NH 1.70 (1.01, 2.84) Adjusted odds ratio pneumonia: HCBS reference, NH 2.86 (1.62, 5.04) Adjusted odds ratio daily or almost daily pain: HCBS reference, NH 0.38 (0.29, 0.50) Adjusted odds ratio shortness of breath: HCBS reference, NH 0.20 (0.13, 0.28) Adjusted odds ratio pressure ulcers: HCBS reference, NH 1.46 (1.04, 2.03) Adjusted odds ratio oxygen therapy: HCBS reference, NH 2.47 (1.51, 4.05) Adjusted odds ratio foley catheter: HCBS reference, NH 1.06 (0.73, 1.53) Adjusted odds ratio antianxiety medications: HCBS reference, NH 0.63 (0.44, 0.89) | High

AL = Assisted Living; HCBS = Home and Community-Based Services; NH = Nursing Home

Note: Table 16 reports analysis performed in each study.

Note: Table rows ordered by analyses of AL versus NH, then by analyses of HCBS versus NH.

a Study focused on samples with dementia.

### KQ 2 Costs for Populations Served by HCBS Versus NHs

#### Key Points

- The strength of evidence for costs (or expenditures) for HCBS versus NHs was insufficient.
- Although Medicaid expenditures for HCBS recipients and NH residents were analyzed, other program and individual expenditures were not examined. Costs related to family burden were not addressed.

#### Detailed Synthesis

Table 27 compares data on expenditures from one U.S. peer-reviewed study.60 This study analyzed individuals' Medicaid expenditures and found that HCBS was less expensive. However, the study did not analyze other program and individual expenditures. This high-risk-of-bias study provided insufficient evidence on costs for HCBS recipients compared with NH residents. No studies analyzed costs for AL versus NH residents.

Table 27 Expenditures: U.S. longitudinal peer-reviewed studies

Study | Measure | Result | Risk of Bias Rating
Kansas Medicaid Shireman and Rigler, 2004^60^ | Mean monthly total Medicaid expenditures (for inpatient services, outpatient services, prescription drugs, and LTC services) | Adjusted mean monthly expenditures for HCBS recipients were $1,281 (p<0.001) lower per month than mean monthly expenditures for NH residents. | High

HCBS = Home and Community-Based Services; LTC = Long Term Care; NH = Nursing Home

Note: Table 16 reports analysis performed in each study.

Table 28 presents expenditure data from grey literature studies. One study on private LTC insurance users compared monthly expenditures on LTC for HCBS recipients and residents of AL and NHs. It found that expenditures were highest for NH residents.71 Three studies measured annual per-client Medicaid expenditures and found that total Medicaid expenditures were higher for NH residents compared with HCBS recipients or AL residents.69,70 These studies did not include other program or individual expenditures, nor did they address costs related to family burden.

Table 28 Expenditures: U.S. longitudinal grey literature studies

Study | Measure | Result | Risk of Bias Rating
ASPE private LTC insurance cohort Miller et al., 2008^71^ | Monthly costs of care – LTC expenditures on either home health care, AL, or NH care estimated by using individuals' reported patterns of service use and cost information by zip code for a variety of service modalities taken from MetLife Market Surveys | Fixed-effect model coefficient results No paid LTC at baseline: reference HCBS: 0.557, p=0.000 AL: 0.618, p=0.000 NH: 1.133, p=0.000 HCBS recipients had 56%, AL residents had 62%, and NH residents had 113% higher monthly expenditures compared with individuals who were not receiving paid LTC at baseline. | NA
Department of Elder Affairs, State of Florida, 2009-2010^69^ | Annual Medicaid cost per client, FY 2009–10 | HCBS: $9,026 Managed care HCBS: $18,504 AL: $9,902 NH payments only: $58,055 | NA
Ohio HCBS Waiver Mehdizadeh, 2007^70^ | Medicaid expenditures per person, per year, October 2004–September 2005 | HCBS: $23,702 NH: $55,571 | NA

AL = Assisted living; ASPE = Assistant Secretary for Planning and Evaluation; HCBS = Home and Community-Based Services; LTC = Long Term Care; NA = Not Applicable; NH = Nursing Home

Note: Table 18 reports analysis performed in each study.