# References

1 Feder J, Komisar HL, Niefeld M. Long-term care in the United States: an overview. Health Affairs. 2000;19(3):40-56. [pmid: 10812780].
2 Feinberg L, Reinhard S, Houser A, et al. Valuing the Invaluable: 2011 Update The Growing Contributions and Costs of Family Caregiving. Washington, DC. Institute APP. 2011.
3 Stone RI, Reinhard SC. Place of assisted living in long-term care and related service systems. Gerontologist. 2007;47(Special Issue 3):23-32. [pmid: 18162566].
4 Kane RA, Cutler LJ. Promoting Homelike Characteristics and Eliminating Institutional Characteristics in Community-Based Residential Care Settings: Insights from an 8-State Study. Seniors Housing and Care Journal. 2009;17(1):15-37.
5 Kaye HS, Harrington C, LaPlante MP. Long-term care: who gets it, who provides it, who pays, and how much?. Health Affairs. 2010;29(1):11-21. [pmid: 20048355].
6 National Council on Disability. The State of 21st Century Long-Term Services and Supports: Financing and Systems Reform for Americans with Disabilities. 2005.
7 U.S. Dept. of Health and Human Services. Who Needs Long-Term Care?. National Clearing House for Long-Term Care Information. 2008. http://www.longtermcare.gov/LTC/Main_Site/Understanding/Index.aspx.
8 Medicaid and Long-Term Care Services and Supports. Kaiser Commission on Medicaid and the Uninsured. #2186-08. 2011. http://www.kff.org/medicaid/upload/2186-08.pdf.
9 LTC Stats: Nursing Facility Operational Characteristics Report. American Health Care Association. 2012. http://www.ahcancal.org/research_data/oscar_data/Nursing%20Facility%20Operational%20Characteristics/OperationalCharacteristicsReport_Mar2012.pdf.
10 AARP Public Policy Institute. Fact Sheet: Nursing Homes. 2007. http://www.aarp.org/research/ppi/.
11 Eiken S, Sredl K, Burwell B, et al. Medicaid Expenditures for Long-term Services and Supports: 2011 Update Thomson Reuter. Cambridge, MA. 2011. http://www.hcbs.org/files/208/10395/2011LTSSExpenditures-final.pdf.
12 Rosenbaum S. The Olmstead decision: implications for state health policy. Health Affairs. Sep-Oct. 2000;19(5):228-32. [pmid: 10992673].
13 Medicaid Home and Community-Based Services Programs: Data Update. Kaiser Commission on Medicaid and the Uninsured. 2011. http://www.kff.org/medicaid/upload/7720-05.pdf.
14 State Options That Expand Access to Medicaid Home and Community-Based Services. Kaiser Commission on Medicaid and the Uninsured. #8241. 2011. http://www.kff.org/medicaid/upload/8241.pdf.
15 American Health Care Association. Medicaid-Financed Home and Community-Based Services Research/A Synthesis. 2007.
16 O'Keeffe J, Saucier P, Jackson B, et al. Understanding Medicaid Home and Community Services: A Primer. U.S. Department of Health and Human Services, Office of the Assistant Secretary for Planning and Evaluation. 2010. http://aspe.hhs.gov/daltcp/reports/2010/primer10.pdf.
17 Kassner E. Home and Community-Based Long-Term Services and Supports for Older People. AARP Public Policy Institute. 2011. http://assets.aarp.org/rgcenter/ppi/ltc/fs222-health.pdf.
18 Stevenson DG, Cohen MA, Tell EJ, et al. The complementarity of public and private long-term care coverage. Health Affairs. Jan-Feb. 2010;29(1):96-101. [pmid: 20048366].
19 Kane RA, Kane RL, Ladd RC. The Heart of Long-Term Care. London. Oxford University Press. 1998.
20 Kemper P, Applebaum R, Harrigan M. Community care demonstrations: what have we learned?. Health Care Financing Review. 1987;8(4):87-100. [pmid: 10312191].
21 Wiener JM, Hanley RJ. Caring for the disabled elderly: There's no place like home. Shortell S, Reinhardt U, editors. Improving health policy and management. Ann Arbor, MI. Health Administration Press. 1992:75-110.
22 Kemper P. The Evaluation of the National Long-Term Care Demonstration. Health Services Research. 1988;23(1):161-73. [pmid: 3130326].
23 Weiner J. State Cost Containment Initiatives for Long-Term Care Services for Older People Congressional Research Service. 2000.
24 Levine SA, Boal J, et al. Home Care. JAMA. 2003;290:1203-7. [pmid: 12953004].
25 Kaye HS, LaPlante MP, Harrington C. Do noninstitutional long-term care services reduce Medicaid spending?. Health Aff (Millwood). Jan-Feb. 2009;28(1):262-72. [pmid: 19124878].
26 Morris JN, Fries BE, Steel K, et al. Comprehensive clinical assessment in community setting: applicability of the MDS-HC. J Am Geriatr Soc. Aug. 1997;45(8):1017-24. [pmid: 9256857].
27 Liberati A, Altman DG, Tetzlaff J, et al. The PRISMA statement for reporting systematic reviews and meta-analyses of studies that evaluate health care interventions: explanation and elaboration. J Clin Epidemiol. Oct. 2009;62(10):e1-34. [pmid: 19631507].
28 Agency for Healthcare Research and Quality. Assessing the Quality and Applicability of Included Studies. Agency for Healthcare Research and Quality, Methods Reference Guide for Effectiveness and Comparative Effectiveness Reviews. Rockville, MD. Agency for Healthcare Research and Quality. 2007.
29 Viswanathan M, Berkman ND. Development of the RTI item bank on risk of bias and precision of observational studies. Journal of Clinical Epidemiology. Feb. 2012;65(2):163-70. [pmid: 21959223].
30 Owens DK, Lohr KN, Atkins D, et al. AHRQ series paper 5: grading the strength of a body of evidence when comparing medical interventions--agency for healthcare research and quality and the effective health-care program. Journal of Clinical Epidemiology. May. 2010;63(5):513-23. [pmid: 19595577].
31 Atkins D, Chang SM, Gartlehner G, et al. Assessing applicability when comparing medical interventions: AHRQ and the Effective Health Care Program. J Clin Epidemiol. Nov. 2011;64(11):1198-207. [pmid: 21463926].
32 Psychological morbidity among informal caregivers of older people: a 2-year follow-up study. The Resource Implications Study Group of the MRC study of cognitive function and ageing (RIS MRC CFAS). Psychological Medicine. 2000;30(4):943-55. [pmid: 11037102].
33 Applebaum RA, Mehdizadeh SA, Straker JK. The changing world of long-term care: a state perspective. Journal of Aging & Social Policy. 2004;16(1):1-19. [pmid: 15040704].
34 Beattie ERA, Song J, LaGore S. A comparison of wandering behavior in nursing homes and assisted living facilities. Research & Theory for Nursing Practice. 2005;19(2):181-96. [pmid: 16025697].
35 Boersma F, Eefsting JA, van den Brink W, et al. Care services for dementia patients: predictors for service utilization. International Journal of Geriatric Psychiatry. 1997;12(11):1119-26. [pmid: 9427096].
36 Borrayo EA, Salmon JR, Polivka L, et al. Utilization across the continuum of long-term care services. Gerontologist. 2002;42(5):603-12. [pmid: 12351795].
37 Challis D, Mozley CG, Sutcliffe C, et al. Dependency in older people recently admitted to care homes. Age & Ageing. 2000;29(3):255-60. [pmid: 10855909].
38 Chappell NL, Dlitt BH, Hollander MJ, et al. Comparative costs of home care and residential care. Gerontologist. 2004;44(3):389-400. [pmid: 15197293].
39 Doty P, Cohen MA, Miller J, et al. Private long-term care insurance: value to claimants and implications for long-term care financing. Gerontologist. 2010;50(5):613-22. [pmid: 20299425].
40 Edelman P, Fulton BR, Kuhn D, et al. A comparison of three methods of measuring dementia-specific quality of life: perspectives of residents, staff, and observers. Gerontologist. Oct. 2005;1(1):27-36. [pmid: 16230747].
41 Franks JS. Comparing Perceived Quality of Life in Nursing Homes and Assisted Living Facilities. Journal of Gerontological Social Work. 2004;43(1):119-30.
42 Frytak JR, Kane RA, Finch MD, et al. Outcome trajectories for assisted living and nursing facility residents in Oregon. Health Services Research. 2001;36(1 Pt 1):91-111. [pmid: 11324746].
43 Gaugler JE. Family Involvement and Resident Psychosocial Status in Long-Term Care. Clinical Gerontologist. 2006;29(4):79-98. [pmid: 22624576].
44 Gaugler JE, Kane RA. Activity Outcomes for Assisted Living Residents Compared to Nursing Home Residents: Findings from a Longitudinal Study. Activities, Adaptation & Aging. 2005;29(3):33-58. [pmid: 18418292].
45 Gruber-Baldini AL, Zimmerman S, Boustani M, et al. Characteristics associated with depression in long-term care residents with dementia. Gerontologist. 2005;45(Special Issue 1):50-5. [pmid: 16230749].
46 Lee T, Kovner CT, Mezey MD, et al. Factors influencing long-term home care utilization by the older population: implications for targeting. Public Health Nursing. 2001;18(6):443-9. [pmid: 11737813].
47 Leon J, Moyer D. Potential cost savings in residential care for Alzheimer's disease patients. Gerontologist. 1999;39(4):440-9. [pmid: 10495582].
48 Marek KD, Popejoy L, Petroski G, et al. Clinical outcomes of aging in place. Nurs Res. May-Jun. 2005;54(3):202-11. [pmid: 15897796].
49 Margallo-Lana M, Swann A, O'Brien J, et al. Prevalence and pharmacological management of behavioural and psychological symptoms amongst dementia sufferers living in care environments. International Journal of Geriatric Psychiatry. 2001;16(1):39-44. [pmid: 11180484].
50 McCann M, O'Reilly D, Cardwell C. A Census-based longitudinal study of variations in survival amongst residents of nursing and residential homes in Northern Ireland. Age & Ageing. 2009;38(6):711-7. [pmid: 19752201].
51 Mehdizadeh SA. Health and Long-Term Care Use Trajectories of Older Disabled Women. Gerontologist. 2002;42(3):304-13. [pmid: 12040132].
52 Mitchell SL, Morris JN, Park PS, et al. Terminal care for persons with advanced dementia in the nursing home and home care settings. Journal of Palliative Medicine. 2004;7(6):808-16. [pmid: 15684848].
53 Port CL, Zimmerman S, Williams CS, et al. Families filling the gap: comparing family involvement for assisted living and nursing home residents. Gerontologist. 2005;45(Special Issue 1):87-95. [pmid: 16230755].
54 Pruchno RA, Rose MS. Effect of long-term care environments on health outcomes. Gerontologist. 2000;40(4):422-8. [pmid: 10961031].
55 Reinardy J, Kane RA. Choosing an adult foster home or a nursing home: residents' perceptions about decision making and control. Soc Work. Nov. 1999;44(6):571-85. [pmid: 10568028].
56 Rigler SK, Perera S, Jachna C, et al. Comparison of the association between disease burden and inappropriate medication use across three cohorts of older adults. American Journal of Geriatric Pharmacotherapy. 2004;2(4):239-47. [pmid: 15903282].
57 Rothera I, Jones R, Harwood R, et al. Health status and assessed need for a cohort of older people admitted to nursing and residential homes. Age & Ageing. 2003;32(3):303-9. [pmid: 12720617].
58 Rothera IC, Jones R, Harwood R, et al. Survival in a cohort of social services placements in nursing and residential homes: factors associated with life expectancy and mortality. Public Health. 2002;116(3):160-5. [pmid: 12082598].
59 Schroeder JM, Nau KL, Osness WH, et al. A comparison of life satisfaction, functional ability, physical characteristics, and activity level among older adults in various living settings. Journal of Aging & Physical Activity. 1998;6(4):340-9.
60 Shireman TI, Rigler SK. Penny wise, pound wise: a comparison of Medicaid expenditures for home and community-based services versus nursing facility care for older adults. Home Health Care Services Quarterly. 2004;23(4):15-28. [pmid: 15778150].
61 Shugarman LR, Fries BE, James M. A comparison of home care clients and nursing home residents: can community based care keep the elderly and disabled at home?. Home Health Care Serv Q. 1999;18(1):25-45. [pmid: 10947561].
62 Sloane PD, Zimmerman S, Gruber-Baldini AL, et al. Health and functional outcomes and health care utilization of persons with dementia in residential care and assisted living facilities: comparison with nursing homes. Gerontologist. Spec No 1. 2005;45(1):124-32. [pmid: 16230759].
63 Sloane PD, Zimmerman S, Hanson L, et al. End-of-life care in assisted living and related residential care settings: comparison with nursing homes. Journal of the American Geriatrics Society. 2003;51(11):1587-94. [pmid: 14687388].
64 Wieland D, Boland R, Baskins J, et al. Five-Year Survival in a Program of All-Inclusive Care For Elderly Compared With Alternative Institutional and Home- and Community-Based Care. Journals of Gerontology: Series A: Biological Sciences and Medical Sciences. 2010;65A(7):721-6.
65 Williams CS, Zimmerman S, Sloane PD, et al. Characteristics associated with pain in long-term care residents with dementia. Gerontologist. 2005;45(Special Issue 1):68-73. [pmid: 16230752].
66 Wodchis WP, Hirdes JP, Feeny DH. Health-related quality of life measure based on the minimum data set. International Journal of Technology Assessment in Health Care. 2003;19(3):490-506. [pmid: 12962335].
67 Zimmerman S, Gruber-Baldini AL, Sloane PD, et al. Assisted living and nursing homes: apples and oranges?. Gerontologist. 2003;43(Special Issue 2):107-17. Note: Included in special issue “Challenges in Nursing Home Care,” with guest editors Jill Quadagno, Sidney Stahl, and Laurence G. Branch. [pmid: 12711731].
68 Zimmerman S, Sloane PD, Williams CS, et al. Dementia care and quality of life in assisted living and nursing homes. Gerontologist. 2005;45(Special Issue 1):133-46. [pmid: 16230760].
69 Long-Term Care Community Diversion Pilot Project 2009-2010 Legislative Report. Prepared by Department of Elder Affairs State of Florida. 2011. http://elderaffairs.state.fl.us/doea/pubs/pubs/LTC_Community_Diversion_PilotProject_2010_11.pdf.
70 Mehdizadeh S. PASSPORT Cost Neutrality: How Do the Total Medicaid and Other Public Costs of Maintaining a PASSPORT Consumer in the Community Compare to That of a Nursing Facility Resident?. Scripps Gerontology Center Miami University. Oxford, OH. May. 2007.
71 Miller JS, Shi X, Cohen MA. Private Long-Term Care Insurance: Following an Admission Cohort over 28 Months to Track Claim Experience, Service Use and Transitions. Prepared by LifePlans, Inc. for the Office of Disability, Aging and Long-Term Care Policy, Office of the Assistant Secretary for Planning and Evaluation under Contract #HHS-100-02-0014. Washington, D.C. U.S. Department of Health and Human Services. April. 2008. http://aspe.hhs.gov/daltcp/reports/2008/coht28mo.pdf.
72 Ormond BA, Sommers AS, Black KJ. Examination of Texas Rider 37: A Medicaid “Money Follows the Person” Long-Term Care Initiative. Prepared by The Urban Institute for the Office of Disability, Aging and Long-Term Care Policy, Office of the Assistant Secretary for Planning and Evaluation under Contract #HHS-100-03-0011. Washington, D.C. U.S. Department of Health and Human Services. May. 2006. http://aspe.hhs.gov/daltcp/reports/2006/TXltc.pdf.
73 Spillman BC, Liu K, McGuilliard C. Trends in Residential Long-Term Care: Use of Nursing Homes and Assisted Living and Characteristics of Facilities and Residents. Prepared by The Urban Institute for the Office of Disability, Aging and Long-Term Care Policy, Office of the Assistant Secretary for Planning and Evaluationunder Contract #HHS-100-97-0010. Washington, D.C. U.S. Department of Health and Human Services. November. 2002. http://aspe.hhs.gov/daltcp/reports/2002/rltct.pdf.
74 Johnson PE, Veazie PJ, Kochevar L, et al. Understanding variation in chronic disease outcomes. Health Care Manag Sci. Aug. 2002;5(3):175-89. [pmid: 12363045].
75 Cutler LJ, Kane RA, Degenholtz HB, et al. Assessing and comparing physical environments for nursing home residents: Using new tools for greater specificity. The Gerontologist. 2006;45(1):42-51. [pmid: 16452283].
76 Feng Z, Fennell ML, Tyler DA, et al. The Care Span: Growth of racial and ethnic minorities in US nursing homes driven by demographics and possible disparities in options. Health Affairs. Jul. 2011;30(7):1358-65. [pmid: 21734211].
77 Kane RL, Lum TY, Kane RA, et al. Does Home and Community-Based Care Affect Nursing Home Use?. Journal of Aging & Social Policy. (in press). 25.
78 Eiken S, Burwell B, Sredl K. An Examination of the Woodwork Effect Using National Medicaid Long-Term Services and Supports Data. Journal of Aging & Social Policy. (in press). 25.
79 LaPlante M. The Woodwork Effect in Medicaid Long-Term Services and Supports. Journal of Aging & Social Policy. (in press). 25.
80 Weissert W. The Woodwork Effect: Estimating It and Controlling the Damage. Journal of Aging & Social Policy. (in press). 25.