# Methods

We conducted the comparative effectiveness review of long-term care (LTC) for older adults following the methods suggested in the Agency for Health Care Research and Quality (AHRQ) Methods Guide for Effectiveness and Comparative Effectiveness Reviews (http://www.effectivehealthcare.ahrq.gov/methodsguide.cfm). The main sections in this chapter reflect the elements of the protocol publicly posted on the AHRQ Effective Healthcare program Web site, and they correspond to the PRISMA checklist.27

## Topic Refinement and Review Protocol

The topic for this comparative effectiveness review was publically nominated through the Effective Healthcare Web site. Investigators developed preliminary Key Questions (KQs) with input from various stakeholder groups (Table 1). The KQs were posted on AHRQ's Web site for public comment for 4 weeks. Public comments and input from the Technical Expert Panel (TEP), convened to provide methodological and content expertise, were used to develop the final KQs and protocol.

Table 1 Perspectives and organizations represented by Key Informants

Perspective | Organization
Policy | - Centers for Medicare & Medicaid Services; - Office of Disability, Aging and Long-term Care Policy, Assistant Secretary for Planning and Evaluation, Department of Health and Human Services
Provider | - American Health Care Association; - Leading Age
Consumer | - National Center for Assisted Living; - AARP
Research | - Scripps Gerontology Center, Ohio

## Literature Search Strategy

An exploratory search indicated that relevant literature would be scarce and difficult to locate. Therefore, we used several strategies to identify potential relevant studies. We searched the bibliographic databases MEDLINE (via OVID) and AGELINE for randomized controlled trials (RCTs) and observational studies of LTC published from 1995 to March 2012. The search algorithm, developed with input from content experts and a biomedical librarian and independently reviewed by another librarian, consisted of a combination of text words and subject index terms in the following categories: intervention (long-term care); services (nursing home [NH] and various types of Home and Community-Based Services [HCBS]); and study design (RCTs and observational studies). We collected search terms related to NHs and HCBS, and combined them using the Boolean AND operator to retrieve articles that compared NHs and HCBS. We retrieved relevant RCTs and observational trials using search filters specific to study design. The search algorithm with the specific strings and index terms is listed in Appendix A. We used an equivalent search strategy for AGELINE database by adapting the search terms to meet database specific syntax requirements.

Bibliographic database searches were supplemented with backward and forward citation searches of relevant articles and by hand searching. We compiled a list of prominent authors in the field and searched specifically for their work to identify missing publications. Finally, we asked the TEP to review the included set and provide missing literature (if any) from their personal files. We searched the grey literature in the form of program evaluation reports, reports to government, and analyses from research organizations and foundations. We developed a comprehensive list of grey literature sources with input from the TEP. Grey literature sources (Appendix B) included Web sites of relevant federal and state agencies (such as the Centers for Medicare & Medicaid Services [CMS] and the Administration on Aging), research organizations (such as the Lewin Group, Abt Associates, and Mathematica Policy Research), foundations (such as the Robert Wood Johnson Foundation), and advocacy groups.

## Inclusion and Exclusion Criteria

The target population was older adults (age ≥60) using LTC. RCTs and quasi-experimental observational study designs were eligible for inclusion. Studies needed to include some comparison of HCBS and NHs. Studies could compare the populations across HCBS and NHs at a particular time point (cross-sectional design) or evaluate changes in outcomes over time (longitudinal design). To capture studies most relevant to the current delivery of LTC in the United States, we limited studies by date (1995 to March 2012), language (English), and geographical location (United States and economically developed countries with well-established health and LTC systems, including Canada, United Kingdom, Australia, and New Zealand, as well as Norway, Sweden, and other European countries). Specific eligibility criteria organized by PICOTS (Population, Intervention, Comparator, Outcomes, Timing, Setting) framework are listed in Table 2. Grey literature studies that satisfied the above criteria were also eligible for inclusion.

Table 2 Inclusion criteria

Domain | Criteria for Inclusion
Population | - Older adults (age ≥60) using LTC (with exception for recipients of PACE where eligibility begins at 55)
Intervention | - LTC through HCBS
Comparator | - LTC in NHs
Outcomes | - Physical function, cognition, mental health outcomes (e.g., depression and anxiety), quality of life, social function, satisfaction, outcomes related to family caregivers, death, place of death, use of acute care services (e.g., hospitals, emergency departments); - Harms, including accidents, injuries, inadequate preventive care, unnecessary hospitalizations, abuse, or neglect; - Costs to programs (i.e., Medicaid and other public programs) and to individuals. Costs to programs include spending on LTC services, as well as spending on acute care services, housing subsidies, food stamps, and other transfer programs. Costs to individuals include out-of-pocket spending on LTC and acute care services (including insurance premiums, deductibles, and co-pays) and costs of family burden
Timing | - Longitudinal studies: varying periods ranging from 6 months to many years
Setting | - U.S; economically developed countries with well-established health and LTC systems (Canada, Australia, United Kingdom, New Zealand, Norway, Sweden, and other European countries)
Study Design Publication dates Language | - Cross-sectional studies and longitudinal studies that directly compare populations and outcomes of care between HCBS recipients and NH residents; - 1995 to March 2012; - English

HCBS = Home and Community-Based Services; LTC = Long-Term Care; NH = Nursing Home; PACE = Program of All-Inclusive Care for the Elderly

## Study Selection

Bibliographic database search results were downloaded to an Endnote™ reference management system. Eligible studies were identified in two stages. In the first stage, two investigators independently reviewed titles and abstracts of all references; studies deemed eligible for inclusion by either investigator were further evaluated. In the second stage, two investigators independently reviewed full text to determine if studies met inclusion criteria. Differences in full-text screening decisions were resolved by discussion or, when necessary, by consultation with a third investigator. For all studies excluded at the full-text screening stage, Eligibility status and one exclusion reason was documented. Reasons for exclusion were coded as: non-English language study; pre-1995 study; not a geographical setting of interest (countries other than those listed above); postacute care population (short-stay NH residents or Medicare home health recipients); no relevant comparison; no relevant settings or sample; no relevant characteristics or outcomes. The excluded studies and the reason for exclusion are listed in Appendix C.

## Data Extraction

One reviewer extracted data from included studies directly into evidence tables and a second reviewer validated the data. Disagreements were resolved by consensus or, when needed, by consultation with a third reviewer. We abstracted data on study design; location (United States or international); sample populations; type of intervention and comparison (setting, services provided); length of followup for longitudinal studies; characteristics of study participants; and outcomes. Appendix D is an evidence table, organized alphabetically by author name.

## Risk of Bias of Individual Studies

We assessed methodological risk of bias of longitudinal peer-reviewed studies from the United States using criteria specific to study design according to current AHRQ guidance.28 Two investigators independently assessed the risk of bias of each study. The full team of investigators validated the assessments.

We found no RCTs that met inclusion criteria. We assessed risk of bias using questions adapted from the RTI item bank for risk of bias.29 Evaluation of selection bias was a key component of risk of bias assessment. We gave a higher rating to studies that accounted for differences in case mix across setting using techniques such as multivariate analysis, propensity score matching, or instrumental variables. In addition to selection bias, we evaluated completeness of intervention specification, use of equivalent outcome measures across experimental and control groups, and differential loss to followup. We assigned summary risk of bias ratings (high, moderate, low, or unclear) based on the overall risk of bias created by the individual components assessed.

## Data Synthesis

Heterogeneity in populations and interventions/settings across studies precluded quantitative synthesis of results. Instead, we analyzed results qualitatively to arrive at conclusions regarding (1) the extent to which HCBS and NHs serve similar populations and (2) the differences in outcomes of the services when tested on similar populations. We separately analyzed the results from the grey literature and international studies.

We compared characteristics of HCBS recipients with those of NH residents using data from cross-sectional and longitudinal studies that reported case mix. We evaluated differences in populations across settings in the domains of physical function, cognition, mental health, and comorbidities. We qualitatively synthesized results from individual studies to evaluate the extent to which HCBS and NHs serve similar populations.

To compare outcomes of care for HCBS versus NHs, we first categorized longitudinal studies by the outcome domain investigated. We compared results across settings for specific outcome domains such as physical function, cognitive function, mental health, use of acute care services, harms, and costs. We qualitatively synthesized result to evaluate the differences in trajectories of older adults as a result of care provided through HCBS or in NHs. Throughout the analysis, we treated assisted living (AL) as a separate subset within HCBS, because AL encompasses elements of both community-based and institutional care. We analyzed international studies separately to account for differences in context. We also analyzed grey literature studies separately.

## Strength of the Body of Evidence

We evaluated the overall strength of evidence using methods developed by the AHRQ Evidence-based Practice Center Program30 for the following outcomes: physical function, cognitive function, mental health, mortality, use of acute care services, harms, and costs. We aggregated all relevant outcome measures within a particular outcome domain and evaluated strength of evidence based on the aggregated set. Because many possible outcomes measures may be used within one domain, and because all included studies used an observational design, we were interested in consistency in the direction of effect. We evaluated strength of the evidence on four required domains:

- Risk of bias (whether the studies for a given outcome or comparison had good internal validity). We rated overall risk of bias as low, moderate, or high based on individual study designs and conduct. For each outcome (such as cognitive function) and each comparison (such as a broad definition of HCBS versus NH, or AL as a subset of HCBS versus NH) we assigned an overall risk of bias based on the average of the individual study risk of bias scores. We assigned a moderate risk of bias rating if the preponderance of studies were of moderate risk of bias, or if one study involved a study population several times larger than the other contributing studies combined. We assigned a high risk of bias rating if the preponderance of individual studies showed high risk of bias or if a moderate risk of bias study did not have a large enough study population to justify dominating the rating.
- Consistency (whether the included studies had the same direction of effect). We rated consistency as consistent, inconsistent, or unknown (e.g., a single study was evaluated).
- Directness (reflecting a single, direct link between the intervention of interest and the outcome, or the direct comparison of the interventions of interest). Directness can be either direct or indirect.
- Precision (degree of certainty surrounding an effect estimate of a given outcome). Precision is either precise or imprecise. Since we did not conduct quantitative meta-analysis of the findings, we based precision on the individual study measures. Since the outcome domains were assessed as aggregates of relevant outcome measures, the precision score also reflects how fully the set of outcome measures describes the outcome domain.

The full team of investigators worked through consensus to rate the individual domains qualitatively. The team assigned an overall strength of evidence summary rating of high, moderate, or low strength of evidence for domains in KQ1b, KQ1c, and KQ2. We did not rate strength of evidence for KQ1a. We based strength of evidence on the longitudinal peer-reviewed studies from the United States; relevant international and grey literature studies supplemented our analysis but were not included in the strength of evidence ratings.

Given the absence of RCTs, we graded no outcome as having high-strength evidence. We graded an outcome as insufficient when evidence did not permit a conclusion. Thus, a single small observational study for a given outcome and comparison was always rated as insufficient. For all other bodies of evidence, we took the perspective of policymakers facing decisions within a political environment and process. Even when evidence is lacking, decisions are required. Thus, we took a liberal stance for assigning a low rating. We graded evidence as low-strength if the studies within a set were high risk of bias but consistent in their finding of benefit or no difference (and directness was automatic because we only reviewed studies of direct comparisons of HCBS with NH using patient centered outcomes).

## Applicability

According to AHRQ guidance,31 we assessed applicability defined as the extent to which effects observed in published studies are likely to reflect the expected results when the specific intervention is applied to the population of interest in “real world” contexts. We assessed applicability separately from strength of evidence based on the following criteria: eligibility requirements for enrollment; case mix; type, frequency, and intensity of services delivered; outcomes measured and the timing of measurement; and sources of financing (Table 3).

Table 3 Criteria for assessing applicability

Domain | Criteria Used To Assess Applicability
Population | - Criteria for enrollment into the program; - Characteristics of population enrolled: demographics; clinical status; functional status; morbidities; cognition; mental illness; and source of finance (Medicaid or self)
Intervention | - LTC through HCBS; ‒ Type, frequency, and intensity of services; ‒ Availability and access to programs
Comparator | - LTC in NHs
Outcomes | - Outcomes assessed (or not assessed) and the time period over which they were assessed
Setting | - Country/geographical region; rural/urban

HCBS = Home and Community-Based Services; LTC = Long-Term Care; NH = Nursing Home

## Peer Review and Public Commentary

Experts in LTC from research and consumer organizations were invited to provide external peer review of this systematic report; AHRQ and an associate editor also provided comments. See the Acknowledgments section for a full listing of peer reviewers. The draft report was posted on the AHRQ Web site for 4 weeks to elicit public comment. Public comments were received from the American Health Care Association, as well as three individuals. We addressed all reviewer comments, revising the text as appropriate, and documented everything in a disposition of comments report that will be made available 3 months after the Agency posts the final systematic review on the AHRQ Web site.