# Introduction

## Definition

Long-term care (LTC) refers to a broad range of services designed to provide assistance over prolonged periods. LTC services attempt to compensate for loss of function due to chronic illness or physical or mental disability.1 LTC represents the intersection of personal services, housing, and medical care (especially chronic disease management). LTC varies in frequency and intensity according to the needs of the recipients. It includes hands-on, direct care as well as general supervisory assistance. LTC includes support for activities of daily living (ADLs), instrumental activities of daily living (IADLs), and routine nursing services such as administration of medications.2 LTC may affect older people's quality of life. Its impact also extends to family members, who are often the primary source of support for older adults with functional limitations.2 LTC may include services and supports for family members and other unpaid caregivers.

This review compares LTC for older adults delivered through Home and Community-Based Services (HCBS) with care delivered in nursing homes (NHs).

HCBS refers to services provided in an array of noninstitutional settings, including recipients' homes; community group living arrangements such as congregate housing, adult foster care, residential care (RC) and assisted living (AL) facilities (the last two terms are often used interchangeably although they are not always synonymous; we use the term AL throughout this report); and community settings such as adult day care and adult day health.

NHs are state-licensed institutional facilities offering 24-hour room and board, supervision, and nursing care. NH services may include personal care, ADL support, medical management, nursing management, medication management, restorative nursing, palliative care, physical rehabilitation (either as a short-term service associated with postacute care or as maintenance rehabilitation), social activities, and transportation. NH care may also include family councils and support groups for informal caregivers.

AL appeared as a care modality in the 1980s and is now offered and licensed under a variety of names. AL presents a taxonomic problem because AL settings vary so widely in the degree of privacy and space of the living arrangements and in the extent and range of services provided. The variation stems both from state licensure policies (that either require or prohibit specified services or living characteristics) and from the business models of the providers.3 AL rarely offers the intensity of care, especially nursing care, found in nursing homes. Nonetheless, AL is an institution, albeit often a more livable one. Further complicating this picture is the emergence of so-called comprehensive care retirement communities in which a single campus offers services ranging from unassisted housing to AL to NHs. For this review, we examined the services individually. We categorized care provided in AL facilities as a subset of HCBS. However, we also examined AL separately, because in many ways, it represents a midway position between care in NHs care and care in recipients' own homes.4

The services provided through HCBS resemble those provided in NHs. However, HCBS services may need to be pieced together from multiple agencies and independent providers, with or without overall coordination or management. Care through HCBS includes care coordination or case management, personal care assistant service, personal attendant service, homemaker and personal care agency services, home hospice, home-delivered meals, home reconfiguration or renovation, medication management, skilled nursing, escort service, telephone reassurance service, emergency help lines, equipment rental and exchange, and transportation. HCBS also includes educational and supportive group services for consumers or their families. Some services provided through HCBS are construed as respite care meant to relieve family caregivers. Formal rehabilitation may also be provided at home, usually as a short-term postacute service associated with Medicare.

## Background

Currently, more than 10 million community residents and 1 million nursing home residents need LTC to assist them with life's daily activities.5 The majority of these individuals (55 percent) are 65 years and older.5 About two-thirds of Americans age 65 and older will eventually need some type of LTC for an average of 2 years.6,7

LTC needs are met through a combination of paid assistance and unpaid services provided by family members. More than three-quarters of community-dwelling adults rely exclusively on unpaid LTC assistance from family members.2,5 Paid LTC services are financed through both public and private means. Medicaid, the public program jointly funded by federal and state governments and administered by the states, is the largest source of public funding for LTC, financing 40 percent of total national LTC spending.8

At present, almost 1.4 million individuals reside in the 15,690 nursing homes in the United States.9 Approximately 4 percent of the population age 65 and older live in nursing homes.10 NH care is a mandatory benefit under Medicaid for individuals that meet the eligibility criteria. In 2009, NH expenditures accounted for about 64 percent of the $80 billion in Medicaid LTC expenditures for older adults and people with physical disabilities.11

Costs per individual for NH care generally exceed those for HCBS. For this reason, states (the major decisionmakers for LTC policies and care) have increasingly prioritized HCBS as a method to restrain LTC costs. Other reasons for increased focus on HCBS include consumer preferences for more LTC in the community and the Supreme Court Olmstead decision stating that LTC services should be provided in the most integrated setting appropriate to the needs of qualified individuals with disabilities.12

About 43 percent of total Medicaid LTC dollars are dedicated to HCBS programs for all recipient groups. Medicaid spending is rising faster for HCBS than for NH. The national percentage of Medicaid spending on HCBS more than doubled from 1995 to 2009, from 19 percent to 43 percent.13 Within Medicaid, spending for HCBS varies among different populations. In 2009 HCBS expenditures accounted for about 36 percent of the $80 billion in Medicaid LTC expenditures for older adults and people with physical disabilities.11 The use and economic consequences of LTC services are expected to increase in the next few decades as the population ages.

States have various options for delivering HCBS, of which the Medicaid Section 1915(c) HCBS waivers are the most common. States can apply for HCBS waivers to the Centers for Medicare & Medicaid Services (CMS) to provide LTC through HCBS as opposed to NHs (www.medicaid.gov/Medicaid-CHIP-Program-Information/By-Topics/Waivers/Waivers.html).

The HCBS waivers allow states to offer services not typically covered under Medicaid to subsets of Medicaid beneficiaries (e.g., aged and physically disabled, intellectually and developmentally disabled) rather than as a universal benefit to all Medicaid beneficiaries within the state. Thus, individuals who meet certain minimum state-determined eligibility criteria (e.g., income and need requirements at a minimum of NH eligibility) are able to receive HCBS under Medicaid in lieu of NH services. Medicaid HCBS waivers allow states to limit the number of individuals who can receive services during a year and to use waiting lists if all approved slots are filled. Services that can be provided through waivers vary and include homemaker services, home health aide services, personal care services, adult day services, and case management.14 Waivers are subject to cost-neutrality requirements. This means that states must demonstrate to CMS that using HCBS waivers to serve institutionally eligible individuals costs the same or less than providing services to these individuals in NHs. States can initially receive approval for the HCBS waivers for 3 years, with potential for renewal every 3 or 5 years.15

States can also offer HCBS through state plan benefits. The most common state plan benefits are the mandatory home health state plan service and the optional personal care state plan service. Generally the state plan benefits must be available to all individuals who meet the eligibility requirements. Thus, these services cannot be limited as they can under the HCBS waivers.16 Services through the home health state plan include part-time nursing services, home health aide services, medical supplies and home equipment, and other services at state discretion. Personal care services include services that provide assistance with ADLs and IADLs. New options under the Deficit Reduction Act (DRA) of 2005 and the Patient Protection and Affordable Care Act of 2010 give states more flexibility with these programs.14

HCBS Medicaid dollars for community residential care are restricted to the service component and exclude room and board costs. Consumers are expected to cover room and board through their own income. NH care also requires most of the income of residents who are financed in full or part by Medicaid. NH payment, however, includes room and board, leaving the resident with only the state-permitted small personal needs allowance.

In addition to Medicaid, states use other mechanisms to fund LTC services. Older Americans Act (OAA) funding is appropriated to states to provide LTC services such as home-delivered meals, in-home assistance, and adult day services for individuals 60 and older. Many states also use general revenue funds to provide LTC services.17

About 22 percent of LTC services are financed by out-of-pocket payments. In the United States, Medicaid and out-of-pocket payments make up the majority of LTC spending. Only 9 percent is supported by private LTC insurance.8 About one in six individuals age 65 and older with an annual income greater than $20,000 have private LTC insurance coverage. Many such policies now include coverage for both HCBS and NH care, paying similar daily benefits for both.18

Initially, HCBS was considered an alternative to NH care. Early demonstration projects (from the mid 1970s through late 1980s) addressed the effectiveness and costs of expanding LTC to include HCBS. These projects generated some empirical literature as well as literature reviews.19-21 By the mid 1990s, newer models of organizing, financing, and delivering care were implemented. Medicaid-funded HCBS expanded substantially through the aforementioned waivers that allowed states to implement such care on a limited basis with funds that would have traditionally gone to NH care.

Many studies, including the National Long-Term Care Channeling Demonstration, found that HCBS did not reduce LTC spending.22,23 Some studies found that HCBS actually increased expenditures.24 Other studies found that after the initial increase needed to start an HCBS program, spending decreased in states with well-established noninstitutional programs compared with states with minimal noninstitutional services.25 Findings across states have been inconsistent due to the difficulty of assessing the cost and effectiveness of HCBS.15 Also, many studies have compared dissimilar populations or failed to use a control group.15

Thinking has shifted regarding the role of HCBS. The value of HCBS is no longer judged solely by its potential as a lower-cost substitute for NH care. Instead, HCBS is now viewed as an LTC modality that is preferred by many older adults and that may enhance their quality of life. A synthesis of the latest evidence and an assessment of the state of the literature may help inform the policy debate as well as highlight areas for future research.

Some programs that aim to keep people in home and community-based settings rather than in NHs loom in the background of this analysis. For example, PACE (Program of All-Inclusive Care of the Elderly) is a program designed to use capitated payment to better integrate services for older persons who are eligible for both Medicare and Medicaid and for NH care. PACE attempts, whenever possible, to substitute HCBS for NH care. Various types of residential housing for older people have begun to offer ascending levels of support in order to allow individuals to remain in residence even as their care needs increase.

### Comparing NHs and HCBS

Apples-to-apples comparisons and meaningful evaluations of outcomes between HCBS and NHs are challenging. Heterogeneity is significant among LTC recipients, both within and across settings. Delivered services vary by type, frequency, and intensity. Comparisons of HCBS and NHs require an understanding of the actual comparisons that investigators made—i.e., the characteristics of those served, the service mix, and the methods used to assess the populations served by HCBS and NHs.

LTC effectiveness is measured by the extent to which HCBS and NHs moderate the rate of functional decline or other well-being measures. Multiple measures across a range of domains (physical function, cognition, mental health, and quality of life) are used to assess outcome trajectories of HCBS recipients and NH residents over time.

Assessments of NH residents tend to rely on a standardized approach to data collection called the Minimum Data Set (MDS). Since 1999, all Medicare- and Medicaid-certified nursing homes have used the MDS (see https://www.cms.gov/site-search/search-results.html?q=minimum%20data%20set). The MDS relies primarily on data derived from staff observations and interpretations of behavior over a period of time. The latest version of the MDS (MDS 3.0), implemented in 2010, incorporates some resident interview items. As a tool designed to assess function in an institutional setting, the MDS emphasizes elements and domains relevant to the institutional experience. Full re-assessments are performed annually; specific parameters are re-assessed quarterly or if significant change has occurred. The MDS plays a crucial role for Medicare and Medicaid reimbursement.

The MDS has been adapted for use in the home-care setting. The home-care version (called the interRAI HC or MDS-HC) relies on the observations of those providing the home care. The items of the home version are not completely consistent with items of the MDS (see http://www.interrai.org).26 Unlike the MDS, which is almost universally used in U.S. NHs, the home version of this tool has not been widely adopted for individuals receiving HCBS.

Moreover, eligibility and plans for LTC services delivered through Medicaid waivers are most often based on direct assessments of clientele by case managers. Such assessments are not aligned with the MDS. To effectively compare and interpret outcome trajectories of HCBS recipients and NH residents over time, careful attention must be given to the domains addressed by the tools used for each group, the measures of disability used, the methods of ascertainment, and the appropriateness of the followup periods.

Comparisons of costs between the two settings are difficult. Cost comparisons must account for both costs to various public programs (i.e., spending by Medicaid and other public programs) and costs to individuals (i.e., spending by individuals and their families). This includes spending on LTC services and on other services. People receiving HCBS through Medicaid continue to be eligible for a variety of transfer programs not available to NH residents, including food stamps and housing subsidies. These expenditures must be counted. Other relevant costs include spending for acute care services such as physician and hospital care and medications. Because most acute care for older adults is paid for by Medicare, Medicare spending should be included. For those who are financially eligible, Medicaid pays premiums, deductibles, and co-pays for Medicare-covered services, so this Medicaid spending must be counted. Finally, the out-of-pocket and opportunity costs to individuals and families providing LTC assistance are relevant. The out-of-pocket costs include spending on LTC services and acute care services (including insurance premiums, deductibles, and co-pays). Opportunity costs include burden to family and other unpaid caregivers. Informal or unpaid caregiving occurs for both HCBS recipients and NH residents. In both cases, the time commitment is challenging to measure and itemize, because of the difficulty of distinguishing between the burden of additional care and ordinary family activity.

### Reason for the Review

The purpose of this review is to support policy and research decisionmaking. This review is timely, as policymakers try to determine the effectiveness and costs associated with different types of LTC. Current financial retrenchment and budgetary pressures intensify the need to identify effective means of delivering LTC services while minimizing costs. For the growing number of older adults who need LTC, identifying the setting or program that comports with their preferences while best serving their needs is a critical priority. This work complements an ongoing review on outcomes for cognitively impaired AL residents, conducted by the RTI-UNC Evidence-based Practice Center.

### Scope and Key Questions

#### Scope of the Review

This comparative effectiveness review targets direct comparisons of LTC provided through HCBS and in NHs. Substantial differences in case mixes between older adults served through HCBS and in NHs made indirect comparisons impossible. That is, heterogeneity in case mix precluded our ability to compare the findings of the two separate bodies of literature that focused either on older adults served by HCBS or on adults in NHs. We examined studies with both cross-sectional and longitudinal designs. Cross-sectional studies compare outcomes across settings at a specific point in time; whereas longitudinal studies compare changes in outcomes over a defined time period from 6 months to 5 years. We examined published and grey literature from the United States and published literature from economically developed countries with well-established health and LTC systems.

We defined population, intervention, comparator, outcomes, timing, and setting as follows:

#### Population

The population for this study included older adults (age ≥60) receiving LTC either through HCBS or in NHs, with adjustment for the age ceiling for PACE, where eligibility begins at 55. Patient characteristics that could modify outcomes include age, race/ethnicity, sex, socioeconomic status, functional status, clinical status, cognition, rural/urban, morbidities, mental illness, payer, prior service use, and disability history. We excluded studies that focused on postacute care, such as Medicare home health services. Postacute care is care provided to individuals discharged from a hospital; it is intended to aid in their recuperation and rehabilitation and typically lasts less than 30 days.

#### Intervention

HCBS refers to services provided in an array of noninstitutional settings. These include recipients' homes; community-based group-living arrangements such as congregate housing, adult foster care, and RC and AL facilities (the last two terms are sometimes used interchangeably, but we refer to AL exclusively); and community settings such as adult day care and adult day health. Services provided through HCBS include care coordination or case management, personal care assistant service, personal attendant service, homemaker and personal care agency services, home hospice, home delivered meals, home reconfiguration or renovation, medication management, skilled nursing, escort services, telephone reassurance services, emergency help lines, equipment rental and exchange, and transportation. Care through HCBS also includes educational and supportive group services for consumers or their families. Some aspects of HCBS are construed as respite care meant to relieve family caregivers.

For this review, we examine AL as a separate subset of HCBS, because it encompasses aspects of both community-based and institutional care.

#### Comparator

NHs are state-licensed institutional facilities offering 24-hour room and board, supervision, and nursing care. NH services may include personal care, support for ADLs, medical management, nursing management, medication management, restorative nursing, palliative care, physical rehabilitation (either as a short-term service associated with postacute care or as maintenance rehabilitation), social activities, and transportation.

#### Outcomes

We separately examined outcomes and costs. We used data from cross-sectional studies to compare the characteristics of HCBS recipients and NH residents. We used longitudinal data to assess change in outcomes over time between HCBS recipients and NH residents. Outcomes of interest included physical function, mental health outcomes (e.g., depression and anxiety), quality of life, social function, satisfaction, outcomes related to family caregivers, death, place of death, use of acute care services (e.g., hospitals, emergency departments), and harms such as accidents, injuries, pain, abuse, and neglect.

To examine costs, we considered all relevant costs to public programs such as Medicaid and other public programs and costs to individuals and their families. These costs included spending on LTC services, acute care services, and transfer programs, and opportunity costs to family caregivers.

#### Timing

The outcomes were assessed at 6 months to many years.

#### Setting

This review includes studies from the United States and international studies from economically developed countries with well-established health and LTC systems: Canada, United Kingdom, Australia, and New Zealand, as well as Norway, Sweden, and other European countries. We analyzed international studies separately.

#### Key Questions

We developed the Key Questions (KQs) after a topic refinement process. Topic refinement included a preliminary review of the literature and consultation with a Key Informant panel of LTC experts and stakeholders. Key Informants affirmed the importance of the issue of differences in case mix across settings in evaluating studies on LTC. Discussions with Key Informants also helped us define the settings and services covered under HCBS. Based on Key Informant input, we (1) identified HCBS settings to include recipients' own homes, group living arrangements such as room and board, adult foster care and assisted living, and nonresidential settings such as adult day care; and (2) excluded studies focusing on short-stay NH residents and recipients of Medicare home health services in order to confine the review to the LTC population.

The draft KQs were posted for public comment on the Agency for Healthcare Research and Quality (AHRQ) Effective Health Care Program Web site from October 10, 2011, to November 3, 2011. The comments received in response to the posting related to three themes: (1) whether individuals with specific diagnoses fare better as recipients of HCBS than as NH residents, (2) the impact of caregivers and caregiver-related outcomes across settings, and (3) the availability of HCBS and its effect on use of NHs. Public comments did not result in changes to the KQs because the questions already addressed the themes expressed.

We also received input from the Technical Expert Panel, who deemed the KQs to be appropriate. The panel did, however, recommend lowering the age limit for inclusion from 65 to 60 years to accommodate Medicaid waiver and other programs that set eligibility at age 60. We revised the age limit and added specific sub-questions (1a and 1b) to address the issue of differences in case mix across settings. The final KQs are below.

##### KQ 1 What are the benefits and harms of long-term care (LTC) provided through Home and Community-Based Services (HCBS) compared with institutions such as nursing homes (NHs) for older adults, aged 60 and older who need LTC?

a. To what extent do HCBS and NHs serve similar populations?
b. How do the outcomes of the services differ when tested on similar populations?
c. What are the harms to older adults as a result of care at HCBS and NHs? (Reported harms include accidents, injuries, inadequate preventive care, unnecessary hospitalizations, and concerns about abuse or neglect.)

##### KQ 2 What are the costs (at the societal and personal levels) of HCBS and NHs (per recipient and in the aggregate) for adults age 60 and older? Costs may include direct costs of care as well as resource use and family burden

Direct costs of care refer to public program and individual spending on LTC services for HCBS recipients and NH residents. Resource use includes program and individual spending on acute care services such as physician and hospital care as well as spending by other subsidy or transfer programs. Family burden includes the opportunity costs of care.

We anticipated that outcomes could be modified by patient characteristics. These include socio-demographic characteristics (age, sex, race/ethnicity); health status (functional, clinical status, morbidities, mental illness, disability); cognition; and other characteristics such as rural/urban location, socioeconomic status, payer status, and prior service use.

Figure 1 shows the analytical framework for our KQs.

Figure 1 Analytical framework for review of home and community-based services versus institutional care for older adults

KQ = Key Question; LTC = long-term care

Figure 1 depicts how long-term care (LTC) delivered through home and community-based services (HCBS) compared with care provided in nursing homes (NHs) may contribute to health outcomes in the target population (older adults age ≥60 years). Patient characteristics of interest that may modify outcomes include: age; race/ethnicity; sex; functional status; clinical status; cognition; rural/urban; morbidities; mental illness; socioeconomic status; payer; prior service use; disability history. LTC of older persons delivered through HCBS compared with NHs (KQ1a and KQ1b) may affect the following outcomes: physical function; social function; cognition; pain; death or place of death; mental health outcomes (e.g., depression, anxiety); satisfaction; quality-of-life outcomes (including health related quality-of-life); use of acute care services (e.g., hospitals, emergency departments); outcomes related to family caregivers (e.g., strain on family caregivers, health effects). Harms from LTC delivered through HCBS compared with NHs (KQ1c) include accidents, injuries, inadequate preventive care, unnecessary hospitalizations, and abuse or neglect. Costs for LTC delivered through HCBS compared with NHs (KQ2) include costs to programs (e.g., Medicaid and Medicare) and to individuals. Cost to programs include spending on LTC services, as well as spending on acute care services, housing subsidies, food stamps, and other transfer programs. Costs to individuals include out-of-pocket spending on LTC and acute care services (including insurance premiums, deductibles and co-pays) and costs of family burden.