# Peer Reviewers

Robert Applebaum, Ph.D.

Director, Ohio Long-term Care Research Project

Scripps Gerontology Center, Miami University

Oxford, OH

Lynn Feinberg, M.S.W.

AARP

Public Policy Institute

Senior Strategic Policy Advisor, Independent Living/Long-Term Care Team

Washington, DC

Penny Feldman, Ph.D.

Senior Vice President for Research and Evaluation

VNSNY, Center for Home Care Policy and Research

New York, NY

Charlene Harrington, Ph.D.

Professor Emeritus of Sociology and Nursing, Department of Social & Behavioral Sciences, UCSF

Director of UCSF National Center for Personal Assistance Services

San Francisco, CA

Mary Jane Koren, M.D., M.P.H.

Vice President for the Picker/Commonwealth Fund Long-Term Quality Improvement Program

The Commonwealth Fund

New York, NY

Nancy Miller, Ph.D.

Professor, Department of Public Policy

University of Maryland, Baltimore County

Baltimore, MD

Susan Miller, Ph.D.

Professor of Health Services, Practice and Policy (Research)

Department of Health Services, Practice and Policy

Center for Gerontology and Health Care Research, Brown University

Providence, RI

Vincent Mor, Ph.D.

Professor of Medical Science

Florence Pirce Grant University Professor of Community Health

Chair, Department of Community Health, Brown University

Providence, RI

Joshua Weiner, Ph.D.

Distinguished Fellow and Program Director, Aging Disability, and Long-Term Care Program

RTI International

Washington, DC