# Technical Expert Panel

Robert Applebaum, Ph.D.

Director, Ohio Long-term Care Research Project

Scripps Gerontology Center, Miami University

Oxford, OH

Pamela Doty, Ph.D.

Assistant Secretary for Planning and Evaluation

Office of Disability, Aging and Long-term Care Policy

Department of Health and Human Services

Washington, DC

David Gifford, M.D., M.P.H.

Senior Vice President of Quality and Regulatory Affairs

American Health Care Association

Washington, DC

David Kyllo

Executive Director, National Center for Assisted Living

Washington, DC

Susan Reinhard, Ph.D.

Senior Vice President, AARP Public Policy Institute

AARP

Arlington, VA

Robyn Stone, Ph.D.

Senior Vice President and Executive Director

Leading Age Center for Applied Research

Washington, DC

Anita Yuskauskas, Ph.D.

Technical Director for HCBS Quality

DEHPG, CMSO, Centers for Medicare & Medicaid Services

Baltimore, MD